# Bibliography

American Academy of Pediatrics. Committee on Infectious Diseases. Policy statement: recommendations for the prevention of pneumococcal infections, including the use of pneumococcal conjugate vaccine (Prevnar), pneumococcal polysaccharide vaccine, and antibiotic prophylaxis. Pediatrics. Aug. 2000;106(2 Pt 1):362-6. [pmid: 10920169].
Adelglass J, Bundy JM, Woods R. Efficacy and tolerability of cefprozil versus amoxicillin/clavulanate for the treatment of adults with severe sinusitis. Clin Ther. Nov-Dec. 1998;20(6):1115-29. [pmid: 9916606].
Adelglass J, Jones TM, Ruoff G, et al. A multicenter, investigator-blinded, randomized comparison of oral levofloxacin and oral clarithromycin in the treatment of acute bacterial sinusitis. Pharmacotherapy. 1998;18(6):1255-63. [pmid: 9855324].
Adelglass J, DeAbate CA, McElvaine P, et al. Comparison of the effectiveness of levofloxacin and amoxicillin/clavulanate for the treatment of acute sinusitis in adults.[see comment]. Otolaryngol Head Neck Surg. Mar. 1999;120(3):320-7. [pmid: 10064632].
Buchanan PP, Stephens TA, Leroy B. A comparison of the efficacy of telithromycin versus cefuroxime axetil in the treatment of acute bacterial maxillary sinusitis. Am J Rhinol. 2003;17(6):369-77. [pmid: 14750614].
Bucher HC, Tschudi P, Young J, et al. Effect of amoxicillin/clavulanate in clinically diagnosed acute rhinosinusitis: a placebo-controlled, double-blind, randomized trial in general practice.[see comment]. Arch Intern Med. Aug 11–25. 2003;163(15):1793-8. [pmid: 12912714].
Burke T, Villanueva C, Mariano H Jr, et al. Comparison of moxifloxacin and cefuroxime axetil in the treatment of acute maxillary sinusitis. Sinusitis Infection Study Group. Clin Ther. Oct. 1999;21(10):1664-77. [pmid: 10566563].
Chatzimanolis E, Marsan N, Lefatzis D, et al. Comparison of roxithromycin with co-amoxiclav in patients with sinusitis. J Antimicrob Chemother. Mar. 1998;41 Suppl B:81-4. [pmid: 9579718].
Clement PA, de Gandt JB. A comparison of the efficacy, tolerability and safety of azithromycin and co-amoxiclav in the treatment of sinusitis in adults. J Int Med Res. Mar-Apr. 1998;26(2):66-75. [pmid: 9602984].
Clifford K, Huck W, Shan M, et al. Double-blind comparative trial of ciprofloxacin versus clarithromycin in the treatment of acute bacterial sinusitis. Sinusitis Infection Study Group. Ann Otol Rhinol Laryngol. Apr. 1999;108(4):360-7. [pmid: 10214783].
Eskola J, Kilpi T, Palmu A, et al. Efficacy of a pneumococcal conjugate vaccine against acute otitis media. N Engl J Med. Feb 8. 2001;344(6):403-9. [pmid: 11172176].
Ferguson BJ, Anon J, Poole MD, et al. Short treatment durations for acute bacterial rhinosinusitis: Five days of gemifloxacin versus 7 days of gemifloxacin. Otolaryngol Head Neck Surg. Jul. 2002;127(1):1-6. [pmid: 12161723].
Gehanno P, Beauvillain C, Bobin S, et al. Short therapy with amoxicillin/clavulanate and corticosteroids in acute sinusitis: results of a multicentre study in adults. Scand J Infect Dis. 2000;32(6):679-84. [pmid: 11200381].
Gwaltney JM Jr, Savolainen S, Rivas P, et al. Comparative effectiveness and safety of cefdinir and amoxicillin/clavulanate in treatment of acute community-acquired bacterial sinusitis. Cefdinir Sinusitis Study Group. Antimicrobial Agents Chemother. Jul. 1997;41(7):1517-20.
Hansen JG, Schmidt H, Grinsted P. Randomised, double blind, placebo controlled trial of penicillin V in the treatment of acute maxillary sinusitis in adults in general practice. Scand J Prim Health Care. Mar. 2000;18(1):44-7. [pmid: 10811043].
Haye R, Lingaas E, Hoivik HO, et al. Azithromycin versus placebo in acute infectious rhinitis with clinical symptoms but without radiological signs of maxillary sinusitis. Eur J Clin Microbiol Infect Dis. May. 1998;17(5):309-12. [pmid: 9721958].
Henry DC, Moller DJ Jr, Adelglass J, et al. Comparison of sparfloxacin and clarithromycin in the treatment of acute bacterial maxillary sinusitis. Sparfloxacin Multicenter AMS Study Group. Clin Ther. Feb. 1999;21(2):340-52. [pmid: 10211537].
Henry DC, Sydnor A Jr, Settipane GA, et al. Comparison of cefuroxime axetil and amoxicillin/clavulanate in the treatment of acute bacterial sinusitis. Clin Ther. Jul. 1999;21(7):1158-70. [pmid: 10463514].
Henry DC, Riffer E, Sokol WN, et al. Randomized double-blind study comparing 3- and 6-day regimens of azithromycin with a 10-day amoxicillin/clavulanate regimen for treatment of acute bacterial sinusitis.[see comment]. Antimicrobial Agents Chemother. Sep. 2003;47(9):2770-4.
Jareoncharsri P, Bunnag C, Fooanant S, et al. An open label, randomized comparative study of levofloxacin and amoxicillin/clavulanic acid in the treatment of purulent sinusitis in adult Thai patients. Rhinology. Mar. 2004;42(1):23-9. [pmid: 15072030].
Johnson PA, Rodriguez HP, Wazen JJ, et al. Ciprofloxacin versus cefuroxime axetil in the treatment of acute bacterial sinusitis. Sinusitis Infection Study Group. J Otolaryngol. Feb. 1999;28(1):3-12. [pmid: 10077777].
Kaplan SL, Mason EO Jr, Wald ER, et al. Decrease of invasive pneumococcal infections in children among 8 children's hospitals in the United States after the introduction of the 7-valent pneumococcal conjugate vaccine.[see comment]. Pediatrics. Mar. 2004;113(3 Pt 1):443-9. [pmid: 14993532].
Klapan I, Culig J, Oreskovic K, et al. Azithromycin versus amoxicillin/clavulanate in the treatment of acute sinusitis. Am J Otolaryngol. 1920;(1):7-11.
Klein GL, Whalen E, Echols RM, et al. Ciprofloxacin versus cefuroxime axetil in the treatment of adult patients with acute bacterial sinusitis. J Otolaryngol. Feb. 1998;27(1):10-6. [pmid: 9511113].
Klossek JM, Siegert R, Nikolaidis P, et al. Comparison of the efficacy and safety of moxifloxacin and trovafloxacin for the treatment of acute, bacterial maxillary sinusitis in adults. J Laryngol Otol. Jan. 2003;117(1):43-51. [pmid: 12590855].
Kutluhan A, Akdeniz H, Kaya Z, et al. The treatment duration of acute maxillary sinusitis: how long should it be? A nasal smear controlled study. Rhinology. Dec. 2002;40(4):198-202. [pmid: 12526248].
Lasko B, Lau CY, SaintPierre C, et al. Efficacy and safety of oral levofloxacin compared with clarithromycin in the treatment of acute sinusitis in adults: a multicentre, double-blind, randomized study. The Canadian Sinusitis Study Group. J Int Med Res. Dec. 1998;26(6):281-91. [pmid: 10399110].
Lau J, Zucker D Engels EA Balk E et al. Diagnosis and treatment of acute bacterial rhinosinusitis. (Contract 290-97-0019 to the New England Medical Center). Evidence Report/Technology Assessment No.9. Rockville, MD, Agency for Health Care Policy and Research. 1999.
Lindbaek M, Kaastad E, Dolvik S, et al. Antibiotic treatment of patients with mucosal thickening in the paranasal sinuses, and validation of cut-off points in sinus CT. Rhinology. Mar. 1998;36(1):7-11. [pmid: 9569434].
Luterman M, Tellier G, Lasko B, et al. Efficacy and tolerability of telithromycin for 5 or 10 days vs. amoxicillin/clavulanic acid for 10 days in acute maxillary sinusitis. Ear Nose Throat J 2003 Aug;82(8):576–80, 82–4, 586 passim.
Murray JJ, Solomon E, McCluskey D, et al. Phase III, randomized, double-blind study of clarithromycin extended-release and immediate-release formulations in the treatment of adult patients with acute maxillary sinusitis. Clin Ther. Dec. 2000;22(12):1421-32. [pmid: 11192134].
Namyslowski G, Misiolek M, Czecior E, et al. Comparison of the efficacy and tolerability of amoxicillin/clavulanic acid 875 mg b.i.d. with cefuroxime 500 mg b.i.d. in the treatment of chronic and acute exacerbation of chronic sinusitis in adults. J Chemother. Oct. 2002;14(5):508-17. [pmid: 12462431].
National Kidney Foundation. K/DOQI clinical practice guidelines for chronic kidney disease: evaluation, classification, and stratification. Kidney Disease Outcome Quality Initiative. Am J Kidney Dis. Feb. 2002;39(2:Suppl 2):Suppl-246.
Rakkar S, Roberts K, Towe BF, et al. Moxifloxacin versus amoxicillin clavulanate in the treatment of acute maxillary sinusitis: a primary care experience. Int J Clin Pract. Jun. 2001;55(5):309-15. [pmid: 11452678].
Roos K, BrunswigPitschner C, Kostrica R, et al. Efficacy and tolerability of once-daily therapy with telithromycin for 5 or 10 days for the treatment of acute maxillary sinusitis. Chemotherapy. May. 2002;48(2):100-8. [pmid: 12011543].
Seggev JS, Enrique RR, Brandon ML, et al. A combination of amoxicillin and clavulanate every 12 hours vs. every 8 hours for treatment of acute bacterial maxillary sinusitis. Arch Otolaryngol Head Neck Surg. Aug. 1998;124(8):921-5. [pmid: 9708721].
Sher LD, McAdoo MA, Bettis RB, et al. A multicenter, randomized, investigator-blinded study of 5- and 10-day gatifloxacin versus 10-day amoxicillin/clavulanate in patients with acute bacterial sinusitis. Clin Ther. Feb. 2002;24(2):269-81. [pmid: 11911557].
Siegert R, Gehanno P, Nikolaidis P, et al. A comparison of the safety and efficacy of moxifloxacin (BAY 12-8039) and cefuroxime axetil in the treatment of acute bacterial sinusitis in adults. The Sinusitis Study Group. Respir Med. Apr. 2000;94(4):337-44. [pmid: 10845431].
Siegert R, Berg O, Gehanno P, et al. Comparison of the efficacy and safety of faropenem daloxate and cefuroxime axetil for the treatment of acute bacterial maxillary sinusitis in adults. Eur Arch Otorhinolaryngol. Apr. 2003;260(4):186-94. [pmid: 12709801].
Simon MW. Treatment of acute sinusitis in childhood with ceftibuten. Clin Pediatr. May. 1999;38(5):269-72.
Stefansson P, Jacovides A, Jablonicky P, et al. Cefuroxime axetil versus clarithromycin in the treatment of acute maxillary sinusitis. Rhinology. Dec. 1998;36(4):173-8. [pmid: 9923060].
Sterkers O. Efficacy and tolerability of ceftibuten versus amoxicillin/clavulanate in the treatment of acute sinusitis. Chemotherapy. Sep-Oct. 1997;43(5):352-7. [pmid: 9309369].
Steurer M, Schenk P. Efficacy and safety of cefdinir in the treatment of maxillary sinusitis. Eur Arch Otorhinolaryngol. 2000;257(3):140-8. [pmid: 10839487].
Varonen H, Kunnamo I, Savolainen S, et al. Treatment of acute rhinosinusitis diagnosed by clinical criteria or ultrasound in primary care. A placebo-controlled randomised trial. Scand J Prim Health Care. Jun. 2003;21(2):121-6. [pmid: 12877377].
Weis M, Hendrick K, Tillotson G, et al. Multicenter comparative trial of ciprofloxacin versus cefuroxime axetil in the treatment of acute rhinosinusitis in a primary care setting. Rhinosinusitis Investigation Group. Clin Ther. 1920;(5):921-32.
Whitney CG, Farley MM, Hadler J, et al. Decline in invasive pneumococcal disease after the introduction of protein-polysaccharide conjugate vaccine.[see comment]. N Engl J Med. May 1. 2003;348(18):1737-46. [pmid: 12724479].