# References and Included Studies

References

1 Lau J, Zucker D, Engels E et al. Diagnosis and treeatment of acute bacterial rhinosinusitis. Evidence Report/Technology Assessment No. 9 (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract 290-97-0019). Rockville, MD, Agency for Health Care Policy and Research. March 1999.
2 National Kidney Foundation. K/DOQI clinical practice guidelines for chronic kidney disease: evaluation, classification, and stratification. Kidney Disease Outcome Quality Initiative. Am J Kidney Dis. 2002;39(2:Suppl 2):Suppl-246.
3 Gehanno P, Beauvillain C, Bobin S, et al. Short therapy with amoxicillin/clavulanate and corticosteroids in acute sinusitis: results of a multicentre study in adults. Scand J Infect Dis. 2000;32(6):679-84. [pmid: 11200381].
4 Simon MW. Treatment of acute sinusitis in childhood with ceftibuten. Clin Pediatr. 1999;38(5):269-72.
5 Luterman M, Tellier G, Lasko B, Leroy B. Efficacy and tolerability of telithromycin for 5 or 10 days vs. amoxicillin/clavulanic acid for 10 days in acute maxillary sinusitis.Ear Nose Throat 2003;J82(8):576–80, 82–4, 586 passim.
6 Roos K, Brunswig Pitschner C, Kostrica R, et al. Efficacy and tolerability of once-daily therapy with telithromycin for 5 or 10 days for the treatment of acute maxillary sinusitis. Chemotherapy. 2002;48(2):100-8. [pmid: 12011543].
7 Ferguson BJ, Anon J, Poole MD, et al. Short treatment durations for acute bacterial rhinosinusitis: Five days of gemifloxacin versus 7 days of gemifloxacin. Otolaryngol Head Neck Surg. 2002;127(1):1-6. [pmid: 12161723].
8 Henry DC, Riffer E, Sokol WN, Chaudry NI, Swanson RN. Randomized double-blind study comparing 3- and 6-day regimens of azithromycin with a 10-day amoxicillin/clavulanate regimen for treatment of acute bacterial sinusitis.[see comment]. Antimicrobial Agents Chemother. 2003;47(9):2770-4.
9 Sher LD, McAdoo MA, Bettis RB, et al. A multicenter, randomized, investigator-blinded study of 5- and 10-day gatifloxacin versus 10-day amoxicillin/clavulanate in patients with acute bacterial sinusitis. Clin Ther. 2002;24(2):269-81. [pmid: 11911557].
10 Kutluhan A, Akdeniz H, Kaya Z, et al. The treatment duration of acute maxillary sinusitis: how long should it be? A nasal smear controlled study. Rhinology. 2002;40(4):198-202. [pmid: 12526248].
11 Faich GA, Morganroth J, Whitehouse AB, et al. Clinical experience with moxifloxacin in patients with respiratory tract infections. Ann Pharmacother. 2004;38(5):749-54. [pmid: 15026565].
12 Garrison N, Spector S, Buffington D, et al. Sparfloxacin for the treatment of acute bacterial maxillary sinusitis documented by sinus puncture. Ann Allergy Asthma Immunol. 2000;84(1):63-71. [pmid: 10674567].
13 American Academy of Pediatrics. Committee on Infectious Diseases. Policy statement: recommendations for the prevention of pneumococcal infections, including the use of pneumococcal conjugate vaccine (Prevnar), pneumococcal polysaccharide vaccine, and antibiotic prophylaxis. Pediatrics. 2000;106(2 Pt 1):362-6. [pmid: 10920169].
14 Kaplan SL, Mason EO Jr, Wald ER, et al. Decrease of invasive pneumococcal infections in children among 8 children's hospitals in the United States after the introduction of the 7-valent pneumococcal conjugate vaccine.[see comment]. Pediatrics. 2004;113(3 Pt 1):443-9. [pmid: 14993532].
15 Whitney CG, Farley MM, Hadler J, et al. Decline in invasive pneumococcal disease after the introduction of protein-polysaccharide conjugate vaccine.[see comment]. N Engl J Med. 2003;348(18):1737-46. [pmid: 12724479].
16 Eskola J, Kilpi T, Palmu A, et al. Efficacy of a pneumococcal conjugate vaccine against acute otitis media. N Engl J Med. 2001;344(6):403-9. [pmid: 11172176].