# Acknowledgments

We would like to acknowledge with appreciation the following members of the Technical Expert Panel for their advice and consultation to the Evidence-based Practice Center during preparation of this report.

## Technical Expert Panel

- Michael Barza, MD
- Director
- Department of Medicine
- Caritas Carney Hospital
- Dorchester, Massachusetts

- Michael Benninger, MD, FACS
- Cummings-Brush Chair in Surgical Education
- Chairman
- Department of Otolaryngology - Head & Neck Surgery
- Henry Ford Hospital
- Detroit, Michigan

- Larry Culpepper, MD, MPH
- Chairman of Family Medicine
- Boston University Medical Center
- Boston, Massachusetts

- Ellen Wald, MD
- Chief of Allergy, Asthma, and Infectious Disease
- Department of Pediatrics
- Children's Hospital of Pittsburgh
- Pittsburgh, Pennsylvania