# Conclusions and Discussion

This report examined the available evidence from randomized trials on the efficacy of antibiotics in patients with acute bacterial rhinosinusitis published since our original report in 1999. Overall, as in our previous report, antibiotics were found to be superior to placebo in the treatment of sinusitis, reducing the risk of clinical failure by almost 30%. Judging from the prevalence of comparisons involving amoxicillin/clavulanate, it appears that most investigators view this antibiotic as the preferred agent in a comparative drug trial. It is also more effective than the cephalosporin class of antibiotics in the treatment of sinusitis, reducing clinical failure rate by approximately 40% within 10–25 days after treatment initiation. However, in absolute terms, this implies that for every 100 patients treated with a cephalosporin, only about 3.5 more clinical failures would occur than in patients treated with amoxicillin/clavulanate. The superiority in clinical efficacy of amoxicillin/clavulanate over cephalosporins disappears when patients are examined for recurrence 24–45 days after treatment initiation.

There are only a few studies that specifically examined the effect of different treatment durations on outcome efficacy. In the one study of 10 vs. 5 days of amoxicillin/clavulanate, the 10-day regimen showed a statistically non-significant reduction of clinical failure by 27% (22% of patients failed on 5 days of treatment compared to 16% on 10 days of treatment). Studies on telithromycin (10 vs. 5 days), gemifloxacin (7 vs. 5 days), gatifloxacin (10 vs. 5 days) and azithromycin (6 vs. 3 days) all showed therapeutic equivalence between the 2 durations. In conclusion, most of the studies generally found no difference between shorter and longer duration of treatment.

It is difficult to compare the rates of adverse events across different antibiotic classes given the enormous variation in the reported rate of adverse events within the same antibiotic class. For example, the reported rate of diarrhea with amoxicillin/clavulanate across different studies ranged from under 2% to more than 30%. This may be due to a lack of an agreed definition of diarrhea, different study populations, and different reporting criteria. In all classes of antibiotics, gastrointestinal disturbances were most common, followed by headaches and skin rashes, as well as vaginal moniliasis. Cardiovascular complaints were rare. Severe adverse events in general occurred in up to about 3.5% of patients in all classes.

As of September 2004, there had not been any published studies examining the effect of the pneumococcal vaccine on the treatment of acute sinusitis. Preliminary surveillance data suggests a changing epidemiology of Streptococcus pneumoniae as a result of the introduction of the 7-valent pneumococcal vaccine in the pediatric population. Prevalence of different pneumococcal serotypes and their resistance patterns will have to be continually monitored to help guide the optimal treatment of acute sinusitis.

## Limitations

Heterogeneous study population across studies, different definitions of clinical success/failure, studies powered primarily for non-inferiority rather than superiority, relatively few studies within each comparison grouping, and the possibility of publication bias all lend limitations to our meta-analyses. Different inclusion criteria may also affect the comparability of the populations across studies. In some studies, patients were recruited from general practices and in others, from otolaryngology practices. In addition to requiring an abnormal sinus radiograph for study entry, some trials also included C-reactive protein and erythrocyte sedimentation rate cut-offs in their inclusion criteria. Definitions of cure ranged from symptomatic relief to radiographic resolution to no days with restricted activities at home or work. Sinus aspirations and cultures, the gold standard for diagnosing and assessing bacterial sinusitis were performed in a minority of trials.

Fifteen of 39 studies included in this review explicitly stated the power calculation used to determine sample size a priori. Virtually all of these studies were powered to demonstrate non-inferiority rather than superiority of one treatment over another. Given that the rate of spontaneous clinical resolution of acute bacterial sinusitis is approximately 65% and even higher with antibiotics, demonstration of superiority of one treatment over another requires extremely large sample sizes.

A notable omission compared to our previous report is the lack of comparative studies between newer expensive antibiotics and older inexpensive ones (like amoxicillin and trimethoprim-sulfamethoxazole). This has important implications for healthcare cost containment. We are unaware of any sound reasons in 2005 why amoxicillin and trimethoprim-sulfamethoxazole should not be used in comparative trials in treatment of bacterial sinusitis; although, our update did not specifically examine the resistance patterns of various pathogens in the last few years to amoxicillin and folate inhibitors.

## Future Research

In the future, more studies that incorporate bacteriological data will help characterize the changing epidemiology of acute sinusitis. We used per-protocol results for our meta-analyses, as these are more consistently reported than intention-to-treat results. To reduce the possibility of bias, intention-to-treat population should be uniformly defined across studies and data should be collected and reported in addition to per-protocol results.

Almost all the trials sponsored by pharmaceutical companies concluded that the sponsored drug was either superior or therapeutically equivalent to the comparator, thus raising the concern that there may be unpublished trials with negative results. This concern can only be resolved if results from all drug trials are duly reported. In addition, the pharmaceutical companies' research agenda appears to be driven by the desire to compare their products against those of their competitors. Such an agenda does not necessarily address clinically important issues that are relevant to the management of acute bacterial rhinosinusitis. Such potential bias can be addressed if there is funding from government and other independent entities to support research, which has as its primary objective the improvement of care of patients with acute bacterial rhinosinusitis.

Compared to our previous report in 1999, the quality of studies in this field has improved. All the studies stated explicit inclusion and exclusion criteria, method of analyses and primary outcome measurements. However, in order to make meaningful comparisons across studies; there should be general agreement in defining eligibility criteria, clinical success and failure, appropriate time of outcome assessment and precise criteria for numerators and denominators in the calculation of clinical success or failure rates.