# Results

From MEDLINE® we identified 704 citations for potential inclusion. Upon screening the abstracts, 87 articles were retrieved for full-text screening. A total of 39 studies ultimately qualified for inclusion in this update.

## 1. Given a clinical diagnosis of acute bacterial rhinosinusitis, what are the comparative efficacies of the antibiotics in resolving symptoms and preventing complications or recurrence?

We identified a total of 39 randomized controlled trials including 15,739 patients from 1997 to 2004 that studied antibiotic comparisons in treatment of acute bacterial sinusitis (Tables 1 & 2). With the exception of 5 studies that did not provide the information, all the studies were either funded by pharmaceutical companies or had authors associated with the pharmaceutical industry. Twelve of the studies consisted of subjects from the United States. Ten out of 39 studies included subjects less than 18 years old. No study was explicitly restricted to the pediatric population, although one study consisted only of subjects whose age ranged from 6 months to 17 years. Sample size of the studies ranged from 40 to 1,798. Of 13,220 patients whose per-protocol results were reported in the studies, less than 3 percent received placebo. All studies stated explicit requirements of clinical signs and symptoms of acute sinusitis for entry into the studies. In addition, 33 studies included results from either radiography or computed tomography (CT) scan of the sinuses as part of their eligibility criteria. Four studies are considered to be superior in methodological, reporting and data quality (A). Twenty-two studies are considered moderate (B) and nineteen studies low quality (C). The low quality studies often had limitations due to high dropout rate and incomplete reporting of data.

Table 1 Placebo-controlled antibiotic trials for the treatment of acute bacterial rhinosinusitis from 7/1997 to 8/2004

Author Year | Country | Funding | # Randomized or Enrolled | # per Protocol | Antibiotic | Dose | Duration | Time of evaluation of 1° outcome (days after start of Rx) | Clinical failure rate per protocol | Comments | Quality
Bucher 2003 | Switzerland | Pharm | 252 | 124 | Amox/Clav | 875/125 mg bid | 6 days | 14 | 23.4% | 1° outcome was “time to cure.” X-ray not required for inclusion. Eligibility criteria changed midway | C
| | | | 127 | Placebo | bid | | | 26%
Hansen 2000 | Denmark | Pharm | 139 | 71 | Penicillin V | 1333 mg bid | 7 days | 7 | 28%* | *calculated rates, differ from rates in abstract (29% for penicillin, 63% for placebo); X-ray not required for inclusion | C
| | | | 62 | Placebo | 2 tabs bid | | | 51.5%*
Haye 1998 | Norway | ND | 87 | 84 | Azithromycin | 500 mg qd | 3 days | 3–5 * | 6% | *Paper did not define this as the timing for 1° outcome.. | B
| | | 82 | 81 | Placebo | qd | | | 12.3% | Subjects should have no empyema on X-ray; 1 author associated with Pharm.
Lindbaek 1998 | Norway | Norwegian Research Council | 70 | 20 | Penicillin V | 1320 mg tid | 10 days | 10 | 10% | Subjects > 15 y/o; CT showed thickening without air-fluid levels or total opacification | C
| | | | 22 | Amoxicillin | 500 mg tid | | | 13.6%
| | | | 21 | Placebo | tid | | | 14.3%
Varonen 2003 | Finland | Government & industry | 150 | 88 | Amoxicillin 750 mg x2 or Penicillin V 1500 IU x2 or Doxycyclin 100 mg x2 | | 7 days | 14 | 20.5% | Subgroup data for each abx was not reported; X-ray not required for inclusion | A
| | | | 59 | Placebo | | | | 32.2%

Abx: antibiotics; Amox/clav: amoxicillin/clavulanate; bid: twice a day; Pharm: pharmaceutical industry; qd: once a day; qid:, four times a day; Rx: prescription; tid: three times a day; X-ray: sinus radiography; y/o, years old

Table 2 Antibiotic-comparison trials for the treatment of acute bacterial rhinosinusitis from 7/1997 to 8/2004

Author Year | Country | Funding | # Randomized or Enrolled | # per Protocol | Antibiotic | Dose | Duration | Time of evaluation of 1° outcome (days after start of Rx) | Clinical failure rate per protocol | Comments | Quality
Adelglass 1998 a | ND | Pharm | 140 | 108 | Cefprozil | 500 mg bid | 10 days | 11–15 | 13.9% | Subjects ≥ 13 y/o | C
| | | 138 | 111 | Amox/Clav | 500/125 mg tid | | | 8.1%
Adelglass 1998 b | ND | Pharm | 108 | 101 | Levofloxacin | 500 mg qd | 14 days | 16–19 | 4.0% | | B
| | | 108 | 89 | Clarithromycin | 500 mg bid | | | 6.7%
Adelglass 1999 | US | Pharm | 307 | 267 | Levofloxacin | 500 mg qd* | 10–14 days | 12–19 | 11.6% | *adjusted down if there is kidney impairment | B
| | | 308 | 268 | Amox/Clav | 500/125mg q8h* | | | 12.7%
Buchanan 2003 | Argentina France S. Africa US | Pharm | 240 | 189 | Telithromycin | 800 mg qd | 5 days | 16–24 | 14.8% | Subjects ≥13 y/o in non-US sites; ≥18 y/o in US | C
| | | 116 | 89 | Cefuroxime | 250 mg bid | 10 days | | 18%
Bucher 2003 | Switzerland | Pharm | 252 | 124 | Amox/Clav | 875/125 mg bid | 6 days | 14 | 23.4% | 1° outcome was “time to cure.” X-ray not required for inclusion. Eligibility criteria changed midway | C
| | | | 127 | Placebo | bid | | | 26%
Burke 1999 | North America | Pharm | 542 | 223 | Moxifloxacin | 400 mg qd | 10 days | 17–31 | 10.3% | | B
| | | | 234 | Cefuroxime | 250 mg bid | | | 10.7%
Chatzimanolis 1998 | Greece | Pharm | 60 | 29 | Roxithromycin | 150 mg bid | 10 days minimum | ~10–12 | 6.9% | | C
| | | | 27 | Amox/clav | 500/125 mg tid | | | 11.1%
Clement 1998 | ND | Pharm | 254 | 136 | Azithromycin | 500 mg qd | 3 days | 21–28 | 12.5% | 133 pts used vasoconstrictors, mucolytics & steroids. | B
| | | | 74 | Amox/clav | 500/125 mg tid | 10 days | | 16.2%
Clifford 1999 | ND | Pharm | 560 | 236 | Ciprofloxacin | 500 mg bid | 10 days | 16–19 | 15.7% | | B
| | | | 221 | Clarithromycin | 500 mg bid | 14 days | | 8.6%
Ferguson 2002 | Canada & 8 countries in Europe | Pharm | 423 | 181 | Gemifloxacin | 320 mg qd | 5 days | 18–25 | 12.7% | | B
| | | | 175 | | | 7 days | | 13.1%
Gehanno 2000 | France | Pharm | 433 | 181 | Amox/clav | 500 mg tid | 5 days | 14 | 21.6% | Some pts received steroids. | B
| | | | 179 | | | 10 days | | 15.6%
Gwaltney 1997 | US | ND | 585 | 474 | Cefdinir | 600 mg qd | 10 days | 17–24 | 10.3% | Subjects ≥13 y/o; X-ray not required for inclusion; 2 authors associated with Pharm. | B
| Europe | | 610 | 481 | | 300 mg bid | | | 12.7%
| | | 603 | 491 | Amox/clav | 500 mg tid | | | 9%
Steurer 2000 (subgroup of Gwaltney) 1997 | Europe | Pharm | 569 | 93 | Cefdinir | 600 mg qd | 10 days | 17–25 | 5.4% | Subjects ≥13 y/o; X-ray not required for inclusion. | C
| | | | 96 | | 300 mg bid | | | 10.4%
| | | | 106 | Amox/clav | 500/125 mg tid | | | 3.8%
Hansen 2000 | Denmark | Pharm | 139 | 71 | Penicillin V | 1333 mg bid | 7 days | 7 | 28%* | *calculated rates, differ from rates in abstract (29% for penicillin, 63% for placebo); X-ray not required for inclusion | C
| | | | 62 | Placebo | 2 tabs bid | | | 51.5%*
Haye 1998 | Norway | ND | 87 | 84 | Azithromycin | 500 mg qd | 3 days | 3–5 * | 6% | *Paper did not define this as the timing for 1° outcome. | B
| | | 82 | 81 | Placebo | qd | | | 12.3% | Subjects should have no empyema on X-ray; 1 author associated with Pharm.
Henry 1999 a | US | Pharm | 132 | 193 clinically assessable | Cefuroxime | 250 mg bid | 10 days | 36–40 | 50%* | *Calculated from reported satisfactory rate. | C
| | | 131 | | Amox/clav | 500 mg tid | | | 59%*
Henry 1999 b | US | Pharm | 252 | 219 | Sparfloxacin | 400 mg qd Day 1; 200 mg qd Days 2–10 | 10 days | 20±3 | 16.9%** | **calculated from reported success rate which is based on a denominator of total population minus the indeterminate cases | B
| | | 252 | 211 | Clarithromycin | 500 mg q12h | 14 days | | 16.6%**
Henry 2003 | US | Pharm | 941 | 272 | azithromycin | 500 mg qd | 3 days | 22–36 | 28.3% | | B
| | | | 271 | | | 6 days | | 26.6%
| | | | 251 | Amox/clav | 500/125 mg tid | 10 days | | 28.7%
Jareoncharsri 2004 | Thailand | Pharm | ND | 34 | Levofloxacin | 300 mg qd | 14 days | 21 | 8.8% | Subjects ≥16y/o | C
| | | | 26 | Amox/clav | 500/125 mg tid | | | 15.4%
Johnson 1999 | ND | Pharm | 501 | 228 | Ciprofloxacin | 500 mg bid | 10 days | 11–18 | 13% | | A
| | | | 225 | Cefuroxime | 250 mg bid | | | 17%
Klapan 1999 | ND | ND | 100 | 47 | Azithromycin | 500 mg qd | 3 days | 10–12 | 0% | Subjects ≥15 y/o; authors from Pharm. | B
| | | | 47 | Amox/clav | 500/125 mg tid | 10 days | | 0%
Klein 1998 | ND | Pharm | 83 | 13 | Ciprofloxacin | 500 mg bid | ≥ 10 days | ≥11–17 | 0% | Included subjects with acute exacerbation of chronic sinusitis | C
| | | | 19 | Cefuroxime | 250 mg bid | | | 26.3%
Klossek 2003 | 8 countries in Europe | ND | 503 | 223 | Moxifloxacin | 400 mg qd | 7 days | 17–20 | 3.1% | 2 authors associated with Pharm. | A
| | | | 229 | Trovafloxacin | 200 mg qd | 10 days | | 7.9%
Kultluhan 2002 | Turkey | ND | 10 | ND | Amox/clav 1 g bid or Ciprofloxacin 500 mg or Clarithromycin 500 mg bid or Cefuroxime 250 mg bid; Choice of antibiotics depended on maxillary sinus puncture and C&S results. | | 1 week | Day 28 | 50%* | *calculated relapse rate at day 28 assuming all patients completed the study; age range of subjects 16–45 y/o | C
| | | 10 | | | | 2 week | | 20%*
| | | 10 | | | | 3 week | | 20%*
| | | 10 | | | | 4 week | | 30%*
Lasko 1998 | ND | Pharm | 119 | 98 | Levofloxacin | 500 mg qd | 10–14 days | 12–19 | 6.1% | | B
| | | 117 | 93 | Clarithromycin | 500 mg bid | | | 6.5%
Lindbaek 1998 | Norway | Norwegian Research Council | 70 | 20 | Penicillin V | 1320 mg tid | 10 days | 10 | 10% | Subjects > 15 y/o; CT showed thickening without air-fluid levels or total opacification | C
| | | | 22 | Amoxicillin | 500 mg tid | | | 13.6%
| | | | 21 | Placebo | tid | | | 14.3%
Luterman 2003 | US Canada S. Africa Argentina Chile | Pharm | 754 | 146 | Telithromycin | 800 mg qd | 5 days | 17–24 | 24.7% | Stability problem with amox/clav, 100 pts from that group were excluded & replaced; data from excluded pts were not reported. | C
| | | | 140 | | | 10 days | | 27.1%
| | | | 137 | Amox/clav | 500/125 mg tid | 10 days | | 25.5%
Murray 2000 | US Canada | Pharm | 284 | 122 | Clarithromycin Extended release | 1000 mg qd | 14 days | 24–31 | 14.8% | Subjects ≥ 12 y/o | B
| | | | 123 | Clarithromycin immediate release | 500 mg bid | | | 21.1%
Namyslowski 2002 | Poland | ND | 231 | 104 | Amox/clav | 875/125 mg bid | 14 days | 15–18 | 2.9% | Included only subjects with chronic sinusitis & acute exacerbation of chronic sinusitis | B
| | | | 102 | Cefuroxime | 500 mg bid | | | 7.8%
Rakkar 2001 | US | Pharm | 475 | 170 | Moxifloxacin | 400 mg qd | 10 days | 24–31 | 14% | X-ray not required for inclusion | B
| | | | 171 | Amox/clav | 875 mg bid | | | 16%
Roos 2002 | 9 countries in Europe | ND | 341 | 123 | Telithromycin | 800 mg qd | 5 days | 17–21 | 8.9% | Patients with pathogens known to be resistant to telithromycin before Rx were excluded. 3 authors associated with Pharm. | C
| | | | 133 | | | 10 days | | 9%
Seggev 1998 | US Canada | Pharm | 170 | 61 | Amox/clav | 875/125 mg q12h | 14 days | 16–17 | 6.6% | Some pts received concurrent nasal steroids | C
| | | | 73 | | 500/125 mg q8h | | | 12.3%
Sher 2002 | ND | ND | 445 | 137 | Gatifloxacin | 400 mg qd | 5 days | 17–24 | 25.6% | 2 authors associated with Pharm. | B
| | | | 127 | | | 10 days | | 20.5%
| | | | 141 | Amox/clav | 875 mg bid | 10 days | | 28.4%
Siegert 2000 | 7 countries in Europe | ND | 493 | 211 | Moxifloxacin | 400 mg am | 7 days | 14 | 3.3% | 2 authors associated with Pharm. | B
| | | | 225 | Cefuroxime | 250 mg bid | 10 days | | 9.3%
Siegert 2003 | 7 countries in Europe | Pharm | 558 | 228 | Faropenem daloxate | 300 mg bid | 7 days | 14–23 | 11% | | B
| | | | 224 | Cefuroxime | 250 mg bid | | | 11.6%
Simon 1999 | US | ND | 50 | ND | Erythromycin-sulfisoxazole | Erythromycin component 10 mg/kg/ dose qid | 14 days | 17–27 (1 week after end of Rx) | 4%* | *reported failure rate, denominators not stated; age range of subjects: 6 months to 17 years; sinus films not obtained | C
| | | 50 | | Ceftibuten | 9 mg/kg/day, maximum 400 mg/day | 10 days | | 8%*
| | | 50 | | | | 15 days | | 8%*
| | | 50 | | | | 20 days | | 0%*
Stefansson 1998 | S. Africa and 7 countries in Europe | ND | 185 | 171 | Cefuroxime | 250 mg bid | 10 days | 11–14 and 38–45 | 9%** | **ITT, included failure & unevaluable patients; per protocol results similar but actual data not shown; 2 authors associated with Pharm. | C
| | | 185 | 175 | Clarithromycin | 250 mg bid | | | 7%**
Sterkers 1997 | France | ND | 458 | 134 | Ceftibuten | 400 mg qd | 8 days | 10 | 17.2% | Subjects ≥15 y/o | B
| | | | 138 | | 200 mg bid | | | 13%
| | | | 128 | Amox/clav | 500/125 mg tid | | | 10.9%
Varonen 2003 | Finland | Government & industry | 150 | 88 | Amoxicillin 750 mg ×2 or Penicillin V 1500 IU ×2 or Doxycyclin 100 mg ×2 | | 7 days | 14 | 20.5% | Subgroup data for each abx was not reported; X-ray not required for inclusion | A
| | | | 59 | Placebo | | | | 32.2%
Weis 1998 | US | Pharm | 1414 | 613 | Ciprofloxacin | 500 mg bid | 10 days | 14–26 | 8.8% | X-ray not required for inclusion. | B
| | | | 606 | Cefuroxime | 250 mg bid | | | 9.9%

Abx: antibiotics; Amox/clav: amoxicillin/clavulanate; bid: twice a day; C&S: culture and sensitivities; ITT: intention-to-treat analysis; ND: no data or not explicitly stated; Pharm: pharmaceutical industry; qd: once a day; qid: four times a day; Rx: prescription; tid: three times a day; X-ray: sinus radiography; y/o: years old.

The antibiotics studied are listed in Tables 1 & 2. The classes of antibiotics studied consist of penicillins, cephalosporins, macrolides, azalides, ketolides, quinolones, carbapenems and tetracyclines. There are a total of 112 comparisons reported in the 39 trials (Table 4); 7 compare antibiotics to placebos; 5 compare various antibiotics (including 2 placebos) to amoxicillin, 22 compare various antibiotics (including 1 placebo) to amoxicillin/ clavulanate; 10 compare various antibiotics to cefuroxime. In contrast to the previous evidence report, there was no comparison against trimethoprim/sulfamethoxazole.

Duration of treatment varied between 3 days and 4 weeks. Twenty-six of the studies included at least one antibiotic that was prescribed for 10 days. Primary outcome assessment took place anywhere from 3 days to more than 4 weeks after the initiation of treatment.

## Results of Meta-analyses

We performed 13 different meta-analyses to answer Research Question 1 regarding the comparative efficacy of different antibiotics on treatment failure and recurrence rates (Table 5). All meta-analyses were reported using per-protocol data from the primary studies. Meta-analyses were also performed substituting per-protocol data with modified intention-to-treat data available in 5 studies; results were similar and are not reported here. None of the cumulative meta-analyses ordered by study methodological quality demonstrated any alteration of treatment effect trend by the addition of studies with lower quality scores to those with higher quality scores. As a result, studies of all methodological quality are included in these meta-analyses.

Table 5 Per-protocol meta-analyses of treatment failure & recurrence with different antibiotics

Antibiotics Compared | Studies Included | Study Day of Assessment | Outcome Assessed | Risk Ratio (95%CI) | Risk Difference [per 100 people treated] (95% CI)
Antibiotics vs. Placebo | Bucher 2003* | 14 | Treatment Failure | 0.69 (0.53–0.89) | -7.47 (-14.26 - -0.68)
| Hansen 2000 | 7
| Haye 1998 | 10–12
| Lindbaek 1998^†^ | 10
| Varonen 2003 | 14
Cephalosporins vs. Amoxicillin/clavulanate | Adelglass 1998 a | 11–15 | Treatment Failure | 1.41 (1.08–1.82) | 3.62 (1.03–6.22)
| Gwaltney 1997^‡^ | 11–14
| Namyslowski 2002^‡^ | 15–18
| Sterkers 1997^‡^ | 10
| Adelglass 1998 a | 24 | Recurrence | 1.10 (0.83–1.45) | 2.37 (-0.75–5.49)
| Gwaltney 1997^†^ | 31–45
| Henry 1999 a | 36–40
| Sterkers 1997^†^ | 40
Macrolides, Azalides and Ketolides vs. Amoxicillin/clavulanate | Chatzimanolis 1998 | 10–17 | Treatment Failure | 0.76 (0.54–1.08) | -1.56 (-4.59–1.48)
| Henry 2003 | 8–15
| Klapan 1999 | 10–12
| Clement 1998 | 21–28 | Recurrence | 0.95 (0.79–1.14) | -2.34 (-6.45–1.78)
| Henry 2003 | 22–36
| Klapan 1999 | 28
| Luterman 2003^†^ | 31–45
Quinolones vs. Amoxicillin/clavulanate | Adelglass 1999 | 12–19 | Treatment Failure | 0.35 (.06–1.9) | -11.45 (-29.92–7.02)
| Jareoncharsri 2004 | 21
| Sher 2002 ^†^ | 12–24
| Adelglass 1999 | 38–46 | Recurrence | 0.74 (0.34–1.6) | -1.06 (-3.5–1.37)
| Rakkar 2001 | 36–56
Macrolides, Azalides and Ketolides vs. Cephalosporins | Buchanan 2003 | 16–24 | Treatment Failure | 0.81 (0.53–1.24) | -1.78 (-5.61–2.06)
| Simon1999 ^§^ | 17–25
| Stefansson 1998 | 11–13
| Buchanan 2003 | 31–45 | Recurrence | 1.11 (0.82–1.51) | 1.68 (-3.68–7.05)
| Simon 1999 ^§^ | 40–50
| Stefansson 1998 | 38–45
Quinolones vs. Cephalosporins (Cefuroxime) | Johnson 1999 | 11–17 | Treatment Failure | 0.68 (0.44–1.04) | -4.51 (-9.15–0.14)
| Klein 1998 | 14–25
| Siegert 2000^‡^ | 14
| Weis 1998 | 14–26
| Burke 1999 | 37–41 | Recurrence | 0.85 (0.57–1.27) | -1.07 (-3.44–1.29)
| Johnson 1999 | 24–38
| Klein 1998 | 27–46
| Siegert 2000 | 34–41
Quinolones vs. Macrolides (Clarithromycin) | Adelglass 1998 b | 16–19 | Treatment Failure | 1.01 (0.59–1.73) | 0.15 (-5.89–6.19)
| Clifford 1999^‡^ | 16–17
| Henry 1999 b | 20–23
| Lasko 1998 | 12–19
| Adelglass 1998 b | 42–46 | Recurrence | 0.70 (0.42–1.15) | -4.44 (-8.18 - -0.69)
| Clifford 1999^‡^ | 29–42
| Henry 1999 b | 31–45

* No significant difference was found between combined study arms evaluating antibiotics in the same class (P ≥.05).

‡ Per-protocol results for this study were significantly different than intent-to-treat results (P <.05).

‡ Treatment results were significantly different between combined study arms evaluating the same antibiotic class (P <.05).

§ Only studies with days of assessment entirely contained by the specified interval were included.

|| Results recorded 14 (vs. 7) days after treatment initiation were used.

Placebo-controlled trials. There were 5 trials (7 comparisons, total of 780 enrolled patients) comparing antibiotics to placebo. All of these trials recruited patients from a primary care setting. Four of the 5 trials used an antibiotic in the penicillin class, while the fifth trial compared azithromycin to placebo. Overall, antibiotics were more effective than placebo, reducing the risk of clinical failure by about 25% to 30% 7 to 14 days after treatment initiation (risk ratio [RR] 0.69, 95% confidence interval [CI] 0.53–0.89, Table 5). Nevertheless, symptoms improved or were cured in 65% of patients without any antibiotic treatment at all (95% CI 40–91%).

Antibiotic comparison trials. Five studies, involving a total of 3033 patients, compared various quinolones to cefuroxime. Except for one study, all antibiotics were given for 10 days. In the four studies that reported data for outcome assessment between 11 to 26 days after initiation of treatment, there was a non-statistically significant trend suggesting that quinolones were superior to cefuroxime in reducing clinical failure (RR 0.68, 95% CI 0.44 to 1.04).

There were four studies involving a total of 2765 patients, which showed that amoxicillin/clavulanate, when compared to antibiotics in the cephalosporin class, was 41% more effective in reducing clinical failure 10 to 25 days after treatment initiation (RR 1.41, 95% CI 1.08 to 1.82). In absolute terms, this means treating 100 patients with antibiotics in the cephalosporin class will lead to 3.5 more failures (95% CI 0.9 to 6.0) as compared to amoxicillin/clavulanate. However, data from four studies involving a total of 2797 patients did not show a significant difference in recurrence rates between amoxicillin-clavulanate and cephalosporins (RR 1.10, 95% CI 0.83 to 1.45) 24–45 days after treatment initiation.

There was no consistent trend observed when comparing amoxicillin/clavulanate, cephalosporins or quinolones to the group encompassing macrolides, azalides and ketolides.

## 1a. Is there evidence that duration of antibiotic treatment in acute bacterial rhinosinusitis affects efficacy?

There are eight studies that reported data on comparisons of the effect of treatment duration on outcomes (Table 6). One study that compared 10 days with 5 days of amoxicillin/clavulanate 500 mg tid reported a statistically non-significant 27% reduction in clinical failure rate ^3^ . Another study of ceftibuten concluded that 20 days of treatment may be more effective than either 10 days or 15 days regimen (0% failure rate vs. 8% vs. 8%, respectively) ^4^ ; however, the study did not report the actual number of patients who completed the study. Two studies of 10 days vs. 5 days of telithromycin reported that the clinical failure rate between the two treatment durations were comparable. ^5^ , ^6^ The studies on gemifloxacin (5 days vs. 7 days) ^7^ , azithromycin (3 days vs. 6 days) ^8^ and gatifloxacin (5 days vs. 10 days) ^9^ showed therapeutic equivalence of the 2 durations. One study compared nasal smear findings for certain periods after different durations of antibiotic treatment and concluded that at least 2 weeks of antibiotics would be an appropriate treatment duration for acute maxillary sinusitis because the average nasal smear score (derived from number of neutrophils) was significantly different beginning from study day 21 between the 7-day-antibiotic group and the other groups. ^10^

Table 6 Comparing different durations of treatment in sinusitis

Author Year | Country | Funding | # Randomized or Enrolled | # per Protocol | Antibiotic | Dose | Duration | Time of evaluation of 1° outcome (days after start of Rx) | Clinical failure rate per protocol | Comments | Quality
Ferguson 2002 | Canada & 8 countries in Europe | Pharm | 423 | 181 | Gemifloxacin | 320 mg qd | 5 days | 18–25 | 12.7% | | B
| | | | 175 | | | 7 days | | 13.1%
Gehanno 2000 | France | Pharm | 433 | 181 | Amox/clav | 500 mg tid | 5 days | 14 | 21.6% | Some pts received steroids. | B
| | | | 179 | | | 10 days | | 15.6%
Henry 2003 | US | Pharm | 941 | 272 | Azithromycin | 500 mg qd | 3 days | 22–36 | 28.3% | | B
| | | | 271 | | | 6 days | | 26.6%
| | | | 251 | Amox/clav | 500/125 mg tid | 10 days | | 28.7%
Kultluhan 2002 | Turkey | ND | 10 | ND | Amox/clav 1 g bid or Ciprofloxacin 500 mg or Clarithromycin 500 mg bid or Cefuroxime 250 mg bid; | | 1 week | 28 | 50%* | *calculated relapse rate at day 28 assuming all patients completed the study; age range of subjects 16–45 y/o; conclusion of study based on nasal smear results, not clinical failure rate | C
| | | 10 | | | | 2 week | | 20%*
| | | 10 | | Choice of abx depending on maxillary sinus puncture C&S results. | | 3 week | | 20%*
| | | 10 | | | | 4 week | | 30%*
Luterman 2003 | US | Pharm | 754 | 146 | Telithromycin | 800 mg qd | 5 days | 17–24 | 24.7% | Stability problem with amox/clav, 100 patients from that group were excluded & replaced; data from excluded pts were not reported. | C
| Canada | | | 140 | | | 10 days | | 27.1%
| S.Africa | | | 137 | Amox/clav | 500/125 mg tid | 10 days | | 25.5%
| Argentina
| Chile
Roos 2002 | 9 countries in Europe | ND | 341 | 123 | Telithromycin | 800 mg qd | 5 days | 17–21 | 8.9% | Pts with pathogens known to be resistant to telithromycin before Rx were excluded. 3 authors associated with Pharm. | C
| | | | 133 | | | 10 days | | 9%
Sher 2002 | ND | ND | 445 | 137 | Gatifloxacin | 400 mg qd | 5 days | 17–24 | 25.6% | 2 authors associated with Pharm. | A
| | | | 127 | | | 10 days | | 20.5%
| | | | 141 | Amox/clav | 875 mg bid | 10 days | | 28.4%
Simon 1999 | US | ND | 50 | ND | Erythromycin-sulfisoxazole | Erythromycin component 10 mg/kg/dose qid | 14 days | 17–27 (1 week after end of Rx) | 4%* | *reported failure rate, denominators not stated; age range of subjects: 6 month to 17 years; sinus films not obtained | C
| | | 50 | | Ceftibuten | 9 mg/kg/day, maximum 400 mg/day | 10 days | | 8%*
| | | 50 | | | | 15 days | | 8%*
| | | 50 | | | | 20 days | | 0%*

Abx: antibiotics; Amox/clav: amoxicillin/clavulanate; bid: twice a day; C&S: culture and sensitivities; ND: no data or not explicitly stated; Pharm: pharmaceutical ndustry; qd: once a day; qid: four times a day; Rx: prescription; tid: three times a day; y/o: years old

## 2. What adverse effects are reported for antibiotics used for acute bacterial rhinosinusitis?

Thirty-four of the comparative trials and five additional non-comparative trials reported adverse events. Descriptions of adverse events were diverse among studies. Almost all reported probable treatment-related adverse events, but many of them did not state the criteria for determining whether an event was considered likely treatment-related or not. Several studies also graded the severity of events; however, no study gave clear criteria for the grading scale. Other studies reported serious adverse events only. Few studies differentiated between severe (a description of degree) and serious (life-threatening, disabling or requiring prolonged hospitalization) events. Virtually all studies examined only short-term adverse events with assessment ending at the conclusion of patient follow-up 2 months or less after treatment initiation.

The overall percentage of subjects who reported at least one adverse event varied from 3% to 88% (Table 7). In general, an average adverse event rate of 15% to 40% of subjects was observed for the different classes of antibiotic. The adverse event rate for placebo was in this range, as well. Severe adverse events were rare, occurring in 0 to 7.7% of subjects. Severe adverse events included diarrhea, abdominal pain and nausea on amoxicillin/clavulanate; abdominal pain, diarrhea, constipation, urticaria, headache/dizziness, loss of appetite/disorientation/insomnia and vaginitis/monilia on levofloxacin; headache, asthenia, diarrhea, vomiting, dizziness and agitation on moxifloxacin; vaginitis, headache, nausea, diarrhea, arthralgia, increased cough and dyspnea on cefuroxime; diaphoresis/rash and loss of appetite/disorientation/insomnia on clarithromycin; and increased coagulation test on faropenem. Very few specific serious adverse events were reported by studies. Reported serious adverse events included diplopia on amoxicillin/clavulanate; myocardial infarction, lumbar disk lesion and neuropathy on levofloxacin; asthma on sparfloxacin; allergic reaction, facial/tongue edema, hepatitis, asthma and convulsion on gatifloxacin; maxillary antral abscess, convulsions, and collapse during local anesthesia on clarithromycin; facial edema on ciprofloxacin; amblyopia, ischemic heart disease and maxillary sinus surgery on cefuroxime; and tachycardia on moxifloxacin. Discontinuation due to adverse events was uncommon with fewer than 10% of subjects removed from any trial due to adverse events.

Table 7 Summary ranges of percent of patients experiencing adverse events with placebo and each antibiotic

| # of Studies | Subjects with Adverse Events,Overall% | Gastrointestinal | | | CNS | Skin/ Extr. | CV | Other^†^ | Study Withdrawal Due to Adverse Events | Severe Adverse Events
| | | Nausea/ Vomiting | Diarrhea | Abdominal Pain
PLACEBO
Placebo | 3 | 3.2–27.1 (18.3,15.6)* | 1.2 | 6.1–6.3 | 1.2–12.5 | | | | | 0–2.1 | 0
CEPHALOSPORINS
Cefdinir | 1 | 33.6 | 2 | 21 | 2.3 | 1.7 | | | | 2.3 | ND
Ceftibuten | 1 | 11.8 | 9.2 | | | | | | | 2.3 | ND
Cefprozil | 1 | 16.4 | 5 | 7.1 | | | 0.7 | | | 2.1 | ND
Cefuroxime | 10 | 9.2–45 (17.7, 22.5)* | 1.7–6.6 | 2–6.2 | 1.1–2.8 | 0.8–5.5 | 2.9 | 1.7 | Urogenital: 2.3–2.9 | 0.7–7.8 | 0–3.6
CARBAPENEMS
Faropenem | 1 | 16.8 | | | | | | | | 2.6 | 0.4
PENICILLINS
Amoxicillin/clavulanate | 17 | 7–51.1 (25.6, 30.2)* | 1.1–12.1 | 1.8–32.3 | 0.8–11.1 | 0–2.7 | 2.5–5.1 | | Vaginal moniliasis: 3–5.3 | 0–8.9 | 0–3.4
Penicillin | 1 | 18.3 | 15.5 | | | | | | | ND | ND
MACROLIDES, AZALIDES AND KETOLIDES
Azithromycin | 4 | 4–34.3 (22.6, 29.1)* | 4–8 | 4.2–19.1 | 3.4–4.2 | 3 | | 1 | | 0–2.9 | 0–3
Clarithromycin | 6 | 9.7–82.4 (43.9, 42.3)* | 4.8–7 | 5.6–27 | 3.6–3.7 | 0–9 | 0.5 | | Taste perversion: 7.7–20.9 | 3.2–5.7 | 7.7
Roxithromycin | 1 | 3.4 | 3.4 | | | | | | | ND | ND
Telithromycin | 3 | 22.2–42.4 (34.5, 35.3)* | 3.6–10.6 | 6–19.9 | 3.3–4.2 | 1.5–5.2 | | | Vaginal moniliasis: 2.4 | 2–6 | ≥3
QUINOLONES
Ciprofloxacin | 4 | 11.3–46 (38.3, 25.6)* | 2.5 | 1–6 | | 1.5–6.7 | | | | 0.4–3.8 | ND
Gatifloxacin | 2 | 14 | 4.4–11.4 | 1.4–8 | | 2.8 | | 0.4 | | 2.4 | 0.1–2.7
Gemifloxacin | 1 | 37 | ≥3 | ≥3 | | | | | | 0.7 | ND
Levofloxacin | 5 | 8.8–87.9 (22.7, 30.1)* | 0–5.6 | 0.9–2.7 | 1–1.9 | 2.8–6.7 | | 0.3 | | 1.8–3.7 | 0–6.7
Moxifloxacin | 6 | 12.2–58.1 (36.6, 18.8)* | 1.2–14.1 | 1.2–9.5 | 1.9–4.1 | 1.6–9.5 | 1.2–3.8 | 1.2 | Nervousness: 2.7–3.8 | 5.1–5.8 | 1.6–2.7
| | | | | | | | | Whole body: 3.8–9.5
Sparfloxacin | 2 | 45.6–54.9 (50.3, 50.3)* | 4.3–4.8 | 7.5–23.8 | 1.6–2 | 4.3 | 7.9–9.5 | 0 | | 3.6–4.4 | 0.4
Trovafloxacin | 1 | 32.7 | 4 | 1.2 | 1.6 | 11.6 | | | | Unclear | 0.8

Abd: abdominal; CNS: central nervous system (headache or dizziness/vertigo); CV: cardiovascular (palpitations, syncope, arrhythmia, cardiac insufficiency, etc.); ND: no data; Skin/Extr: skin (photosensitivity, rash, urticaria, eczema flare, etc.) or extremities;

* Median and weighted mean percentages reported if ≥2 studies for each antibiotic.

† Other adverse events occurring in ≥ 2% of patients in at least 2 studies.

It is difficult to compare the rates of occurrence of particular adverse events by antibiotic class given the heterogeneity among studies. Overall, the most common events involved the gastrointestinal system, specifically reports of nausea or vomiting, diarrhea and abdominal pain. Central nervous system adverse events, mostly complaints of headaches, were also common. Some subjects in each antibiotic class reported skin disorders, such as rash and photosensitivity. Taste perversion seemed to be a problem specific to clarithromycin administration with anywhere between 8% and 21% of study subjects reporting this complaint.

Cardiovascular problems were a particular concern to investigators of quinolones given their association with prolongation of the QT_c_ interval on electrocardiogram. Nevertheless, cardiac-related adverse event rates were low with quinolones, as well as for all classes of antibiotics. In the study conducted on 10,822 subjects with sinusitis by Faich et al. ^11^ , an independent safety committee was convened to search for a link between moxifloxacin and cardiac-related events. Investigators asked patients specifically about symptoms suggestive of a possible cardiac event such as chest pain or tachycardia; however, electrocardiograms were not routinely collected. The committee concluded that there was no evidence of increased mortality or detectable treatment-associated ventricular tachyarrhythmias in that trial. In a study of 253 patients treated with sparfloxacin conducted by Garrison et al. ^12^ which did collect electrocardiograms on all patients, there was a mean increase in the QT_c_ interval from baseline to day 4 of 0.010±0.024 sec., but no cardiovascular adverse events related to this increase.

Some women in each antibiotic class experienced vaginal moniliasis. Comparison of the rates of moniliasis between classes is problematic as the incidence reported by some studies may be under-estimated. Some reports are unclear as to whether they excluded men from the denominator in their calculations. Other studies did not specifically report the incidence of vaginal moniliasis but the incidence of vaginitis or urogenital complaints.

Tables 8 to 11 present the specific adverse events reported in each antibiotic class.

Table 8 Adverse events for placebo and penicillins, N (%)

| | Gastrointestinal
Study | Subjects with Adverse Events | Nausea/Vomiting | Diarrhea | Abd.Pain | CNS | Skin/Extr. | CV | Other^†^ | Study.Withdrawal Due to Adverse Events | Severe Adverse Events
PLACEBO
Hansen 2000 | 2/62 (3.2) | | | 1 (1.6) | | | | | ND | ND
Haye 1998 | 15/82 (18.3) | 1 (1.2) | 5 (6.1) | 1 (1.2) | | | | | 0 (0) | 0 (0)
Varonen 2003 | 13/48 (27.1) | | 3 (6.3) | 6 (12.5) | | 0(0) | | Fatigue 3 (6.3) | 1 (2.1) | ND
AMOXICILLIN/CLAVULANATE
Adelglass 1998 a | 53/138 (38.4) | 14 (10.1) | 35 (25.4) | | | 7 (5.1) | | | 9 (6.5) | ND
Adelglass 1999 | 146/302 (48.3) | 5 (1.7) | 35 (11.6) | 5 (1.7) | | | | | 16 (5.3) | 0 (0)
Chatzimanolis 1998 | 7/27 (25.9) | | 5 (18.5) | 3 (11.1) | | | | | Unclear | ND
Clement 1998 | 23/89 (25.8) | 1 (1.1) | 13 (14.6) | 7 (7.9) | 0 (0) | | | | 2 (2.2) | 3 (3.4)
Gehanno 2000 (Non-comparison study) | 46/433 (10.6) | X | X | X | | X | | | 8 (1.8) | ND
Gwaltney 1997 | 234/603(38.8) | 9 (1.5) | 133.(22.1) | 25.(4.1) | 16.(2.7) | | | Vaginal moniliasis: 18 (3.0) | 30 (5.0) | ND
Henry 2003 ^\|\|^ | 160/313(51.1) | 38 (12.1) | 101.(32.3) | | | | | | 28 (8.9) | 0 (0)
Henry 1999 a ^\|\|^ | 38/131 (29.0) | 6 (4.6) | 25 (19.1) | | | | | Vaginitis: 5 (3.8) | 8 (6.1) | ND
Jareoncharsri 2004 | 2/26 (7.7) | X | | | | | X | | ND | 0 (0)
Klapan 1999 | 5/50 (10) | 5 (10.0) | 1 (2.0) | | | | | | 0 (0) | 0 (0)
Luterman 2003^§^ | 101/245(41.2) | 19 (7.8) | 58.(23.7) | 6 (2.4) | 5.(2.0) | | | Vaginal moniliasis: 13 (5.3) | 11 (4.5) | ND
Namyslowski 2002 | 8/115 (7) | | 3 (2.6) | | | | | | 4 (3.5) | 0 (0)
Rakkar 2001 | 60/237(25.3) | 13 (5.5) | 24.(10.1) | 2 (0.8) | 5.(2.1) | 6 (2.5) | | Whole body: 20 (8.4) | 8 (3.4) | ND
| | | | | | | | Moniliasis: 15 (6.3)
| | | | | | | | Asthenia: 5 (2.1)
| | | | | | | | Urogenital: 9 (3.8)
| | | | | | | | Elevated LFTs: 11 (4.6)
Seggev 1998 | 26/170(15.3) | 4.(2.4) | 3.(1.8) | 6.(3.5) | 2.(1.2) | | | Fungal infection: 10 (5.6) | 4 (2.4) | 1 (0.6)
Sher 2002 | not reported | -4 | -14 | | | | | Vaginitis: (9% of women) | 3 (1.9)* | 4 (3)*
Sterkers 1997 | 16/146 (11) | 15 (10.3) | | | | | | | 5 (3.4) | ND
PENICILLIN
Hansen 2000 | 13/71 (18.3) | 11 (15.5) | | | | | | | ND | ND

Numbers reported are for all adverse events, unless only likely drug-related adverse events were reported by a study.

Abd: abdominal; CNS: central nervous system (headache or dizziness/vertigo); Skin/Extr: skin (photosensitivity, rash, urticaria, eczema flare, etc.) or extremities; CV: cardiovascular (palpitations, syncope, arrhythmia, cardiac insufficiency, etc.); X: actual percent not reported

* Denominator not specified, so based on number enrolled, or percentage stated by authors

† Only reported for adverse events that occurred in ≥ 2%; see study summaries for less common adverse events.

‡ Estimated from stated odds ratio

§ Study only reported adverse events that occurred on at least 2 occasions.

|| Study only reported adverse events that occurred in more than 5% of subjects

Table 9 Adverse events for cephalosporins and faropenem, N (%)

| | Gastrointestinal
Study | Subjects with Adverse Events | Nausea/Vomiting | Diarrhea | Abd.Pain | CNS | Skin/Extr. | CV | Other^†^ | Study.Withdrawal Due to Adverse Events | Severe Adverse Events
CEFDINIR
Gwaltney 1997 | 400/1189 (33.6) | 24 (2.0) | 250 (21.0) | 27 (2.3) | 20 (1.7) | | | | 27 (2.3) | ND
CEFIBUTEN
Sterkers 1997 | 36/304 (11.8) | 28 (9.2) | | | | | 7 (2.3) | ND
CEFPROZIL
Adelglass 1998 a | 23/140 (16.4) | 7 (5.0) | 10 (7.1) | | | 1 (0.7) | | | 3 (2.1) | ND
CEFUROXIME
Buchanan 2003 | 20/121 (16.5) | 8 (6.6) | 6 (5) | | | | 2 (1.7) | Abnormally low creatinine clearance | 2 (1.7) | ND
Burke 1999 | 112/274 (40.9) | 11 (5.1) | 17 (6.2) | 3 (1.1) | 15 (5.5) | 8 (2.9) | | Whole body: 15 (5.5) | 6 (2.2) | 10 (3.6)
| | | | | | | | Special senses: 9 (3.3)
| | | | | | | | Urogenital: 8 (2.9)
Henry 1999 b | 23/132 (17.4) | | 8 (6.1) | | | | | Vaginitis 3 (2.3) | 2 (1.5) | ND
Johnson 1999 | 113/251 (45)* | X | X | | X | | | | 6 (2.4)* | ND
Klein 1998 | 10/28 (34)* | X | X | | | | | | 1 (2.9)* | ND
Namyslowski 2002 | 11/116 (9.5) | | 3 (2.6) | | | | | | 9 (7.8) | 1 (0.9)
Siegert 2003 | 49/273 (17.9) | X | | | | X | | | 2 (0.7) | 0 (0)
Siegert 2000 | 88/252 (35.1) | 9 (3.6) | 15 (6.0) | 7 (2.8) | 2 (0.8) | | | | 11 (4.4) | ND
Stefansson 1998 | 17/185 (9.2) | 13 (7.0) | | | | | | | ND | ND
Weis 1998 | 81/700 (11.6) | 12 (1.7) | 14 (2.0) | | 12 (1.7) | | | | 26 (3.7) | ND
FAROPENEM
Siegert 2003 | 46/274 (16.8) | X | | | | X | | | 7 (2.6) | 1 (0.4)

Numbers reported are for all adverse events, unless only likely drug-related adverse events were reported by a study.

Abd: abdominal; CNS: central nervous system (headache or dizziness/vertigo); Skin/Extr: skin (photosensitivity, rash, urticaria, eczema flare, etc.) or extremities; CV: cardiovascular (palpitations, syncope, arrhythmia, cardiac insufficiency, etc.); X: actual percent not reported.

* Denominator not specified, so based on number enrolled, or percentage stated by authors.

† Only reported for adverse events that occurred in ≥ 2%; see study summaries for less common adverse events.

‡ Estimated from stated odds ratio

§ Study only reported adverse events that occurred on at least 2 occasions

|| Study only reported adverse events that occurred in more than 5% of subjects

Table 10 Adverse events for macrolides, azalides and ketolide, N (%)

Study | Subjects with Adverse Events | Gastrointestinal | | | CNS | Skin/Extr. | CV | Other^†^ | Study Withdrawal Due to Adverse Events | Severe Adverse Events
| | Nausea/ Vomiting | Diarrhea | Abd. Pain
AZITHROMYCIN
Clement 1998 | 29/165 (17.6) | 8 (4.8) | 7 (4.2) | 7 (4.2) | 5 (3) | | 2(1) | | 0 (0) | 5 (3)
Haye 1998 | 24/87 (27.6) | 7 (8) | 11 (12.6) | 3 (3.4) | | | | | 0 (0) | 1 (1.1)
Henry 2003 ^\|\|^ | 214/623 (34.3) | 50 (8) | 119 (19.1) | | | | | | 18 (2.9) | 0 (0)
Klapan 1999 | 2/50 (4) | 2 (4) | | | | | | | 0 (0) | 0 (0)
CLARITHROMYCIN
Adelglass 1998 b | 88/108 (82.4) | 7 (6.5) | 6 (5.6) | 4 (3.7) | 0 (0) | | | Taste perversion: 13 (12.0) | ND | ND
| | | | | | | | Fungal infection: 3 (2.8)
| | | | | | | | Insomnia: 3 (2.8)
Clifford 1999 | 158/278 (56.8) | Overall GI: 81 (29.1) | | | 25 (9) | | | Taste perversion: 58 (20.9) | 9 (3.2) | ND
| | Diarrhea: 36 (13.0) | | | | | | Special senses: 60 (21.6)
Henry 1999 b | 122/252 (48.4) | 12 (4.8) | 68 (27) | 9 (3.6) | | 1 (0.5) | | Taste perversion: 22 (8.7) | 14 (5.6) | ND
| | | | | | | | Elevated LFT's or blood glucose: 6 (2.4)
Lasko 1998 | 46/117 (39.3) | 39 (33.3) | | | 5 (4.3) | | | Taste perversion: 9 (7.7) | ND | 9 (7.7)
Murray 2000 | 85/283 (30) | (7) | (7) | | | | | Taste perversion: (10) | 16 (5.7) | ND
Stefansson 1998 | 18/185 (9.7) | 8 (4.3) | | | | | | | ND | ≥3
ROXITHROMYCIN
Chatzimanolis 1998 | 1/29 (3.4) | 1 (3.4) | | | | | | | Unclear | ND
TELITHROMYCIN
Buchanan 2003 | 56/252 (22.2) | 22 (8.7) | 15 (6) | | 7 (2.8) | | | Abnormally low creatinine clearance | 5 (2.0) | ND
Luterman 2003 ^\|\|^ | 211/498 (42.4) | 53 (10.6) | 99 (19.9) | 21 (4.2) | 26 (5.2) | | | Vaginal moniliasis: 12 (2.4) | 30 (6.0) | ≥1
Roos 2002 | 115/333 (34.5) | 12 (3.6) | 38 (11.4) | 11 (3.3) | 5 (1.5) | | | Vaginal moniliasis: 8 (2.4) | 7 (2.1) | ND

Numbers reported are for all adverse events, unless only likely drug-related adverse events were reported by a study.

Abd: abdominal; CNS: central nervous system (headache or dizziness/vertigo); Skin/Extr: skin (photosensitivity, rash, urticaria, eczema flare, etc.) or extremities; CV: cardiovascular (palpitations, syncope, arrhythmia, cardiac insufficiency, etc.); X: actual percent not reported

* Denominator not specified, so based on number enrolled, or percentage stated by authors

† Only reported for adverse events that occurred in ≥ 2%; see study summaries for less common adverse events.

‡ Estimated from stated odds ratio

§ Study only reported adverse events that occurred on at least 2 occasions

|| Study only reported adverse events that occurred in more than 5% of subjects

Table 11 Adverse events for quinolones, N (%)

Study | Subjects withAdverseEvents | Gastrointestinal | | | CNS | Skin/Extr. | CV | Other^†^ | Study Withdrawal Due to Adverse Events | Severe Adverse Events
| | Nausea/Vomiting | Diarrhea | Abd. Pain
CIPROFLOXACIN
Clifford 1999 | 120/282 (42.6) | Overall GI: 58 (20.6) Diarrhea: 17 (6.0) | | | 19 (6.7) | | | Taste Perversion: 7 (2.5) Special senses: 14 (5) | 9 (3.2) | ND
Johnson 1999 | 115/250 (46)* | X | X | | X | | | | 1 (0.4)* | ND
Klein 1998 | 10/28 (34)* | X | X | | | | | | 1 (3.6)* | ND
Weis 1998 | 80/711 (11.3) | 18 (2.5) | 7 (1) | | 11 (1.5) | | | | 27 (3.8) | ND
GATIFLOXACIN
Sher 2002 | ND | (11.4) | (8) | | | | | Vaginitis in women: (9) | 7 (2.7)* | 7 (2.7)*
Sher 2002 (non-comparison) | 1605/11,476(14) | 505 (4.4) | 161 (1.4) | | 321 (2.8) | | 41 (0.4) | | ND | 14 (0.1)
GEMIFLOXACIN
Ferguson 2002 | (37) | (≥3) | (≥3) | | | | | | 3 (0.7) | ND
LEVOFLOXACIN
Adelglass 1998 b | 94/107 (87.9) | 6 (5.6) | 1 (0.9) | 2 (1.9) | 3 (2.8) | | | | ND | 2 (1.9)
Adelglass 1999 | 114/297 (38.4) | 0 (0) | 4 (1.3) | 3 (1) | | | | | 11 (3.7) | 0 (0)
Jareoncharsri 2004 | 3/34 (8.8) | X | X | X | X | | | | ND | 0 (0)
Lasko 1998 | 27/119 (22.7) | 20 (16.8) | | | 8 (6.7) | | | | ND | 8 (6.7)
Sydnor 1998 | 29/329 (9) | 4 (1.2) | 9 (2.7) | | | | 1 (0.3) | | 6 (1.8) | 8 (2.4)
MOXIFLOXACIN
Burke 1999 | 126/263 (47.9) | 37 (14.1) | 18 (6.8) | 5 (1.9) | 25 (9.5) | 9 (3.4) | | Whole body: 25 (9.5)Nervousness: 7 (2.7) | 15 (5.7) | 7 (2.7)
Gehanno 2003^§^ | 31/255 (12.2) | 6 (2.4) | 3 (1.2) | 6 (2.4) | 4 (1.6) | 3 (1.2) | 3 (1.2) | | ND | ND
Faich 2004 | 1793/10,822 (16.6) | 827 (8.1) | 259 (2.4) | | 378 (3.5) | | | Whole body: 371 (3.4) | ND | ND
Klossek 2003 | 74/248 (29.8) | 3 (1.2) | 14 (5.6) | 5 (2) | 5 (2) | | | Asthenia: 5 (2.0) | ≥2 | 4 (1.6)
Rakkar 2001 | 136/234 (58.1) | 33 (14.1) | 7 (3) | 5 (2.1) | 9 (3.8) | 9 (3.8) | | Moniliasis 8 (3.4) Nervousness: 9 (3.8) Special senses 7 (3.0) | 12 (5.1) | ND
Siegert 2000 | 105/242 (43.3) | 17 (7) | 23 (9.5) | 10 (4.1) | 7 (2.9) | | | | 14 (5.8) | ND
SPARFLOXACIN
Henry 1999 b | 115/252 (45.6) | 12 (4.8) | 60 (23.8) | 4 (1.6) | | 24 (9.5) | | Elevated LFT's or blood glucose: 8 (3.2) | 11 (4.4) | ND
Garrison 2000 | 139/253 (54.9) | 11 (4.3) | 19 (7.5) | 5 (2) | 11 (4.3) | 20 (7.9) | 0 (0) | Insomnia: 7 (2.8) | 9 (3.6) | 1 (0.4)
TROVAFLOXACIN
Klossek 2003 | 82/251 (32.7) | 10 (4) | 3 (1.2) | 4 (1.6) | 29 (11.6) | | | Asthenia: 6 (2.4) | ≥6 | 2 (0.8)

Numbers reported are for all adverse events, unless only likely drug-related adverse events were reported by a study.

Abd: abdominal; CNS: central nervous system (headache or dizziness/vertigo); Skin/Extr: skin (photosensitivity, rash, urticaria, eczema flare, etc.) or extremities; CV: cardiovascular (palpitations, syncope, arrhythmia, cardiac insufficiency, etc.); X: actual percent not reported

* Denominator not specified, so based on number enrolled, or percentage stated by authors

† Only reported for adverse events that occurred in ≥ 2%; see study summaries for less common adverse events.

‡ Estimated from stated odds ratio

§ Study only reported adverse events that occurred on at least 2 occasions

|| Study only reported adverse events that occurred in more than 5% of subjects

## 3. How does the introduction of the pneumococcal vaccine affect the resistance patterns of pneumococcus and the treatment decisions in acute bacterial rhinosinusitis?

We did not identify any article in our literature search that directly addressed this question. Streptococcus pneumoniae is one of the most common pathogens identified in acute bacterial sinusitis. In the early 2000, a 7-valent pneumococcal conjugate vaccine (PCV7) was approved for routine administration to infants and children in United States. In the same year, the American Academy of Pediatrics (AAP) recommended routine administration of PCV7 to all children 23 months and younger. ^13^ It is therefore, important to monitor the changes in serotypes and antibiotic susceptibility of S. pneumoniae as a result of the introduction of PCV7 to the population. Furthermore, recommendations for treatment of acute bacterial sinusitis may well have to be modified depending on the results of the surveillance. Surveillance data are already appearing demonstrating the changing epidemiology of S. pneumoniae serogroups after the introduction of PCV7. Data collected from the US Pediatric Multicenter Pneumococcal Surveillance Group reported that before the licensure, nonvaccine serogroups accounted for 6% of the isolates recovered from children ≤ 24 months old; in 2002, nonvaccine-serogroup isolates were 37.6% of the total isolates in this age group. Also, among the isolates of S. Pneumoniae belonging to the serogroups contained in PCV7, the proportion that were nonsusceptible to penicillin decreased from 54% in 2001 to 43% in 2002. ^14^ Another report reported that rate of invasive pneumococcal disease decreased from an average of 24.3 cases per 100,000 persons in 1998 and 1999 to 17.3 per 100,000 in 2001. The largest decline was in children under two years of age. Disease rates also fell for adults. This observation suggests that the use of pneumococcal vaccine in children may be reducing the rate of disease in adults as well. ^15^ A randomized controlled trial between 1995 and 1999 involving 1,662 infants reported that the heptavalent pneumococcal vaccine reduced the number of episodes of acute otitis media by 6% (95% CI -4 to 16%) and also reduced the number of episodes due to the serotypes contained in the vaccine by 57% (95% CI 44 to 67%), whereas the number of episodes due to all other serotypes increased by 33%. ^16^ This suggests that the impact of pneumococcal immunization on acute sinusitis in adults will also depend on the virulence and resistance patterns of the serotypes that replace those contained in the vaccine.