# Methodology

The Tufts-NEMC EPC conducted a systematic review of the literature published since 1997 to summarize the evidence and we performed meta-analysis on comparative drug trials if there were 3 or more studies in the same grouping. We held meetings and teleconferences with technical expert representatives from three science partners (the American Academy of Family Physicians, American Academy of Otolaryngology-Head and Neck Surgery, and American Academy of Pediatrics) to refine the three research questions addressed in this evidence report. To answer the question on comparative efficacies of the antibiotics and the effect of different treatment durations on acute bacterial sinusitis, we sought only published results from randomized controlled trials. For the question on adverse events, we examined the reported adverse event data in these trials. For the question on pneumococcal vaccine's effect on treatment decision in acute sinusitis, we looked for published articles that directly addressed this question.

## Definitions

As in the original evidence report, we have focused this update on acute uncomplicated bacterial sinusitis. Sinusitis is defined as clinical signs and symptoms of inflammation of the paranasal sinuses and nasal passages (including: nasal congestion/discharge, nasal mucosa hyperemia, cough, fever, craniofacial pain/tenderness, periorbital edema, headache, toothache, earache, hyposmia/anosmia, halitosis, malaise, opacities/mucosal thickening/air-fluid level of the sinuses on standard films and/or CT scan, and positive sinus culture). Rhinosinusitis is included in this grouping. Acute duration is defined as having signs and symptoms of less than 30 days' duration. Uncomplicated sinusitis is defined as the lack of clinically evident neurological, soft tissue or other complications present prior to treatment initiation. Treatment failure is defined as the lack of improvement or worsening in signs and symptoms by the end of therapy. Recurrence includes persistent or relapsed disease assessed after a period of at least one week following the end of therapy. Some studies reported clinical success rate rather than clinical failure rate. In such instances, the clinical failure rate is calculated as: 100 percent clinical success rate.

## Search Strategy and Retrieval

We searched MEDLINE® using a broad search strategy covering the period from January 1997 to September 2004. The search terms were: “sinusitis,” “rhinosinusitis,” “anti-bacterial agents” and other relevant terms. See Appendix A. We limited search results to human and English-language studies. Studies of any age group were included.

For the question on pneumococcal vaccine and sinusitis, the search terms were: “vaccines”, “pneumococcal vaccine”, “sinusitis” and “rhinosinusitis”.

Additional sources of published articles were provided by members of the Technical Expert Panel (TEP), and also sought from reference lists of selected review articles and meta-analyses.

## Inclusion Criteria

Studies that

- included subjects with acute rhinosinusitis
- included subjects with acute exacerbation of chronic sinusitis
- included any age group, in any country
- were based in primary care and/or specialty clinics
- included at least 10 subjects in each treatment arm
- addressed component(s) of the Research Questions: efficacy of antibiotics, antibiotic treatment duration, antibiotic adverse effects, pneumococcal vaccine effect on resistance patterns
- were randomized, comparative trials (5 non-comparative studies were included in the review of adverse events only)

## Exclusion Criteria

Studies that

- included only patients with chronic sinusitis without acute exacerbation
- included other respiratory infections in addition to acute rhinosinusitis

## Adverse Events Data Extraction

Adverse event data were extracted from the antibiotic comparison studies obtained via the defined search strategy. In addition, we abstracted data from non-comparative antibiotic studies that included safety analyses. We did not seek out the adverse event data collected by the pharmaceutical companies. For each study we recorded the percentage of subjects who experienced at least one adverse event, the percentage who withdrew from a study due to adverse events, the percentage with severe adverse events and the percentage who experienced gastrointestinal, central nervous system, skin/extremity and/or cardiovascular events. In addition, any other adverse events occurring in at least 2% of study subjects were also extracted. For antibiotics with two or more studies, we calculated a median and weighted mean percentage of study subjects experiencing at least one adverse event.

## Methodological Quality Grading

We used a 3-category grading system (A, B, C) to denote the methodological quality of each study. This grading system has been used in most of the previous evidence reports from the Tufts-NEMC EPC as well as in evidence-based clinical practice guidelines. ^2^ For this report, we have slightly modified the grading system to take into account the percentage of dropout in the study. This system defines a generic grading system that is applicable to varying study designs including randomized controlled trials, cohort, and case-control studies:

A. Category A studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality including the following: a formal randomized study; clear description of the population, setting, interventions and comparison groups; sufficient power (arbitrarily defined as minimum sample size of 30 subjects per treatment arm); clear description of the intervention used; appropriate comparator; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; double-blinding; no reporting errors; less than 10% dropout; clear reporting of dropouts; and no obvious bias.
B. Category B studies are susceptible to some bias, but not sufficiently so as to invalidate the results. They do not meet all the criteria in category A because they have some deficiencies, but none likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
C. Category C studies have significant bias that may invalidate the results. These studies have serious errors in design, analysis or reporting, have large amounts of missing information, or discrepancies in reporting. Specific criteria included large (>20%) or unequal dropout rate, large discrepancy in baseline and final numbers of subjects, unclear duration or numbers of subjects, missing baseline data, or irreconcilable apparent differences between data in figures, tables, and text.

Two investigators independently reviewed each primary study for methodological quality according to this grading system. Discrepancies in assigned grade between investigators were resolved via discussion and consensus. In addition to applying this grading system to each study, additional comments relating to potential sources of bias and other study limitations were noted and recorded during data extraction. Such comments are included in the evidence tables.

## Meta-Analysis

Based on the available data, meta-analysis of primary studies was possible only for Research Question 1 regarding the comparative efficacies of antibiotics in the treatment of acute bacterial rhinosinusitis. Table 4 in chapter 3 shows the number of comparisons between the various antibiotics that were obtained by our search strategy. Meta-analysis was possible for the following comparisons:

Table 4 Comparison of antibiotics/placebo in the randomized controlled trials: each trial contributes 1 or more comparisons to the table

| | Penicillins | | | Cephalsporins | | | | Macrolides / Azalides / Ketolides | | | | | Quinolones | | | | | | | Others
| | Amoxicillin | Amoxicillin clavulanate | Penicillin | Cefprozil | Cefdinir | Ceftibuten | Cefuroxime axetil | Azithromycin | Clarithromycin | Erythromycin | Roxithromycin | Telithromycin | Gatifloxacin | Gemifloxacin | Ciprofloxacin | Moxifloxacin | Levofloxacin | Sparfloxacin | Trovafloxacin | Faropenem | Doxycycline | Placebo | Number of Comparisons for Each Drug
| Amoxicillin | | | 2 | | | | | | | | | | | | | | | | | | 1 | 2 | 5
Penicillins | Amoxicillin clavulanate | | 2 | | 1 | 2 | 2 | 2 | 4 | | | 1 | 2 | 2 | | | 1 | 2 | | | | | 1 | 22
| Penicillin | | | | | | | | | | | | | | | | | | | | | 1 | 3 | 6
| Cefprozil | | | | | | | | | | | | | | | | | | | | | | | 1
Cephalosporins | Cefdinir | | | | | 2 | | | | | | | | | | | | | | | | | | 4
| Ceftibuten | | | | | | 4 | | | | 3 | | | | | | | | | | | | | 9
| Cefuroxime axetil | | | | | | | | | 1 | | | 1 | | | 3 | 2 | | | | 1 | | | 10
| Azithromycin | | | | | | | | 1 | | | | | | | | | | | | | | 1 | 6
Macrolides / Azalides/ Ketolides | Clarithromycin | | | | | | | | | 1 | | | | | | 1 | | 2 | 1 | | | | | 6
| Erythromycin | | | | | | | | | | | | | | | | | | | | | | | 3
| Roxithromycin | | | | | | | | | | | | | | | | | | | | | | | 1
| Telithromycin | | | | | | | | | | | | 2 | | | | | | | | | | | 7
| Gatifloxacin | | | | | | | | | | | | | 1 | | | | | | | | | | 6
| Gemifloxacin | | | | | | | | | | | | | | 1 | | | | | | | | | 1
| Ciprofloxacin | | | | | | | | | | | | | | | | | | | | | | | 4
Quinolones | Moxifloxacin | | | | | | | | | | | | | | | | | | | 1 | | | | 4
| Levofloxacin | | | | | | | | | | | | | | | | | | | | | | | 4
| Sparfloxacin | | | | | | | | | | | | | | | | | | | | | | | 1
| Trovafloxacin | | | | | | | | | | | | | | | | | | | | | | | 1
Others | Faropenem | | | | | | | | | | | | | | | | | | | | | | | 1
| Doxycycline | | | | | | | | | | | | | | | | | | | | | | 1 | 3
Placebo | Placebo | | | | | | | | | | | | | | | | | | | | | | | 7

1. antibiotics with placebo for treatment failure
2. cephalosporins with amoxicillin/clavulanate for treatment failure and recurrence
3. the combined category of macrolides/azalides/ketolides with amoxicillin/clavulanate for treatment failure and recurrence
4. quinolones with amoxicillin/clavulanate for treatment failure and recurrence
5. macrolides/azalides/ketolides with cephalosporins for treatment failure and recurrence
6. quinolones with cephalosporins for treatment failure and recurrence
7. quinolones with macrolides for treatment failure and recurrence

We calculated risk ratios and risk differences for each of these comparisons. All meta-analyses were performed using a random effects model. Similar to our previous report, cumulative meta-analyses ordered by methodological quality of the studies were used to explore possible treatment effect trends as studies with lower quality scores were added to studies with higher quality scores. We used a three level quality score (from A to C) in this meta-analysis.

Several studies reported intention-to-treat data in addition to per-protocol data. However, because intention-to-treat data were not uniformly defined and less common, all meta-analyses were reported using per-protocol data. Some studies included multiple study arms comparing different doses of the same antibiotic. Chi-square analyses were used to determine the presence of heterogeneity in treatment outcome between different doses of the same antibiotic. To avoid arbitrarily selecting one treatment dose, multiple study arms evaluating the same antibiotic were combined for meta-analyses.

A few studies reported rates of microbiological treatment failure. However, because no more than 2 to 3 such studies were available for each comparison, we did not perform meta-analysis on microbiological treatment results.

## Peer Review Process

The EPC requested nominations for potential external reviewers from the members of the Technical Expert Panel, which included the original individuals appointed to the first Panel in 1998 by the American Academy of Family Physicians, American Academy of Otolaryngology-Head and Neck Surgery, and American Academy of Pediatrics. The EPC also directly contacted researchers in the field inviting them to peer review. We provided material to reviewers, including the draft evidence report, guidance on the review process, and a structured evaluation form for collecting feedback from reviewers. We collated responses received from reviewers and made these available the EPC evidence review team. We then produced a structured summary report of the reviewers' comments and the responses made by the EPC review team for review by the AHRQ Task Order Officer.