# Appendix D: Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

- David Atkins, MD, MPH
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, Maryland

- Michael Brady, MD
- College of Medicine and Public Health
- Ohio State University
- Columbus, Ohio
- Chair, Clinical Affairs Committee
- Pediatric Infectious Disease Society

- Richard Haydon, MD
- Chandler Medical Center
- University of Kentucky
- Lexington, Kentucky
- Chair, Allergy and Immunology Committee
- American Academy of Otolaryngology-Head and Neck Surgery

- Mark Sawyer, MD
- University of California, San Diego School of MedicineLa Jolla, California
- Reviewer, Pediatric Infectious Disease Society

- Jonathan L. Temte, MD, PhD
- Department of Family Medicine
- University of Wisconsin
- Madison, Wisconsin
- Reviewer, American Academy of Family Physicians
- Executive committee,
- Section on Otolaryngology
- American Academy of Pediatrics