# Appendix C: Evidence Tables

## Adelglass et al. 1998 ID 534

Stated Purpose of the Study: To compare the efficacy and tolerability of cefprozil with amoxicillin/clavulanate in the treatment of adults with severe acute bacterial sinusitis

Population & Setting: 278 patients from multi-center enrolled in the study, study years not specified. Patients were stratified according to the severity of disease before randomization.

Baseline statistics:
Cefprozil | 140 | Mean age 36.9 | Males 42%
Amox/Clav | 138 | Mean age 37 | Males 50%

Inclusion criteria: ≥ 13 y/o; signs and symptoms of acute sinusitis; abnormal sinus x-ray, women of childbearing potential were required to have a negative pregnancy test on enrollment, be using an acceptable method of contraception, and not be lactating

Exclusion criteria: hx of hypersensitivity to beta-lactam abx; abx within 24 h of study entry, long-acting parenteral PCN within 2 weeks of enrollment; see paper for others

Study design: Multicenter, open-label study. To achieve balance in the severity of signs and symptoms, the eligible patients were stratified according to the severity of disease before randomization. Method of randomization not explicitly stated.

Treatments:

Cefprozil 500 mg twice a day for 10 days

Amox/Clav 500/125 mg three times a day for 10 days

Outcome:

Primary - clinical response satisfactory (either cure or improvement, based on a clinical score) or unsatisfactory, assessed on days 11–15 (after the initiation of treatment)

Secondary - assessment for relapse 2 weeks after the end of therapy Sinus cultures were not performed as part of the study. See paper for subgroup analysis for “severe sinusitis.”

Results:

278 patients randomized into 2 groups (cefprozil 140; amox/clav 138)

219 assessable for efficacy (cefprozil 108; amox/clav 111)

Clinical failure - Cefprozil 15/108 (13.9%); Amox/Clav 9/111 (8.1%)

2-week post treatment follow up Failure - Cefprozil 18/100 (18%); Amox/Clav 16/99 (16.2%)

Adverse events:

At least one event | cefprozil | 23/140 (16.4%) | amox/clav | 53/138 (38.4%)
Diarrhea | | 10/140 (7.1%) | | 35/138 (25.4%)
Nausea | | 4/140 (2.9%) | | 12/138 (8.7%)
Rash | | 1/140 (0.7%) | | 7/138 (5.1%)

See table VII in paper for others.

3 patients treated with cefprozil and 9 patients treated with amox/clav discontinued treatment because of adverse events, most commonly diarrhea (cefprozil 2; amox/clav 7).

Funding: Bristol-Myers Squibb

Comments:

## Adelglass et al. 1998 ID 540

Stated Purpose of the Study: To compare the clinical efficacy and safety of oral levofloxacin once daily for 14 days with those of oral clarithromycin twice daily for 14 days in patients with acute bacterial sinusitis

Population & Setting:

216 patients from 20 sites were randomized into 2 groups (108 in each group).

Levofloxacin | 101 | mean age (range) | 41.1 (18–83) | males | 58.4%
Clarithromycin | 89 | mean age (range) | 38.8 (19–68) | males | 70.8%

Inclusion criteria: ≥ 18 y/o; radiograph supported dx of acute bacterial sinusitis (see paper for details regarding clinical criteria); x-ray showed opacification, air-fluid level, and/or mucosal thickening of ≥ 5 mm; see paper for others

Exclusion criteria: chronic sinusitis (presence of current signs/symptoms for > 4 weeks or > 2 episodes of acute sinusitis within the past 12 months); calculated creatinine clearance ≤ 50 ml/min; nasal steroids and others (see paper)

Study design: randomized, single (investigator) - blinded, parallel group study; subject randomization list was computer-generated and stratified by site; equal numbers of subjects were assigned to each treatment group;

Treatments:

Levofloxacin oral 500 mg once daily in AM for 14 days

Clarithromycin oral 500 mg twice a day for 14 days

Outcome:

Primary: clinical response 2–5 days post treatment; clinical success was defined as cure or improvement

Secondary: relapse rate assessed one month after therapy

Results:

216 patients were randomized; 190 evaluable. 4/101 in Levofloxacin group withdrew due to symptomatic failure; 5/89 in Clarithromycin group withdrew (4 due to symptomatic failure; 1 for other reasons)

Reported clinical failure rate: | Levofloxacin | 4/101 (4%) | Clarithromycin | 6/89 (6.7%)
ITT analysis: | Levofloxacin | 8/108 (7.4%) | Clarithromycin | 17/108 (15.7%)
One month after therapy relapse rate: | Levofloxacin | 4/97 (4.1%) | Clarithromycin | 6/83 (7.2%)

Adverse events:

2 serious events in Levofloxacin group, lumbar disk lesion and neuropathy, not felt to be treatment related by investigator

| Levofloxacin (n=107) | Clarithromycin (n=108)
At least one adverse event | 94 (87.9%) | 89 (82.4%)
Drug-related adverse event | 15 (14%) | 25 (23.1%)
Abdominal pain | 2 (1.9%) | 4 (3.7%)
Dizziness | 3 (2.8%) | 0
Nausea | 6 (5.6%) | 7 (6.5%)
Diarrhea | 1 (0.9%) | 6 (5.6%)
Insomnia | 1 (0.9%) | 3 (2.8%)
Taste perversion | 1 (0.9%) | 13 (12%)
Fungal infection | 2 (1.9%) | 3 (2.8%)

See table 3 in paper for rest.

Funding: Ortho-McNeil Pharmaceutical

Comments:

Table 3 Randomized controlled trials of antibiotics in treatment of sinusitis from 7/1997 to 8/2004

Author Study ID | Penicillins | | | Cephalosporins | | | | Macrolides/ Azalides/Ketolides | | | | | Others | | Quinolones | | | | | | | Placebo
| Amoxicillin | Amox/ clav | Penicillin | Cefprozil | Cefdinir | Ceftibuten | Cefuroxime | Azithromycin | Clarithromycin | Erythromycin | Roxithromycin | Telithromycin | Doxycycline | Faropenem | Gatifloxacin | Gemifloxacin | Ciprofloxacin | Moxifloxacin | Levofloxacin | Sparfloxacin | Trovafloxacin
Adelglass ID 534 | | x | | x
Adelglass ID 540 | | | | | | | | | x | | | | | | | | | | x
Adelglass ID 490 | | x | | | | | | | | | | | | | | | | | x
Buchanan ID 95931 | | | | | | | x | | | | | x
Bucher ID 9 | | x | | | | | | | | | | | | | | | | | | | | x
Burke ID 524 | | | | | | | x | | | | | | | | | | | x
ChatzimanolisID585 | | x | | | | | | | | | x
Clement ID 583 | | x | | | | | | x
Clifford ID 480 | | | | | | | | | x | | | | | | | | x
Ferguson ID 225 | | | | | | | | | | | | | | | | xx
Gehanno ID 373 | | xx
Gwaltney ID 648 | | x | | | xx
Hansen ID 97079 | | | x | | | | | | | | | | | | | | | | | | | x
Haye 1998 | | | | | | | | x | | | | | | | | | | | | | | x
Henry ID 10 | | x | | | | | | xx
Henry ID 482 | | | | | | | | | x | | | | | | | | | | | x
Henry ID 462 | | x | | | | | x
Jareoncharsri ID 34 | | x | | | | | | | | | | | | | | | | | x
Johnson ID 491 | | | | | | | x | | | | | | | | | | x
Klapan ID 500 | | x | | | | | | x
Klein ID 599 | | | | | | | x | | | | | | | | | | x
Klossek ID 164 | | | | | | | | | | | | | | | | | | x | | | x
Lasko ID 530 | | | | | | | | | x | | | | | | | | | | x
Lindbaek 1998 | x | | x | | | | | | | | | | | | | | | | | | | x
Luterman ID 97041 | | x | | | | | | | | | | xx
Murray ID 375 | | | | | | | | | xx
Namyslowski ID 189 | | x | | | | | x
Rakkar ID 97064 | | x | | | | | | | | | | | | | | | | x
Roos ID 240 | | | | | | | | | | | | xx
Seggev ID 563 | | xx
Sher ID 257 | | x | | | | | | | | | | | | | xx
Siegert ID 143 | | | | | | | x | | | | | | | x
Siegert ID 415 | | | | | | | x | | | | | | | | | | | x
Simon ID 475 Pedi | | | | | | xxx | | | | x
Stefansson ID 97076 | | | | | | | x | | x
Sterkers ID 633 | | x | | | | xx
Varonen ID 97080 | x | | x | | | | | | | | | | x | | | | | | | | | x
Weis ID 545 | | | | | | | x | | | | | | | | | | x

Amox/clav: amoxicillin/clavulanate

## Adelglass et al. 1999 ID 490

Stated Purpose of the Study: To compare the efficacy and safety of levofloxacin 500 mg orally once daily for 10–14 days with those of amox/clav 500/125 mg orally 3 times daily for 10–14 days in treating acute sinusitis in adult outpatients.

Population & Setting: 615 patients from 28 centers in US enrolled in the study. 307 randomly assigned to levofloxacin and 308 to amox/clav. Patients were enrolled by both office-based primary care physicians and otolaryngologists, study years not specified.

Baseline statistics:
Levofloxacin | 306 | Mean age (range) | 39.2 (18–85) | Males | 37.6%
Amox/Clav | 309 | Mean age (range) | 38.6 (18–84) | Males | 35.6%

Inclusion criteria: ≥ 18 y/o; female and male outpatients with 2/5 typical signs and symptoms of acute sinusitis (see paper for details); radiographic evidence including air-fluid level, opacification, or ≥ 4 mm mucosal thickening of at least 1 sinus on sinus x-ray, CT, or sinus scope

Exclusion criteria: hx of hypersensitivity to beta-lactam abx levofloxacin or any quinolone; chronic sinusitis > 4 weeks, pregnancy (or inability to r/o pregnancy), breast feeding, calculated creatinine clearance of ≤ 20 mL/min, see paper for others

Study design: Multicenter, open-label study. Method of randomization not explicitly stated.

Treatments:

for patients with normal renal function, Levofloxacin 500 mg once daily for 10–14 days;

for patients with creatinine clearance of 50 mL/min, an initial loading dose of levofloxacin 500 mg followed by 500 mg every 48 hours;

Amox/Clav 500/125 mg every 8 hours for 10–14 days, dosage was adjusted in accordance with package insert instructions for patients with renal impairment.

Duration of therapy could extend beyond 14 days if medically justified; the decision to extend therapy was made between days 10 and 14 of therapy.

Outcome:

Primary - clinical response satisfactory (either cure or improvement, based on a clinical score) or failure, assessed on 2–5 days post therapy; clinical success rate was calculated based on the number of evaluable patients

Secondary - assessment for relapse 28–32 days after the end of therapy Sinus cultures were not performed as part of the study.

Results:

615 patients randomized into 2 groups (levofloxacin 307; amox/clav 308)

535 evaluable for efficacy (levofloxacin 267; amox/clav 268)

Reported Clinical failure | - Levofloxacin 31/267 (11.6%);
| Amox/Clav 34/268 (12.7%)

4 week post treatment follow up Relapse | - Levofloxacin 5/233 (2.1%)
| Amox/Clav 9/231 (3.9%)

Adverse events: | Levofloxacin | Amox/Clav
Adverse event | 114/297 (38.4%) | 146/302 (48.3%)
Diarrhea | 4/297 (1.3%) | 35/302 (11.6%)
Abdominal Pain | 3/297 (1%) | 5/302 (1.7%)
Flatulence | 1/297 (0.3%) | 4/302 (1.3%)
Vomiting | 0 | 5/302 (1.7%)
Vaginitis | 2 (1.1% of women) | 8 (4.1% of women)
Genital moniliasis | 2 (0.7% of women) | 10 (3.3% of women)

11/297 (3.7%) patients treated with levofloxacin and 16/302 (5.3%) patients treated with amox/clav discontinued treatment because of adverse events.

In the levofloxacin group, those who discontinued because of adverse events included 4 patients with urticaria, rash or pruritus; 4 patients with GI adverse events; and 1 patient with asthenia-dizziness and symptoms of influenze. In the amo/clav group, all discontinued for GI adverse events except for one instance of fatigue.

No serious drug-related events or deaths occurred during the study

Funding: R. W. Johnson Pharmaceutical Research Institute

Comments:

## Buchanan et al. 2003 ID 91698

Stated Purpose of the Study: To establish the clinical equivalence of 800 mg of telithromycin once daily for 5 days with 250 mg of cefuroxime axetil twice daily for 10 days in the treatment of patients with acute bacterial maxillary sinusitis (ABMS)

Populaton and Setting: 385 subjects were randomized in 73 sites in 4 countries: Argentina (3), France (6), South Africa (9), and the United States (55). Study took place from 4/2000 to 11/2000.

Telithromycin group = 240 | Median age = 40 | Males= 42%
Cefuroxime group= 116 | Median age = 40.5 | Males= 41%

Inclusion criteria: ≥ 18 y/o and consent for sinus puncture (US only); ≥ 13 y/o and consent for sinus endoscopy (at non-US sites); for females, postmenopausal for at least one year or surgically unable to bear children or a normal menses within 1 month of study entry, plus a negative pregnancy test and agreement to use contraceptive; ABMS as evidenced by clinical and radiological findings (see paper for details); gram stain or microbiological results of sinus specimens

Exclusion criteria: > 3 episodes of sinusitis requiring abx within the previous 12 months; hx of sinusitis > 28 days; suspicion of sphenoidal sinusitis requiring treatment other than oral abx; nosocomial sinusitis and others (see paper)

Study design: multicenter, multinational, randomized, double-blind, active-controlled trial; method of randomization, not stated.

Treatments: Patients were randomized in a 2:1 ratio

Telithromycin - 2 × 400 mg capsules in am for 5 days and 2 matched placebo capsules in evening from days 1–5 and 2 matched placebo capsules in am and pm from days 6–10.

Cefuroxime Axetil - 2 × 125 mg capsules in am and pm for 10 days.

Outcome:

Primary Outcome: Clinical cure is assessed by study investigators, it is defined by return to preinfection state, with no ABMS-related signs and symptoms present, as determined on a scale of 0–3 in which 0=absent, 1=mild, and 3= severe, supplemented by a sinus x-ray/CT scan confirming no worsening or the presence of only those residual symptoms indicative of a normal course of clearance in the infection process, with no requirement for additional abx. Test of Cure visit took place at days 16–24 after the 1st day of abx.

Secondary Outcome: Late post therapy visit (days 31–45 after the 1^st^ day of abx)

Results:

Clinical failure: Telithromycin 28/189 (14.8%); Cefuroxime 16/89 (18%)

Microbiological failure: Telithromycin 20/132 pathogens (15.2%); Cefuroxime 11/61 pathogens (18%)

Secondary Outcome at late post therapy visit: Clinical Failure: Telithromycin 35/174 (20.1%); Cefuroxime 18/82 (22%)

Adverse events:

Adverse events possibly related to study medications: telithromycin 56/252; cefuroxime 20/121;

Most frequent in telithromycin: nausea 6.7%, diarrhea 6%, dizziness 2.8%, vomiting 2%

Most frequent in cefuroxime: nausea 4.1%, diarrhea 5%, vomiting 2.5%

Most common “clinically noteworthy abnormal lab value” was abnormally low creatinine clearance in both groups.

2 cefuroxime patients experienced one or more adverse event known to have a potential for association with prolonged QTc (palpitations, arrhythmia, syncope, vertigo and cardiac insufficiency)

Discontinuation rates due to adverse events were 2% for telithromycin and 1.7% for cefuroxime.

Funding: Aventis Pharmaceuticals

Comments:

## Bucher et al. 2003 ID 9

Stated Purpose of the Study: To evaluate the effect of a amox/clav on adults with clinically diagnosed acute rhinosinusitis in a general practice setting

Population & Setting: 252 patients from 24 general practices in Switzerland over 4 winter seasons (November to April, 1997-2001) were randomized.

Amox/clav | 124 | mean age | 37 | males | 46%
Placebo | 127 | mean age | 37 | males | 45.7%

Inclusion criteria: hx of repeated purulent nasal d/c and maxillary or frontal unilateral or bilateral pain for at least 48 hours but < 1 month and presence or absence (see paper) of pus under rhinoscopy

Exclusion criteria: < 18 y/o; URI or abx within the previous 4 weeks; after year 2000, pts with CRP > 100 mg/L; pts with CRP between 50 and 99 mg/L were reassessed at day 3 (3 pts) and excluded if clinical worsening was noted or the CRP level had increased to > 100 mg/L (none); see paper for rest of details

Study design: randomized, placebo-controlled, double-blind trial; stratified randomization, with the general practice or outpatient clinic as the stratification unit and patients randomized in blocks of 6; a computer random-number generator was used, and the allocation sequence was performed by a statistician who was not involved in the final analysis; patients were consecutively enrolled; study physicians were required to record the reason why eligible patients were not recruited

Treatments:

Amox/Clav 875/125 mg twice daily for 6 days

Placebo matching tablets for 6 days

All patients received decongestant therapy with xylometazolin hydrochloride spray and acetaminophen 500 mg tablet, with a maximal dose of 3 g/day

Outcome:

Primary outcome was time to cure.

Definition of cure = zero days (since the previous visit or interview) during which rhinosinusitis restricted activities at home or work

Results: 252 randomized, 1 randomized but never took any medication, 249 completed the trial (see Figure 1 in paper for details)

Calculated Failure rate (100% - reported cure rate) at 1 week: | amox/clav | 70.2%
| Placebo | 69.3%
Calculated Failure rate (100% - reported cure rate) at 2 weeks: | amox/clav | 23.4%
| Placebo | 26%

In Cox proportional analysis, with adjustment for severity of restrictions at baseline, modification of the inclusion criteria, open treatment, and concomitant medication with steam inhalation, the hazard ratio for the effect of antibiotic treatment on time to cure was 0.99 (95% CI, 0.68–1.45)

Reported Relapse rate at 28 days | amox/clav | 2/124 (1.6%)
| Placebo | 5/125 (4%)

Adverse events:

At 7 and 14 days was significantly more likely in the amon/clav group than in the placebo group, with odds ratio of 3.89 (95% CI, 2.09–7.25) and 1.71 (95% CI, 0.91–3.23) at 7 and 14 days, respectively.

4 adverse events of moderate or severe intensity that were thought to be drug related: 2 in the amox/clav group (diarrhea) and 2 in the placebo group (diarrhea and vomiting)(?)

In the placebo group, there was 1 serious disease-related adverse event; after 2 weeks of symptomatic treatment, the patient was then treated for 1 week with amox/clav (1 g twice daily) but experienced a brain abscess caused by an amox/clav sensitive strain of Streptococcus milleri. The patient was operated on and recovered but has a frontal syndrome.

There were 2 additional serious adverse events in the placebo group, 1 myocardial infarction and 1 severe depressive episode; both were thought to be neither disease nor drug related.

Funding: GlaxoSmithKline, Swiss Academy of the Medical Sciences, Astra Klinik Fonds University Hospital Basel, and Forum fur interdisziplinare Hausarztmedizin, University of Basel.

Comments:

## Burke et al. 1999 ID 524

Stated Purpose of the study: To compare the efficacy and safety of Moxifloxacin with those of Cefuroxime axetil for the treatment of community-acquired acute sinusitis.

Population & Setting:

542 patients from 48 clinical sites (primary care, allergists, infectious disease) in North America.

Unknown study years.

Moxifloxacin group (n=223): | Mean Age (range) = 40 yrs (18–76) | Males= 84 (38%)
Cefuroxime axetil group (n=234): | Mean age (range) = 39 yrs (18–78) | Males=94 (40%)

Inclusion Criteria:

≥18 y/o with acute sinusitis (based on having at least 2 of the following: nasal congestion, post-nasal drainage, frequent coughing/throat clearing, frontal headache, malar tenderness/pain and purulent nasal discharge) of 1–4 weeks duration AND radiologic signs of sinusitis (air-fluid levels, opacification or mucosal thickening≥6mm).

Exclusion Criteria:

More than 2 episodes of acute sinusitis within the previous 12 months despite therapy; allergy to carboxyquinolones or ß-lactams; history of carboxyqinolone therapy or of sinus surgery; pregnancy, nursing or not using contraception; inability to take oral medications; bacteremia or meningitis; received investigational drugs during the preceding 30 days; requiring concomitant systemic antimicrobial therapy with non-study drugs; hepatic or renal insufficiency; immunocompromise; prolonged QT_c_ interval or taking medications that prolong QT_c_; received an antimicrobial agent within 24 hours of enrollment, unless treatment failure.

Study Design: Randomized (by block-design random code, with unknown concealment method), double-blinded (medications encapsulated in gelatin), multi-center trial. Unknown if prestratified by center.

Treatment:

1. Moxifloxacin 400 mg QD + matched placebo QD for 10 days
2. Cefuroxime axetil 250 mg PO BID for 10 days

Outcome:

(Primary) End of therapy (7–21 days after therapy)

(Secondary) Follow up (27–31 days after therapy)

Resolution: Resolution or improvement of clinical Si/Sx and radiographic findings and no additional antibiotics required.

Failure: No change, worsening or reappearance of infection and need for additional antibiotics.

Indeterminate: Clinical response could not be determined.

Results: 542 enrolled and randomized. 223 in the moxifloxacin group and 234 in the cefuroxime axetil group were evaluated for clinical efficacy (per protocol analysis). 44 in the moxifloxacin group and 41 in the cefuroxime axetil group were excluded (for reasons including insufficient duration of therapy and entry criteria violation). Rates of and reasons for ineligibility stated to be similar between treatment arms.

Clinical Failure: (Primary) 23/223 (10.3%) in the moxifloxacin group and 25/234 (10.7%) in the cefuroxime axetil group failed. (Secondary) 3/184 in the moxifloxacin group and 5/202 in the cefuroxime axetil group relapsed.

Adverse Events: Adverse events were experience by 126/263 in the moxifloxacin group and 112/274 in the cefuroxime axetil group. Discontinuation due to adverse events occurred in 15/263 in the moxifloxacin group and 6/274 in the cefuroxime axetil group (P=.04). Severe drug-related adverse events occurred in 7 (3%) of patients taking moxifloxacin (2 headache, 1 asthenia, 1 diarrhea, 1 vomiting, 1 dizziness and 1 agitation) and 10 (4%) of patients taking cefuroxime (5 headache, 2 nausea 1 diarrhea, 1 arthralgia, 1 increased cough, 1 dyspnea).

| Moxifloxacin (n=263) | Cefuroxime (n=274)
Any drug-related AE | 96 (37%) | 70 (26%)
Nervousness | 7 | 2
Asthenia | 5 | 4
Dizziness | 13 | 7
Headache | 12 | 8
Nausea | 28 | 11
Diarrhea | 18 | 17
Vomiting | 9 | 3
Abdominal pain | 5 | 3
Skin and Appendages | 9 | 8
Special senses | 3 | 9
Urogenital | 3 | 8

Funding: Bayer

Comments: Use of decongestants and antihistamines were “standardized by each study center.” Steroid use was prohibited unless the patient had already been receiving treatment prior to study entry. Compliance of ≥80% of study medication administered required for inclusion in analysis.

## Chatzimanolis et al. 1998 ID 585

Stated Purpose of the Study: To compare the clinical efficacy and tolerability of roxithromycin and amox/clav, given in the conventional doses used in respiratory tract infections, in acute or recurrent sinusitis

Population & Setting: 60 patients with acute or recurrent sinusitis were enrolled in Greece.

Roxithromycin | 31 | mean age (range) | 39 (18–70) | males | 54.8%
Amox/clav | 29 | mean age (range) | 37 (18–70) | males | 58.6%

Inclusion criteria: recurrent or acute sinusitis; diagnosis of sinusitis was mainly documented by clinical and endoscopy findings, bacteriology and x-ray; > 18 y/o of either sex;

Exclusion criteria: not stated

Study design: open, randomized study

Treatments:

Roxithromycin 150 mg oral twice a day for at least 10 days

Amox/Clav 500/125 mg oral thrice a day for at least 10 days

Outcome: Clinical response was assessed within 48 hours after the end of treatment.

Results: 60 patients enrolled, 56 patients evaluated for efficacy and safety

For roxithromycin, treatment lasted 10–14 days (mean 11 days)

For amox/clav, treatment lasted 10–15 days (mean 12 days)

Calculated Clinical Failure Rate post-treatment (100% - reported satisfactory case rate in clinically assessable population): 2/29 (6.9%) in roxithromycin; 3/27 (11.1%) in amox/clav

Microbiological failure: 2 in roxithromycin and 3 in amox/clav out of a total of 48 patients (combined roxithromycin and amox/clav) Unable to calculate actual rate as denominators for antibiotics were not reported.

Adverse events:

| Roxithromycin n=29 | Amox/Clav n=27
GI | 1 (3.4%) | 7 (25.9%)

3 patients from Amox/Clav had discontinuation of medication 2° to adverse event?)

Funding: Hoechst Marion Roussel

Comments:

## Clement & de Gandt 1998 ID 583

Stated Purpose of the Study: To compare azithromycin with amox/clav in the treatment of acute sinusitis

Population & Setting:

254 patients from 38 ENT clinics in unknown country (authors are from Belgium), Unknown study years.

Azithromycin group (n=158): | Mean age (range) = 42.1 yrs (unknown range) | Males=61
(37%)
Co-amoxiclav group (n=82): | Mean age (range) = 38.7 yrs (unknown range) | Males=38
(47.2%)

Inclusion Criteria:

Adults of any age with acute ethmoidal or maxillary sinusitis (based on a scoring system described in the study) for an unspecified duration AND endoscopic evidence of pus from a sinus ostium AND unspecified CT scan evidence.

Exclusion Criteria:

Chronic sinusitis; suspected fungal sinusitis; allergy to macrolides or ß-lactams; infection requiring IV antibiotics; immunocompromise; pregnancy/nursing; receiving ergot derivatives, digoxin, cyclosporine or phenytoin; received investigational drugs during the preceding month

Study Design: Randomized (unknown method of randomization or concealment), not blinded, multi-center trial. Unknown if prestratified by center.

Treatment:

1. Azithromycin 500 mg PO qd for 3 days
2. Co-amoxiclav 500/125 mg PO TID for 10 days

Outcome (Primary):

Follow up (21–28 days after enrollment)

Response rate was based on clinical scoring system 0–21.

Cure: score=0, Improvement: score=1–20, Failure: score=21

Results: 254 enrolled and randomized. 136 in azithromycin group and 74 in co-amoxiclav group were evaluated for clinical efficacy (per protocol analysis). 7 in azithromycin group (lost to follow up) and 7 in co-amoxiclav group (lost to follow up, premature discontinuation of treatment due to lack of efficacy or adverse event) were excluded.

1. Clinical Failure: 17/136(12.5%) in azithromycin group and 12/74(16.2%) in co-amoxiclav group had no response (includes failure and relapse). 17/136 in azithromycin group and 10/74 in co-amoxiclav group had improvement but not cure.
2. Microbiological Failure: Most common pathogens isolated at baseline: S. pneumoniae, H. influenzae and S. aureus. Presumed persistence determined by presence of purulent discharge at day 21–28 only for those patients from whom pathogens were isolated at baseline by endoscopy of the ostia. 5/52 in azithromycin group and 5/31 in co-amoxiclav group had presumed persistence of infection.

Adverse Events: Discontinuation due to adverse events occurred in 0/165 in azithromycin group and 2/89 in co-amoxiclav group.

| Azithromycin (n=165) | Co-amoxiclav (n=89)
# reporting drug-related AE | 29 | 23
Drug related AE | 24 | 19
Abdominal pain | 7 | 7
Diarrhea | 7 | 13
Nausea | 8 | 1
CNS (headache/vertigo) | 5 | 0
Severe AE | 5 | 3
Study withdrawal due to AE | 0 | 2

Funding: Pfizer, Belgium

Comments: 133 patients used adjuvant therapy (vasoconstrictors, mucolytics and corticosteroids). Compliance with study medications is unknown.

## Clifford et al. 1999 ID 480

Stated Purpose of the Study: To compare the efficacy and safety of a 10-day oral treatment course of ciprofloxacin to those of 13-day therapy with clarithromycin for the management of adults with acute maxillary sinusitis or acute exacerbations of chronic sinusitis

Population & Setting: 560 patients enrolled at 19 clinical sites

Ciprofloxacin | 236 (efficacy-valid population) | mean age (range) 40.4 (18–74) | males 38%
Clarithromycin | 221 (efficacy-valid population) | mean age (range) 41 (18–76) | males 44%

Inclusion criteria: ≥ 18 y/o; primary dx of clinically (see paper for details) and radiologically documented acute sinusitis of ≤ 4 weeks duration; x-ray: opacification, or ≥ 6 mm of mucosal thickening or air-fluid level;

Exclusion criteria: inability to take oral medications; symptoms > 4 weeks (chronic sinusitis); unwillingness to undergo a sinus aspiration; need for concomitant anti-bacterial agents during the study period; baseline creatinine ≥ 3 mg/dL; terfenadine or astemizole during the study period; nasal or oral steroids; abx within 5 days of enrollment unless the patient was a treatment failure or had received only 1 or 2 doses of the abx; see paper for rest

Study design: prospective, randomized, double-blind, multicenter comparative trial; patients were randomly assigned to 1 of 2 treatment groups by means of a block design random code computer-generated at Bayer; study drugs were encapsulated in opaque gelatin capsules for blinding purposes.

Treatments:

Ciprofloxacin 2×250 mg twice a day for 10 days; placebo for days 11 to 14

Clarithromycin 2×250 mg twice a day for 14 days

Outcome:

Primary: clinical response 2–3 days post-treatment

Secondary: follow up at 28 day

Results: 560 enrolled; 559* included in Intent to treat analysis; 457 valid for efficacy analysis

Clinical failure rate in efficacy-valid group: | ciprofloxacin 37/236 (15.7%)
| Clarithromycin 19/221 (8.6%)
Clinical failure rate in Intent to treat group: | Ciprofloxacin 45/272* (16.5%)
| Clarithromycin 25/267* (9.4%)

28-day follow up relapse rate in efficacy-valid group: | ciprofloxacin 7/175 (4%)
| Clarithromycin 18/187 (9.6%)
28-day follow up relapse rate in Intent to treat group: | ciprofloxacin 9/196 (4.6%)
| Clarithromycin 20/223 (9%)

Adverse events: 559 valid for safety analysis, 1 was excluded because no study drug (the paper did not specify which one) was administered; therefore, calculated rates are based on 560

| Ciprofloxacin (282) | Clarithromycin (278)
At least 1 adverse event | 120 (42.6%) | 158 (56.8%)
At least 1 drug-related event | 93 (33%) | 133 (48%)
GI | 58 (20.6%) | 81 (29.1%)
Nervous system | 19 (6.7%) | 25 (9%)
Special-senses related | 14 (5%) | 60 (21.6%)
Diarrhea | 17 (6%) | 36 (13%)
Taste perversion | 7 (2.5%) | 58 (20.9%)
Discontinuation 2° to adverse event | 9 (3.2%) | 9 (3.2%)

One episode each of arthralgia and tinnitus in the ciprofloxacin group, and 1 episode each of peripheral edema, hyperuricemia, and pleural pain in the clarithromycin group were reported as unchanged at the final evaluation.

Funding: Bayer Corporation

Comments: *Unclear why the denominators in ITT (272+267=539) do not add up to the reported 559?

## Faich 2004 ID 20

REJECTED STUDIES: Adverse Events extraction only

Stated Purpose of the Study:

Population and Setting:

18,409 patients from 3,377 family practice and general internist sites in the US and Puerto Rico between 4/00–6/00.

Diagnoses included in the study:

Acute maxillary sinusitis, community acquired pneumonia, acute bacterial exacerbation of chronic bronchitis

Treatment: Moxifloxacin 400 mg QD × 5–10 days (10 days for sinusitis indication)

Study Design: multicenter, open-label noncomparative surveillance study

Adverse Events Included in Analyses: Those contactable by phone (70%, 12,854) or office visit (27%, 4,908) within 48 hours of treatment completion. 3% (n=645) were lost to follow-up.

Funding: Bayer Pharmaceuticals Corp.

Comments: Use of adjuvant therapy is unknown

Adverse Events: Of the 18,374 safety-validated patients, 3257 (17.7%) had one or more AE. No difference in AE rate by gender, race or age.

Most common reasons for early discontinuation due to AE:

Reason | Number
Nausea | 396
Dizziness | 202
Vomiting | 161
Diarrhea | 124
Headache | 81
Abdominal pain | 66
Rash | 64
Palpitation | 48

Serious adverse events were reported in 168 (0.9%). And 131 (0.7%) were hospitalized. 843 had possible cardiac-related events. An independent safety committee concluded there was no evidence of increased mortality or treatment-associated ventricular tachyarrhythmias. 6 deaths occurred, 5 were deemed not related to study drug and 1 was unlikely related.

Most common AE deemed probably or possibly drug related by the investigator only in those with sinusitis indication : (SEE TABLE 2)

Reason | Number
Any | 1793/ 10,822 (16.6%)
Nausea | 729 (6.7%)
Body as a whole | 371 (3.4%)
Diarrhea | 259 (2.4%)
Dizziness | 245 (2.3%)
Vomiting | 143 (1.3%)
Headache | 133 (1.2%)

## Ferguson et al. 2002 ID 225

Stated Purpose of the Study: To compare clinical and radiologic efficacy of 2 treatment regimens, 5 days vs. 7 days of gemifloxacin therapy, in adults with acute bacterial rhinosinusitis

Population & Setting: 423 patients from 59 centers in 9 countries ( Belgium, Canada, Estonia, Finland, Germany, Ireland, Italy, Lithuania, and the Netherlands) were randomized.

In ITT analysis

5-day Gemifloxacin | 218 | mean age 41.4 | males 42.7%
7-day Gemifloxacin | 203 | mean age 39.7 | males 41.9%

Inclusion criteria: > 18 y/o; signs and symptoms of acute bacterial rhinosinusitis for at least 7 but not more than 28 days (see paper for details); radiologic confirmation was required within 72 hours of randomization (sinus opacification and/or air-fluid level); patients in Germany and Lithuania were required to consent to an initial sinus endoscopy/rhinoscopy at study entry

Exclusion criteria: abx within 7 days before enrollment; signs and symptoms of disseminated infection requiring hospitalization or parenteral abx; hypersensitivity to fluoroquinolone abx; receipt of an investigational drug in the 30 days before the first dose of study medication; see paper for others

Study design: prospective, double-blind, multicenter, parallel-group study; method of randomization not stated

Treatments:

Gemifloxacin oral 320 mg once daily for 5 days; matching placebo once daily for study day 6 & 7

Gemifloxacin oral 320 mg once daily for 7 days

Outcome:

Primary: clinical response at follow-up (study days 18–25); success was defined as sustained improvement or resolution in signs and symptoms of acute bacterial rhinosinusitis so that no additional abx was required

Secondary: clinical response at end of therapy (study days 9 to 11)

Results: 423 randomized, 421 received at least 1 dose of study medication and were included in the Intent-to-treat (ITT) analysis; 356 were in the completed per-protocol-analysis (181 in 5-day group and 175 in 7-day group).

Calculated clinical failure (100% - reported clinical success rate in per-protocol patients):

5-day group 12.7%

7-day group 13.1%

Calculated clinical failure (100% - reported clinical success rate in ITT population):

5-day group 16.5%

7-day group 15.8%

Data on secondary clinical response at end of therapy (study days 9 to 11) were not reported.

Adverse events: diarrhea, nausea, and rash were the only reported events that occurred in 3% of patients or more in either group.

| 5-day group | 7-day group
adverse events while on therapy + 30 days post-therapy | 33.5% | 40.4%
Rash | 1.4% | 5.9%
Patients withdrawn 2° to adverse events | 2/218 (0.9%)* | 1/203 (0.5%)**
*one broken leg injury and one maculopapular rash
**vertigo

Funding: GlaxoSmithKline

Comments:

## Garrison 2000 ID 438

REJECTED STUDIES: Adverse events extraction only

Stated Purpose of the Study: Determine the efficacy and safety of sparfloxacin in the treatment of AMS, microbiologically documented by maxillary sinus puncture, aspiration and culture.

Population and Setting:

253 patients in the outpatient setting of unknown specialty type by 21 investigators in the US

Diagnoses included in the study: Acute maxillary sinusitis

Treatment: Sparfloxacin 400 mg ×1 (loading dose) followed by 200 mg QD for a total Rx of 10 days PLUS nasal decongestant therapy for the first 3 days of antibiotic treatment

Study Design: Open, non-comparative multicenter trial

Adverse events included in analysis: All 253 patients

Funding: Rhône-Poulenc Rorer Pharmaceuticals Inc.

Comments: Nasal decongestant administered for the first 3 days of antibiotic treatment

Adverse Events: One or more adverse events were reported by 139/253 (54.9%).

Most common AE | N, % (of 253 total)
Headache | 33, 13.0%
Photosensitivity reaction | 20, 7.9%
Diarrhea | 19, 7.5%
Many others with frequency over 2%--see original paper.

62/253 (24.5%) reported AE “considered by investigator to be possibly or probably related to the study medication” (not specified by what criteria considered related).

AE related to study drug | N, %
Photosensitivity reaction | 16 (6.3%)
Diarrhea | 14 (5.5%)
Headache | 11 (4.3%)
Nausea | 11 (4.3%)
Insomnia | 7 (2.8%)
Dyspepsia | 5 (2.0%)
Pruritis | 4 (1.6%)
Nervousness | 3 (1.2%)

9/253 (3.6%) discontinued study due to AE, 6 were considered related to study medication(4 with photosensitivity reaction, 1 with headache and 1 with 1 urticaria). One patient discontinued the study prematurely due to a serious adverse event (asthma) that was considered by the investigator to be remotely related to study medication. No other patients experienced serious adverse events. No cardiovascular AE related to increase in QTc interval. No deaths occurred. 1 elevated creatinine.

## Gehanno 2003 ID 41

REJECTED STUDIES: Adverse events extraction only

Stated Purpose of the Study: Evaluate the efficacy of moxifloxacin for treating acute maxillary sinusitis after confirmed failure of empirical antimicrobial therapy and acute sinusitis with a higher risk of complications, such as frontal or sphenoidal sinusitis and pansinusitis.

Population and Setting:

258 patients from 52 ENT centers throughout France between 1/01 to 7/01

Diagnoses included in the study: Acute maxillary sinusitis after confirmed failure of empirical antimicrobial therapy and acute sinusitis with a higher risk of complications such as frontal or sphenoidal sinusitis and pansinusitis

Treatment: Moxifloxacin 400 mg QD ×7 days

Study Design: multi-center, non-comparative study

Adverse events included in analysis: Events that occurred at least 2 times and that occurred after the first dose of moxifloxacin until 7–10 days after the last dose were reported. Only 255/258 received the study medication. Serious adverse events were followed until 4–5 weeks after the last dose.

Adverse Events: 31/255 patients (12.2%) experienced at least 1 adverse event.

No data on number of patients with serious adverse events, or the number of patients who discontinued treatment due to adverse events.

Events deemed by investigators to be possibly or probably related to moxifloxacin treatment

Event | Number
Abdominal pain | 6 (2.4%)
Nausea | 6 (2.4%)
Neurosensorial | 4 (1.6%)
Cardiovascular (includes tachycardia) | 3 (1.2%)
Diarrhea | 3 (1.2%)
Musculoskeletal complaints (includes arthralgia) | 3 (1.2%)
Skin/Mucous membrane (includes rash) | 3 (1.2%)

Funding: unknown

Comments: Use of adjuvant therapy is unknown. Corticosteroids were not permitted.

## Gehanno et al. 2000 ID 373

Stated Purpose of the Study: The efficacy and tolerance of amoxicillin-clavulanate, with and without associated short steroid therapy, was evaluated in adults with acute sinusitis.

Population & Setting: 433 patients recruited from 51 private ENT specialists in France were randomized. The study was carried out from 11/1991 to 7/1994.

In ITT population:

5-day amox/clav (with or without steroids) 205 | mean age 39.1 | male 82/205 (40%)
10-day amox/clav (with or without steroids) 212 | mean age 30.5 | male 82/212 (39%)

Inclusion criteria: outpatients ≥ 18 y/o with acute sinusitis (see paper for details) < 10 days; opacities with or without air-fluid levels on standard films or computed tomography

Exclusion criteria: acute sinusitis requiring immediate surgical drainage and acute exacerbations of chronic sinusitis; abx or steroids in the 15 days preceding recruitment; see paper for others

Study design: muticenter, randomized, double-blind, placebo-controlled, parallel 2×2 factorial arrangement

Treatments:

A: Amox/Clav 500 mg three times a day for 5 days, then matching placebo for 5 more days

B: Amox/Clav 500 mg three times a day for 10 days

Also, for both group A and B, patients were randomized to receive 8 mg of methylprednisiolone three times daily or a matching placebo for study days 1 to 5

Outcome:

Primary: primary efficacy was assessed on day 14; success was defined as clinical recovery on day 14, with or without radiological normalization

Results:

433 randomized, 417 in Intent to treat (ITT) analysis, 360 in per-protocol analysis

Reported clinical failure rate on day 14, in ITT population:

5-day group | 41/205 (20%)
10-day group | 32/212 (15%)

Reported clinical failure rate on day 14, in per-protocol population:

5-day group | 39/181 (21.6%)
10-day group | 28/179 (15.6%)

Reported recurrence rate on day 30 follow up:

5-day group | 11/162 (6.8%)
10-day group | 7/175 (4%)

Absence of interaction between the duration of treatment by the antibiotic and the adjunctive use of methlyprednisolone was verified, permitting separate analysis of each treatment.

Evaluation at day 14 showed no evidence of a higher rate of recovery in the group treated by methylpredinsolone than in the placebo group (actual data not provided).

Adverse events:

433 in safety analysis; recorded adverse events were nausea, vomiting, diarrhea, gastric pain, skin reactions and Candida superinfection.

| 5-day (213) | 10-day (220)
patients with adverse events | 20 (9.4%) | 26 (11.8%)
discontinuation 2° to adverse events | 1 (0.4%) | 7(3.2%)

| steroids (219) | no steroids (214)
patients with adverse events | 24 (11%) | 22 (10.3%)
discontinuation 2° to adverse events | 5 (2.3%) | 3(1.4%)

Funding: SmithKline Beehcam

Comments: some patients received both amox/clav and methylprednisolone (see explanation in paper), actual data not provided.

## Gwaltney et al. 1997 ID 648

Stated Purpose of the Study: To evaluate cefdinir for the treatment of acute community-acquired bacterial sinusitis.

Population & Setting: 1798 patients in US (1229) and Europe (569) participated

Cefdinir 600 mg once a day = 585 | Median age (range) = 35 (12–83) | Males= 44%
Cefdinir 300 mg twice a day = 610 | Median age (range) = 35 (13–88) | Males= 43%
Amox/Clav 500mg thrice a day=603 | Median age (range) = 34 (13–79) | Males= 45%

Inclusion criteria: ≥13 y/o; males and females; signs and symptoms of acute sinusitis; had to include facial pain and purulent nasal discharge; dx confirmed by x-ray showing disease of the maxillary sinus; duration of illness ≤ 4 weeks; see paper for details

Exclusion criteria: hx of sensitivity to beta lactams, treatment with systemic abx within prior 48 hours;, significant renal or hepatic disease; requirement of Fe therapy; pregnant or lactating

Study design: Two (one in US, one in Europe) randomized, Investigator-blinded,multi-center trials were conducted. The studies were identical in design, with the exception that admission sinus aspiration was optional in US and mandatory in Europe. Patients were randomly assigned at each site to one of 3 treatment groups. Medications were dispensed by a third party, and all records regarding study medications were kept at a separate site. Patients were instructed to withhold details of study medication appearance and dosing schedule.

Treatments:

Cefdinir 600 mg once a day for 10 days

Cefdinir 300 mg twice a day for 10 days

Amoxicillin/Clavulanate 500 mg three time a day for 10 days

Outcome:

Primary: Satisfactory clinical response is defined by cure or improvement, assessed by absence or presence of clinical signs and symptoms. Test of cure visit took place 7–14 days post therapy.

Secondary: rate for continued clinical response with initial success was determined 3 to 5 weeks post therapy

Results: Evaluable patients were defined as those who took ≥ 80% of prescribed medications, returned for the test of cure visit (except for failures prior to scheduled visits), and did not take non-study systemic abx for other infections.

Calculated Clinical Failure Rate at 1–3 days post-treatment (100% - reported satisfactory cases in clinically evaluable population):

Cefdinir 600 mg once a day | 49/474 (10.3%)
Cefdinir 300 mg twice a day | 61/481 (12.7%)
Amox/Clav thrice a day | 44/491 (9%)

Calculated Clinical Failure Rate at 3–5 wks post-treatment (100% - reported satisfactory cases in clinically evaluable population):

Cefdinir 600 mg once a day | 37/379 (9.8%)
Cefdinir 300 mg twice a day | 39//370(10.5%)
Amox/Clav thrice a day | 30/389 (7.7%)

Calculated Microbiological failure at 7–14 days post therapy (evaluable patients):

Cefdinir 600 mg once a day | 25/215
Cefdinir 300 mg twice a day | 31/225 (1
Amox/Clav thrice a day | 28/256 (10.9%)

Calculated Microbiological failure at 3–5 wks post therapy (evaluable patients):

Cefdinir 600 mg once a day | 10/169 (5.9%)
Cefdinir 300 mg twice a day | 20/167 (12%)
Amox/Clav thrice a day | 14/203 (6.9%)

Adverse events:

Cefdinir once a day 188/582 (32%); Cefdinir twice a day 212/607 (35%); Amox/Clav 234/603 (39%) experienced at least one side effect (see table 6 in paper). The most frequent adverse event is GI related; mild diarrhea occurred in approximately 20% of each group. Diarrhea was the most common reason for discontinuation of treatment.

8/582 (1.4%) patients of the cefdinir OD group and 19/607 (3.1%) patients of the cefdinir BD and 30/603 (5%) patients of amox/clav groups discontinued treatment because of an adverse event. No clinically important alterations in laboratory values were observed for any of the groups.

Funding:

Comments: authors Leigh and Tack associated with Parke-Davis

## Hansen et al. 2000 ID 97079

Stated Purpose of the Study: To compare the effectiveness of penicillin V and placebo given to patients with a dx of acute maxillary sinusitis based on pain in the maxillofacial area combined with either raised CRP or ESR.

Population & Setting: 139 patients from 26 general practices in town and rural areas from Denmark. Study took place from 11/1995 to 4/1997. 71 were given PCN and 62 placebo. Median age was 37 (quartiles 30 to 46). 33 (25%) were males. Consecutively included only once if they fulfilled the inclusion criteria.

Inclusion criteria: 18–65 years; pain in the maxillofacial area and values of CRP > 10 mg/L or ESR > 10 mm/h in males and > 20 mm/h in females.

Exclusion criteria: known allergy to PCN; pregnancy; breastfeeding; previous maxillary sinus surgery; ENT malignancy; DM; rheumatic arthritis; collagen vascular diseases; facial trauma; Rx with steroids, probenecid or immunotherapy; abx treatment previous 2 weeks or ongoing Rx; Symptoms > 4 weeks. After randomization, excluded if severe side effects, unwilling to continue or did not show up for control visit.

Study design: Randomized (a block randomization was used with 10 dark colored glasses in each block containing 5 glasses of PCN and 5 glasses of placebo; each glass contained 28 tablets; the general practitioner received one block each), double-blind, placebo-controlled.

Treatments: Penicillin V 1333 mg (2 million IE) twice daily for 7 days.

Placebo: 2 tablets twice daily for 7 days.

Outcome: Pain score after 7 day of treatment (from patient kept diary). Pain score of zero is considered a cure.

Results: After randomization, 2 in placebo and 4 in PCN group were withdrawn because of non-compliance. Another 6, 3 in each group, stopped treatment before day 7, due to lack of effect in 4 and side effects in 2 treated with PCN. They were included in analyses and registration of side effects until they dropped out. 133 patients in final analysis, 71 in PCN group, 62 in placebo.

Calculated Clinical Failure Rate of PCN at 7 days post initiation of treatment (100% - reported percentage of patients with pain score of zero at 7 days multiply by number of patients at 7 days divided by number of patients at day zero): 100% - 75%×68/71= 28%

Calculated Clinical Failure Rate of placebo at 7 days post initiation of treatment (100% - reported percentage of patients with pain score of zero at 7 days multiply by number of patients at 7 days divided by number of patients at day zero): 100% - 51%×59/62= 51.5%

See table 1 for original reported data.

Adverse events: 13 (18%) patients treated with PCN claimed to have side effects - 11 due to GI symptoms and 2 with unspecified symptoms - in contradiction to two (3%) patients treated with placebo - one with abdominal pain and one with unspecified symptoms (p=0.009).

Funding: PCN and placebo tablets from Nycomed Amersham, Denmark; financial support from Danish Practitioners' Foundation.

Comments: calculated results differ from reported results in the abstract (PCN failure 29%, placebo failure 63%)?

## Haye et al. 1998 ID 562

Stated Purpose of the Study: To compare the efficacy of azithromycin to placebo in the treatment of patients with clinical symptoms and signs of acute maxillary sinusitis but without radiological evidence of empyema

Population & Setting: 169 patients recruited from general practices in Norway in the winter season were randomized.

Azithromycin group | 87 | mean age (range)= 40.2 (21–84) | males 20.7%
Placebo | 82 | mean age (range)= 43.2 (18–68) | males 31.7%

Inclusion criteria: ≥ 18 y/o; hx of URI; signs and symptoms of acute maxillary sinusitis: presence of nasal secretion (purulent at the time of examination) for > 10 days and < 30 days, and maxillary sinus tenderness and/or pain of < 30 days' duration; radiograph should not show complete opacity or an air-fluid level, and the mucosal thickness must be < 6 mm, should not show frontal or sphenoidal sinusitis

Exclusion criteria: hx of intolerance to macrolides, azalides, PCN, or lactose; >2 episodes of sinusitis in the past 12 months; abx within the preceding 2 weeks; see paper for rest

Study design: double-blind, double-dummy, parallel-group, multicenter study; computer randomized in blocks of six to either of the two treatment groups

Treatments:

Azithromycin one 500 mg tablet daily for 3 days

Matching Placebo one tablet daily for 3 days

Outcome: Primary outcome not defined.

Results: 169 patients enrolled in the study; all patients had at least one follow up visit after treatment; in patients who did not return for visits on study day 10–12 or study day 23–27, the results from the previous visit were carried forward.

| Azithromycin | Placebo
Reported Failure rate at 3–5 days: | 5/84 (6%) | 10/81 (12.3%)
Reported combined failure + relapse rate at 10–12 days (counted some patients who were not present at this visit but were present at the previous visit): | 6/86 (7%) | 9/81 (11.1%)
Reported combined failure + relapse rate at 23–27 days (counted some patients who were not present at this visit but were present at the previous visits): | 9/87 (7%) | 10/82 (12.2%)
Adverse events:
| Azithromycin (n=87) | Placebo (n=82)
Patients with adverse events | 24 (27.6%) | 15 (18.3%)
GI (diarrhea, nausea, abdominal pain) | 22 (25.3%) | 12 (14.6%)

One azithromycin related adverse event was considered severe (details not provided).

No patient in either treatment group discontinued therapy due to an adverse event.

Funding:

Comments: author Odegard associated with Pfizer

## Henry et al. 1999 ID 482

Stated Purpose of the Study: To compare the efficacy and tolerability of a 10-day regimen of sparfloxacin with a 14-day regimen of clarithromycin in patients with well-defined acute maxillary sinusitis

Population & Setting: 504 patients from 61 centers in US participated.

Sparfloxacin 252

Clarithromycin 252

Inclusion criteria: ≥ 18 y/o; dx of acute maxillary sinusitis (AMS) within the previous 2 weeks; at least one symptom of AMS and sinus x-ray abnormalities (see paper for details)

Exclusion criteria: Symptoms of AMS within the previous 4 weeks; chronic sinusitis; systemic abx within 7 days before start of study; pregnancy, baseline QTc > 500 msec and others (see paper)

Study design: randomized, double-masked, comparative, multicenter trial. Randomized in a 1:1 ratio. To preserve masking, patients were provided with cards containing encapsulated study medications and placebos.

Treatments:

Sparfloxacin arm - 2× 200 mg tablets on day one, followed by 1× 200 mg tablet each am from days 2 through 10, plus appropriate am and pm placebos for 14 days

Clarithromycin arm - 2× 250 mg tablets every 12 hours for 14 days.

Outcome Primary: Test of cure occurs on study day 20±3; clinical success is defined by number of patients with clinical outcomes of cure plus improvement divided by the total population minus the indeterminate cases.

Secondary: recurrence of infection was assessed on day 38± 7

Results: 504 enrolled, 430 clinically assessable; primary reasons for exclusion were incorrect dx of AMS, normal x-ray at baseline, and non-compliance

Calculated Clinical Failure Rate (100% - reported clinical success rate* in clinically assessable population):

Sparfloxacin 37/219 (16.9%)

Clarithromycin 35/211 (16.6%)

Calculated Clinical Failure Rate in all-treated population (100% - reported clinical success rate in all-treated population):

Sparfloxacin 40/230 (17.4%)

Clarithromycin 40/224 (17.9%)

Secondary follow up at 3–4 weeks after therapy

Calculated Clinical Relapse Rate (100% - reported sustained clinical success rate in clinically assessable population):

Sparfloxacin 52/191 (27.2%)

Clarithromycin 56/185 (30.3%)

Calculated Clinical Relapse Rate in all-treated population (100% - reported sustained clinical success rate in all-treated population):

Sparfloxacin 56/197 (28.4%)

Clarithromycin 61/194 (31.4%)

Adverse events:

| Sparfloxacin n=252 | Clarithromycin n=252
diarrhea | 60 (23.8%) | 68 (27%)
photosensitivity | 24 (9.5%) | 1 (0.45)
taste perversion | 2 (0.8%) | 22 (8.7%)
nausea | 12 (4.8%) | 12 (4.8%)
abdominal pain | 4 (1.6%) | 9 (3.6%)
flatulence | 5 (2%) | 4 (1.6%)
discontinuation 2° to med | 11 (4.4%) | 14 (5.6%)
adverse lab values** | 8 (3.2%) | 6 (2.4%)

**elevations in lipase, aspartate aminotransferase, alanine aminotransferase or blood glucose

5 patients in the clarithromycin group experienced serious adverse events, 1 of which (rash) was considered to be drug related; 4 of these patients were discontinued from the study.

Funding: Rhone-Poulenc Rorer

Comments: *clinical success rate is defined by number of patients with clinical outcomes of cure plus improvement divided by the total population minus the indeterminate cases

## Henry et al. 2003 ID 10

Population & Setting:

941 patients from multiple (unknown number) of centers in the U.S. Unknown study years.

Azithromycin for 3 days group (n=312):

Mean age (range) = 40.2 yrs (18–76) Males=123 (39.4%)

Azithromycin for 6 days group (n=311):

Mean age (range) = 41.3 yrs (18–80) Males=124 (39.9%)

Amoxicillin-clavulanate group (n=313):

Mean age (range) = 42.4 yrs (18–84) Males=134 (42.8%)

Inclusion Criteria:

≥18 y.o. in outpatient setting with acute sinusitis (based on: purulent nasal discharge or facial pain and/or pressure and/or tightness) for 8–27 days duration AND radiologic signs of sinusitis (air-fluid levels, opacification or mucosal thickening≥6mm).

Exclusion Criteria:

History of chronic sinusitis; allergy to penicillins or macrolides; history of sinus surgery; systemic anti-histamine treatment; systemic antibiotic treatment for over 24 hours within 2 weeks of enrollment.

Study Design: Randomized (unknown method of randomization or concealment), double-blinded (amoxicillin-clavulanate given as a suspension to facilitate masking), multicenter trial. Unknown if prestratified by center.

Treatment:

1. Azithromycin 500 mg QD for day 1–3 + matched placebo tab QD day 4–6 + matched placebo suspension TID for 10 days
2. Azithromycin 500 mg QD for 6 days+ matched placebo suspension TID for 10 days
3. Amoxicillin-clavulanate 250/62.5 mg TID for 10 days + matched placebo QD for 6 days

Outcome:

(Primary) End of study (22–36 days after enrollment)

(Secondary) End of therapy (8–15 days after enrollment)

Cure: Resolution of Si/Sx, no worsening in radiographic findings and no additional antibiotics required.

Improvement: Partial resolution of Si/Sx and no additional antibiotics required.

Failure: Persistence of Si/Sx or emergence of new Si/Sx and/or the need for additional antibiotics or a change in antimicrobial therapy.

Results: 941 enrolled and randomized; 298 in azithromycin for 3 days group, 294 in azithromycin for 6 days group, and 288 in the amoxicillin-clavulanate group were included in the intent to treat analysis for clinical efficacy. 5 in azithromycin for 3 days group, 5 in azithromycin for 6 days group, and 6 in the amoxicillin-clavulanate group were excluded due to enrollment by an ineligible center. Others excluded for not meeting entry criteria, visits outside the protocol-specified windows or unknown/missing data.

Clinical Failure: (Primary) 85/298 in azithromycin for 3 days group, 76/294 in azithromycin for 6 days group, and 82/288 in the amoxicillin-clavulanate group failed. (Secondary) 35/303 in azithromycin for 3 days group, 33/298 in azithromycin for 6 days group, and 43/291 in the amoxicillin-clavulanate group failed.

Adverse Events: (Primary) Adverse events were experience by 97/312 in azithromycin for 3 days group (nausea=23 diarrhea=53, flatulence=17), 117/311 in azithromycin for 6 days group (nausea=27, diarrhea=66, flatulence=11) and 160/313 in the amoxicillin-clavulanate group (nausea=38, diarrhea=101, flatulence=6). Discontinuation due to adverse events occurred in 7 in azithromycin for 3 days group, 11 in azithromycin for 6 days group and 28 in the amoxicillin-clavulanate group. No treatment-related serious adverse events occurred in any treatment arm.

Funding: Pfizer

Comments: Compliance is stated as being recorded by investigators (amount taken, reasons for missed doses and amount of study medication returned at the end of therapy), but data is not shown. Sinus films at the end of therapy compared to baseline showed improvement/resolution in 71.7% in azithromycin for 3 days group, 74.2% in azithromycin for 6 days group and 66.2% in the amoxicillin-clavulanate group.

## Henry et al. 1999 ID 462

Stated Purpose of the Study: To compare the efficacy and tolerability of a 10-day regimen of cefuroxime axetil 250 mg twice daily with a 10-day regimen of amoxicillin/clavulanate 500 mg/125 mg three times daily in adult patients with acute bacterial maxillary sinusitis

Population & Setting: 263 patients from 9 centers in US participated.

Cefuroxime | 132 | mean age (range) 40.5 (19–70) | males 52%
amox/clav | 131 | mean age (range) 39.4 (18–82) | males 38%

Inclusion criteria: men and women ≥ 18 y/o; clinical dx of acute maxillary sinusitis (AMS) within the previous 30 days; ≥ 2 of the following symptoms with at least moderate severity: rhiniorrhea, nasal congestion, or cough, sinus x-ray: opacification, ≥ 4 mm membrane thickening, and/or air-fluid level in 1 or both maxillary sinuses; and others (see paper)

Exclusion criteria: dx or hx of chronic sinusitis; sinus washout or systemic abx in the previous 7 days; sinus surgery in the past month, pregnancy, see paper for others

Study design: randomized, double-masked, multicenter trial. Method of randomization not explicitly stated.

Treatments:

Cefuroxime 250 mg twice a day plus matched placebo once daily for 10 days

Amox/Clav 500 mg three times a day for 10 days

Outcome:

Primary: Post treatment response and follow-up assessment 26–30 days after cessation of treatment. Satisfactory response comprised of both “cure” and “improvement”. For the outcome to be judged satisfactory, no residual opacification or air-fluid level was allowed on sinus x-ray (see paper for details). Data on post treatment 1–3 days not shown.

Results: 263 enrolled, 193 clinically assessable; primary reasons for exclusion were violation of selection criteria, failure to complete all required study visits, absence of urine compliance assay, and loss to follow-up

Actual result reads: “A satisfactory clinical response (cure or improvement) in the per-protocol analysis at the follow-up assessment was present in 50% and 41% of clinically assessable patients treated with cefuroxime axetil and amoxicillin/clavulanate, respectively (P=0.19). Fifty-one cefuroxime axetil patients and 54 amoxicillin/clavulanate patients were judged to be clinical failures or had clinical recurrences.”

Calculated Clinical Failure Rate at follow-up assessment (100% - reported satisfactory case rate in clinically assessable population):

Cefurxoime 100%-50%=50%

Amox/Clav 100%-41%=59%

Adverse events:

| Cefuroxime n=132 | Amox/Clav n=131
patients with ≥ 1 drug-related event | 23 (17.4%) | 38 (29%)
patients with ≥ 1 GI events | 15 (11.4%) | 30 (22.9%)
diarrhea | 8 (6.1%) | 25 (19.1%)
nausea | 0 | 6 (4.6%)
vaginitis | 3 (2.3%) | 5 (3.8%)
patients withdrew 2° adverse event | 2 (1.5%) | 8 (6.1%)

Funding: Glaxo Wellcome

Comments: Table IV heading should specify the data is from a retrospective analyses using an overall symptom scoring system for the subset of symptoms published by the IDSA and not from the per-protocol analyses.

## Jareoncharsri et al. 2004 ID 34

Stated Purpose of the study: To compare the efficacy, safety and antimicrobial activity of Levofloxacin with amoxicillin/clavulanic acid in the treatment of purulent sinusitis in adult Thai patients.

Population & Setting:

60 patients from 2 ENT centers in Thailand from 6/98–12/99.

Overall mean age (range) =35.5 yrs (17–68) Overall Males= 23 (38%)

Levofloxacin group (n=34) Co-amoxiclav group (n=26)

Unknown age range and number of males for each group, but demographic characteristics stated to be statistically comparable.

Inclusion Criteria:

≥16 y.o. in outpatient setting with acute sinusitis/acute exacerbation of chronic sinusitis (based on nasal obstruction, purulent nasal discharge or postnasal drip, impairment of sense of smell, foul smell and headache) of ≤4 weeks duration AND purulent discharge in the middle meatus or maxillary ostium by endoscopy AND abnormal radiologic signs (undefined).

Exclusion Criteria:

None listed

Study Design: Randomized (unknown method of randomization or concealment), not blinded, multi-center trial. Unknown if prestratified by center.

Treatment:

Levofloxacin 300 mg QD for 14 days

Co-amoxiclav 500/125 mgTID for 14 days

Outcome: (Primary) End of study (day 21 after enrollment)

Cure: Resolution of Si/Sx and no radiologic evidence of remaining disease

Improvement: Incomplete resolution of Si/Sx and improvement of radiologic findings

Relapse: Initial improvement/cure followed by recurrence of Si/Sx

Failure: Neither clinical nor radiologic improvement is seen

Results: Unknown number enrolled and randomized. 34 in levofloxacin group and 26 in co-amoxiclav group evaluated for clinical efficacy (unknown if intent to treat analysis). Unknown number excluded.

1. Clinical Failure: (Primary) 3/34 in levofloxacin group and 4/26 in co-amoxiclav group failed, relapsed or withdrew from therapy.
2. Microbiological Failure: Most common pathogens isolated at baseline: Streptococcus species, H. influenzae and Staphylococcus species. Persistence determined by repeated isolation of baseline pathogens at day 14 after enrollment. 6/28 in levofloxacin group and 6/20 had persistence of infection.

Adverse Events: Adverse events were experience by 3/34 in levofloxacin group (nausea, dizziness, abdominal pain and diarrhea) and 2/26 in co-amoxiclav group (nausea, palpitation, acute urticaria and bronchospam). All adverse events in both groups were mild and resolved spontaneously.

Funding: Daiichi Pharmaceutical Co.

Comments: Use of adjuvant therapy is unknown. Compliance with study medications is unknown. 14 days after enrollment, 62% in levofloxacin group and 62% in co-amoxiclav group showed radiological improvement.

## Johnson et al. 1999 ID 491

Stated Purpose of the Study: To compare the efficacy and safety of a 10-day oral treatment of ciprofloxacin to cefuroxime axetil for the management of adults with acute bacterial sinusitis or acute exacerbations of chronic sinusitis

Population and Setting: 501 (ITT) adults in 17 otolaryngology offices, study years not specificed

Ciprofloxacin 228 | mean age (range) 40 (18–72) | males 40%
Cefuroxime 225 | mean age (range) 43 (18–85) | males 43%

Inclusion criteria: Primary dx of acute presumed or documented bacterial sinusitis or acute exacerbation of chronic bacterial sinusitis of up to 4 weeks' duration; > 18 y/o; clinical signs and symptoms of sinusitis and x-ray confirming maxillary sinusitis; for additional criteria, see paper; antral puncture procedure was performed on all patients

Exclusion criteria: inability to take oral medications, allergy to carboxyquinolones or beta-lactams; symptom duration > 4 weeks, administration of an antimicrobial agent within 5 days of study enrollment was also a reason for exclusion, unless the patient was a treatment failure or had received only 1 or 2 doses of the antibiotic, see paper for rest of criteria

Study design: Prospective, randomized (one of two treatment groups using a block-design random code), double-blind, two-arm comparative study

Treatments:

Ciprofloxacin 500 mg twice a day for 10 days

Cefuroxime 250 mg twice a day for 10 days

Outcome:

Primary - Clinical resolution - resolution based on the resolution or improvement of both clinical symptoms and radiography, as well as the physician's clinical judgment of whether or not additional antimicrobial treatment was necessary. Test-of-cure took place 1–7 days post-therapy.

Secondary - follow-up at 2–4 week

Results:

501 enrolled; 48 disqualified (22 cipro; 26 cefuroxime); 453 were valid for efficacy analysis (228 cipro; 225 cefuroxime);

Clinical failure = ciprofloxacin 29/228 (13%); cefuroxime 38/225 (17%) Microbiological response; 99 (43%) ciprofloxacin and 90 (40%) cefuroxime had one or more causative organisms isolated pre-therapy.

Microbiological failure = ciprofloxacin 3/92 (3.3%); cefuroxime 5/100 (5%)

2–4 week follow up: clinical relapse = cipro 16/168 (9.5%) cefuroxime 20/165 (12.1%)

Adverse events:

115 (46%) cipro and 113 (45%) cefuroxime treated patients reported at least one treatment-emergent event.

87 (35%) cipro and 83 (33%) cefuroxime experienced at least one drug-related adverse event. Diarrhea, nausea, headache and dizziness were the most common events reported. Premature discontinuation of a study drug due to an adverse event was reported in one cipro patient (vasodilatation, facial edema and rash) and 6 cefuroxime patients ( 3 rash, 2 diarrhea, 1 dizziness and amblyopia).

Funding: Bayer

## Klapan et al. 1999 ID 500

Stated Purpose of the study: To compare the efficacy and tolerability of a 3-day course of azithromycin and a 10-day course of amox/clav in the treatment of acute sinusitis in adults

Population & Setting:

100 patients from unknown number or type of centers possibly in Croatia. Unknown study years.

Azithromycin group (n=50): Mean age (range) = 33yrs (unknown range)

Males=40 (80%)

Amoxicillin/clavulanic acid group (n=50): Mean age (range) = 40yrs (unknown range)

Males=37 (74%)

Inclusion Criteria:

≥15 y/o with Si/Sx of acute sinusitis (undefined) of ≤4 weeks duration AND radiologic signs (air-fluid levels, opacification or mucosal thickening≥4mm or opacities) AND nasal endoscopy (complete obstruction of ostiomeatal complex or partial obstruction with purulent drainage).

Exclusion Criteria:

Chronic sinusitis; allergy to azithromycin or amoxicillin/clavulanic acid; pregnancy or nursing; viral infection; severe hepatic or renal impairment; GI disorder; immunodeficiency; received more than 1 dose of antibiotic within 7 days of enrollment.

Study Design: Randomized (unknown method of randomization or concealment), not blinded trial.

Treatment:

Azithromycin 500 mg PO qd for 3 days

Amoxicilllin-clavulanic acid 500/125 mg PO TID for 10 days

Outcome:

(Primary) End of treatment (10–12 days after initiation of treatment)

(Secondary) Follow up (4 weeks after initiation of treatment)

Response rate was based on clinical scoring system 0–3 (based on fever, headache, facial tenderness, nasal congestion/discharge, nasal mucosa hyperemia and post-nasal secretions)

Cured: complete disappearance of signs and symptoms, score≤1

Improvement: partial disappearance of signs and symptoms without need for further therapy

Failure: persistence or progression of signs or symptoms requiring further therapy

Relapse: reappearance of signs or symptoms at 4 weeks

Results: 100 enrolled and randomized. 47 in azithromycin group and 47 in amoxicillin/clavulanic acid group were evaluated for clinical efficacy (per protocol analysis). 3 in azithromycin group and 3 in amoxicillin/clavulanic acid group were excluded for reasons including: violation of inclusion criteria.

1. Clinical Failure:
  - (Primary) 0/47 in azithromycin group and 0/47 in amoxicillin/ clavulanic acid group had failure or relapse. 3/47 in azithromycin group and 12/47 in amoxicillin/clavulanic acid group had improvement.
  - (Secondary) 1/43 in azithromycin group and 4/46 in amoxicillin/clavulanic acid group had failure or relapse.
2. Microbiological Failure: Ostiomeatal sinus aspiration was performed in 70 patients at baseline (unknown reason not performed on all patients). Most common pathogens isolated at baseline: H. influenzae, S. aureus and S. pneumoniae. No pathogens cultured in 33%. Aspiration was repeated after 72 hours from treatment initiation if clinical failure. 0/23 in azithromycin group and 3/24 in amoxicillin/clavulanic acid group failed (includes persistence and relapse).

Adverse Events: Adverse events occurred in 2/50 in azithromycin group (nausea=2, diarrhea=0, other=0), and 5/50 in amoxicillin-clavulanic acid group (nausea=5, diarrhea=1, other=0). Discontinuation due to adverse events did not occur in either group.

Funding: Not disclosed

Comments: Some of the authors are from Pliva d.d. Pharmaceuticals Division, Zagreb, Croatia. Compliance with study medications is unknown.

## Klein et al. 1998 ID 599

Stated Purpose of the Study: To compare the efficacy and safety of ciprofloxacin to cefuroxime in the treatment of adult outpatients with acute bacterial sinusitis or acute exacerbation of chronic sinusitis.

Population & Setting:

83 patients from a single (unknown type) center in unknown country. Unknown study years.

Ciprofloxacin group (n=13): | Mean age (range) = 46.8yrs (30–75) | Males= 6 (46%)
Cefuroxime axetil group (n=19): | Mean age (range) = 44.3yrs (25–71) | Males= 4 (21%)

Inclusion Criteria:

≥18 y.o. with acute sinusitis/acute exacerbation of chronic sinusitis (based on having at least 2 of the following: fever, leukocytosis, typical symptoms or physical findings) of ≤4 weeks duration AND radiologic signs (air-fluid levels, opacification or mucosal thickening≥6mm).

Exclusion Criteria:

Frequent, recurrent acute sinusitis; allergy to carboxyquinolones or ß-lactams; pregnancy or nursing; inability to undergo sinus aspiration or to take oral medications; bacteremia or meningitis; received investigational drugs during the preceding 30 days, or more than 2 doses of an antibiotic within 5 days of enrollment unless the patient was a treatment failure; baseline serum creatinine≥3.0 mg/dL.

Study Design: Randomized (computer-generated block-design random code with unknown concealment method), double-blinded (study drugs encapsulated in opaque capsules for masking), single-center trial

Treatment:

Ciprofloxacin 500 mg PO BID for 10 or more days (range=13–18 days)

Cefuroxime axetil 250 mg PO BID for 10 or more days (range=13–18 days)

Outcome (Primary):

End of therapy (1–7 days after treatment)

(Secondary): Follow up (2 to 4 week after treatment)

Resolution: complete resolution of Si/Sx, negative radiography and no further therapy required

Improvement: decrease in Si/Sx, decreased mucosal thickening and no further therapy required

Failure: no change, worsening or reappearance of Si/Sx requiring alternative therapy

Relapse: reappearance of any Si/Sx AND positive sinus x-rays

Results: 83 enrolled and randomized. 13 in ciprofloxacin group and 19 in cefuroxime axetil group were evaluated for clinical efficacy (per protocol analysis). 51 (unknown number in ciprofloxacin vs. cefuroxime axetil group) were excluded for reasons including: no pathogen isolated and inadequate treatment length.

1. Clinical Failure:
  - (Primary) 0/13 in ciprofloxacin group and 5/19 in cefuroxime axetil group were failed. 8/13 in ciprofloxacin group and 11/19 in cefuroxime axetil group had improvement.
  - (Secondary) 3/9 in ciprofloxacin group and 1/9 in cefuroxime axetil group had relapse.
2. Microbiological Failure: Most common pathogens isolated at baseline: H. influenzae and Streptococcus species. By sinus aspiration if clinical failure at end of therapy.
  - (Primary) 0 (of unknown number re-cultured) in ciprofloxacin group and 5 (of unknown number re-cultured) in cefuroxime axetil group failed. All 5 failures were due to super-infection, not persistence of pathogen originally cultured.
  - (Secondary) 0 (of unknown number re-cultured) in ciprofloxacin group and 0 (of unknown number re-cultured) in cefuroxime axetil group failed.

Adverse Events: Drug-related adverse events were experienced by 10 (45%) of ciprofloxacin group and 10 (34%) or cefuroxime axetil group. Most events in both groups were GI related (diarrhea, nausea/vomiting and flatulence). Discontinuation due to adverse events occurred in 1 (rash) in the ciprofloxacin group and 1 (eczema flare) in the cefuroxime axetil group.

Funding: Bayer

Comments: Use of decongestants and antihistamines were permitted but not recorded. One-sided 95% CI were calculated for clinical and microbiological efficacy. More subjects in the cefuroxime axetil group had multiple organisms cultured at baseline than in the ciprofloxacin group. An unknown number of patients were removed from analysis for clinical failure with resistant pathogens cultured at end of study. Compliance with study drugs is unknown.

## Klossek et al. 2003 ID 164

Stated Purpose of the Study: To compare the efficacy and safety of oral moxifloxacin 400 mg once daily for 7 days with those of oral trovalfloxacin 200 mg once daily for 10 days in treating adult out-patients with acute bacterial rhinosinusitis

Population & Setting: 503 patients with acute bacterial maxillary sinusitis were randomized. Patients were enrolled in 60 centers in 8 countries: Belgium, France, Germany, Great Britain, Greece, Lithuania, Spain and Sweden, by both office-based primary care physicians (UK) and otolaryngologists (other countries).

Moxifloxacin | 223 | mean age 38.8 | males 43.9%
Trovafloxacin | 229 | mean age 41.9 | males 49.3%

Inclusion criteria: male and female patients 18 y/o with acute sinusitis (see paper for details) and x-ray evidence of air-fluid level, opacification or ≥ 6 mm mucosal thickening.

Exclusion criteria: chronic sinusitis (symptomatic > 4 weeks), recurrence of > 2 episodes of acute sinusitis within the preceding 6 months, patients with hypersensitivity to any quinolone, receiving concomitant medication reported to increase the QT interval, and others (see paper)

Study design: This was a prospective, multinational, multicenter, randomized, double-blind, comparative study. Patients were randomly assigned 1:1 to one of two treatment groups using a block design computer-generated random code. As randomization was performed by the center, each patient within each center was assigned a sequential ascending random number to complete a pre-defined block size of four. Matching placebos were used.

Treatments:

Moxifloxacin 400 mg once daily for 7 days, matching placebo once daily for days 8–10

Trovafloxacin 200 mg once daily for 10 days

Outcome:

Primary - clinical response 7–10 days after the end of therapy, “clinical resolution” is defined by disappearance of signs and symptoms or improvement and no further therapy required

Secondary - final follow up 3 to 4 weeks after the end of therapy

Results: Primary efficacy analysis was performed on clinically evaluable patients: confirmed clinical and x-ray dx of acute sinusitis, received at least 5 days of therapy (with no other abx administered concomitantly), followed the protocol and received post-therapy clinical evaluation within 3 to 14 days after ending the study drug therapy

503 enrolled, 452 valid for efficacy analysis; most common reasons fro exclusion were violation of the time schedule for evaluation and insufficient duration of therapy

Reported clinical failure rate 7–10 days post-therapy:

Moxifloxacin 7/223 (3.1%)

Trovafloxacin 18/229 (7.9%)

Microbiological failure rate:

Moxifloxacin 5/90 (5.6%)

Trovafloxacin 10/101 (9.9%)

Adverse events:

Drug-related adverse events occurring in ≥ 2% of patients

| Moxifloxacin N=248 | Trovafloxacin N=251
Dizziness | 3 (1.2%) | 21 (8.4%)
Diarrhea | 14 (5.6%) | 3 (1.2%)
Nausea | 3 (1.2%) | 10 (4%)
Asthenia | 5 (2%) | 6 (2.4%)
Vertigo | 2 (0.8%) | 8 (3.2%)
Abdominal Pain | 5 (2%) | 4 (1.6%)

One or more serious events were reported for 4 moxifloxacin and 2 trovafloxacin-treated patients. However, only 2, in one patient of the moxifloxacin group, were considered to be drug-related (pruritus and tachycardia) necessitating study drug discontinuation. 5 patients (2%) receiving moxifloxacin and 12 (4.8%) of trovafloxacin treated patients discontinued therapy prematurely. Early discontinuation was at least in part due to dizziness/vertigo in 6/12 patients who received trovafloxacin compared to 1/5 of those in the moxifloxacin group.

Of the 499 patients evaluated for safety, treatment-emergent adverse events were reported by 74 (29.8%) of moxifloxacin group and 82 (32.7%) of the trovafloxacin group.

Funding: not stated

Comments: authors Arvis & Leberre associated with Bayer Pharma, France

## Kutluhan et al. 2002 ID 97073

Stated Purpose of the Study: To determine the most appropriate duration of treatment in adult patients with bacterial acute maxillary sinusitis and to investigate whether a linear correlation is present between nasal smear findings and symptoms of acute maxillary sinusitis at the time of diagnosis and the follow-up period

Population & Setting:

Selected group of 40 clinic patients in Turkey enrolled in the study between 1998 and 2001.

Mean age (range): 29 (16–45)

Inclusion criteria: bacterial acute maxillary sinusitis diagnosed by maxillary sinus puncture; also clinical signs and symptoms (major and minor, see table 1 in paper); x-ray opacification and air-fluid level;

Exclusion criteria: x-ray findings of mucosal thickening or cysts...etc.; acute sinusitis within the last 6 months; chronic sinusitis

Study design: prospective, randomized; method of randomization not stated

Treatments:

Group 1 = 10 patients | 1 week antibiotic
Group 2 = 10 patients | 2 week antibiotic
Group 3 = 10 patients | 3 week antibiotic
Group 4 = 10 patients | 4 week antibiotic

Antibiotic choice was made depended on culture and sensitivity results from maxillary sinus puncture.

Amox/Clav 1 g twice a day

Ciprofloxacin 500 mg (dosing frequency not specified)

Clarithromycin 500 mg twice a day

Cefuroxime 250 mg twice a day

Patients were allowed Paracetamol if needed.

Outcome: Presence or absence of symptoms at study day 7, 14, 21, 28 and 56

Results: Total number of patients completed the study was not explicitly stated in the paper.

At day 7 and 14, no reported relapse in any patients.

At day 28, relapse of the symptoms was noted in 5, 2, 2 and 3 patients in groups 1, 2, 3, and 4.

Assuming all patients completed the study, the following relapse rate at day 28 can be calculated:

1 week antibiotic | 5/10 (50%)
2 week antibiotic | 2/10 (20%)
3 week antibiotic | 2/10 (20%)
4 week antibiotic | 3/10 (30%)

Adverse events: data not presented

Funding:

Comments: Total number of patients completed the study was not explicitly stated in the paper. Number of patients with relapse on other study days was not reported.

## Lasko et al. 1998 ID 530

Stated Purpose of the Study: This report presents the findings of the first multicenter, randomized, double-blind trial in acute sinusitis evaluating the efficacy of levofloxacin compared with clarithromycin in the management of acute sinusitis.

Population & Setting: 236 patients were randomized into 2 groups.

Levofloxacin | 119 | Mean age (range) 40.4 (18–83) | Males | 44.4%
Clarithromycin | 117 | Mean age (range) 39.9 (18–78) | Males | 41.9%

Inclusion criteria: male and female patients > 18 y/o with clinical symptoms of acute sinusitis and positive x-ray of opacification, air fluid level or mucosal thickening ≥ 5 mm, not pregnant, see paper for details.

Exclusion criteria: symptoms > 4 weeks or hx of > 2 episodes of sinusitis within the previous year, reaction to quinolone or macrolide abx and others (see paper)

Study design: multicenter, randomized, double-blind trial; randomization based on a computer-generated randomization schedule; double-blinding was accomplished by encapsulation of 250 mg tablets of levofloxacin or clarithromycin.

Treatments:

Levofloxacin 2×250 mg capsules in am and matching placebos in pm for 10–14 days

Clarithromycin 2×250 mg capsules twice a day for 10–14 days

Outcome: Primary: Clinical success is defined by “cured” or “improved”. The assessment took place 2–5 days after completing therapy.

Secondary: Patients were assessed for relapse or worsening of symptoms and had a repeat sinus x-ray at days 28–32 after completing therapy.

Results: 236 randomized; 191 evaluable for clinical efficacy; 21 (17.6%) unevaluable in Levofloxacin arm, 24 (20.5%) unevaluable in clarithromycin arm; majority of patient were excluded either because the admission x-ray was negative or they were lost to follow-up.

Reported clinical failure rate in evaluable patients:
Levofloxacin | 6/98 (6.1%)
Clarithromycin | 6/93 (6.5%)

Adverse events:

| Levofloxacin (n=119) | Clarithromycin (n=117)
All Body Systems | 27 (22.7%) | 46 (39.3%)
GI | 20 (16.8%) | 39 (33.3%)
CNS (dizziness,headache) | 8 (6.7%) | 5 (4.3%)
Taste Perversion | 1 (0.8%) | 9 (7.7%)
Loss of appetite, disorientation and insomnia | 5 (4.2%) | 4 (3.4%)

See table 6 for rest.

Comparison of laboratory data collected at admission and post therapy demonstrated no significant changes in laboratory values.

Funding: Janssen-Ortho Inc.

Comments:

## Lindbæk et al. 1998 ID 586

Stated Purpose of the Study: To compare the efficacy of penicillin V, amoxicillin and placebo given to patients with mucosal thickening on CT without fluid level or total opacification

Population & Setting:

244 patients from 29 family practice centers in Norway. Unknown study years.

Penicillin V group (n=20): | Mean age (range)= 41.2 yrs (unknown range) | Males= 8 (40%)
Amoxicillin group (n=22): | Mean age (range)= 37.1 yrs (unknown range) | Males= 11 (50%)
Placebo (n=21) | Mean age (range)= 32.5 yrs (unknown range) | Males= 6 (29%)

Inclusion Criteria:

Patients with clinical Si/Sx of acute sinusitis (based on scoring system including: hyposmia/anosmia, unilateral facial pain, pain in upper teeth, pain worsening at bending forward, “double sickening,” nasal obstruction, rhinorrhea, sinus pain, malaise, fever and purulent secretion) of ≥7 days duration AND paranasal sinus mucosal thickening ≥5mm without air-fluid levels or total opacification on CT scan.

Exclusion Criteria:

Age≤ 15 years; pregnancy; ongoing antibiotic treatment; immunosuppressive treatment, previous sinus/nose surgery; alcohol or drug abuse; rheumatic disease; penicillin allergy; chronic sinusitis; high fever; high degree of pain.

Study Design: Randomized (unknown method of randomization and concealment), double blinded to clinician, patient and radiologist (study drugs were all similar-appearing tablets), multi-center trial. Unknown if prestratified by center.

Treatment:

1. Penicillin V 1320 mg TID for 10 days
2. Amoxicillin 500 mg TID for 10 days
3. Matched Placebo TID for 10 days

Outcome: Subjects kept a diary and after 10 days of treatment answered if they thought they still had sinusitis. If the answer was no, the diary was stopped (day of cure). The daily diary continued until the answer was no until a maximum of 30 days.

(Primary) Subjective status: After 10 days of treatment, subjects ranked their own condition as restored, much better, somewhat better, unimproved or worse.

(Secondary) Clinical score: Assessed after 10 days of treatment. Maximum value of 4. Summed from four visual analogue scales based on subjects' ranking their own degree of nasal obstruction, rhinorrhea, sinus pain and malaise.

Results: 244 enrolled and 70 randomized. 20 in penicillin V group, 22 in amoxicillin group and 21 in placebo group were evaluated for clinical efficacy (intent to treat analysis). 7 subjects were excluded (unknown from which groups) for reasons including: poor quality CT scans and failure to return a diary.

Clinical Failure: (Primary) 2/20 in penicillin V group, 3/22 in amoxicillin group and 3/21 in placebo group failed (includes unimproved and worse). (Secondary) Mean reduction in clinical score was 1.1 (95%CI 0.8,1.5) in penicillin V group, 1.1 (0.6–1.6) in amoxicillin group, and 1.0 (0.7–1.3) in placebo group.

Adverse Events: not reported

Funding: Norwegian Research Council

Comments: Use of nasal decongestants and paracetamol was allowed but not recorded. Compliance with study medications is unknown. If a patient asked for another antibiotic after 10 days because subjective symptoms persisted, (s)he was given amoxicillin 500 mg TID for 10 days. The median number of days before a patient was no longer feeling ill (Kaplan-Meier plot) was 13.5 days in penicillin V group and 10 days in both the amoxicillin and placebo groups.

## Luterman et al. 2003 ID 97041

Stated Purpose of the Study: To compare the efficacy and safety of 5- and 10-day courses of telithromycin with that of a standard 10-day regimen of amoxicillin/clavulanic acid in the treatment of acute maxillary sinusitis (AMS).

Population and Setting: 7/17/98–6/16/99 in 69 centers in US, Canada, S. Africa, Argentina & Chile

Median age (range):

Group 1: 800 mg telithromycin qd for 5 days : 38 y/o (18–69)

Group 2: 800 mg telithromycin for 10 days: 39 y/o (18–84)

Group 3: 500/125 mg amoxicillin/clavulanic tid for 10 days: 38.5 (16–79)

Inclusion criteria: ≥ 18 y/o with presumed acute maxillary sinusitis (purulent nasal discharge, maxillary tenderness...etc.); <28 days Symptoms; sinus x-ray: presence of air-fluid level and/or total sinus opacity and/or ≥6 mm mucosal thickening within 48 hours of enrollment.

Exclusion criteria: History of chronic or recurrent sinusitis, sphenoid or nosocomially acquired sinusitis, suspected nonbacterial infection, obstructive anatomic lesions in nasopharynx, documented resistant organisms, immotile cilia syndrome, CF or odontogenic infection; immune-compromised, hypersensitivity to macrolide or beta-lactam abx; on steroids or any drug that interferes with efficacy and safety assessments of study medication; progressively fatal illness, long Q-T syndrome, severe hypokalemia, hx of drug or ETOH abuse, renal or hepatic impairment, and lactation or pregnancy

Study Design: Randomized (1:1:1) Controlled Trial, double-blind, 3-arm, parallel-group design

Treatments: Group 1: 800 mg telithromycin qd for 5 days

Group 2: 800 mg telithromycin for 10 days

Group 3: 500/125 mg amoxicillin/clavulanic tid for 10 days

Outcome: (Primary) Test of Cure Outcome visit between days 17 and 24. (Secondary) Late post-therapy visit between days 31 and 45; cure: no infection, clinical improvement or to preinfection state without need for further abx; normal, improved or not worse sinus x-rays; pts whose signs or symptoms were unchanged or worse and who needed more abx were treatment failures.

Results: 754 enrolled, 753 received at least 1 abx, 146 excluded because x-ray was not consistent,

modified ITT: 607

Clinically evaluable at end of study: 423, Group 1: 146; Group 2: 140; Group 3: 137

184 excluded because of major protocol violation

Clinical Failure:

Group 1: 36/146 (24.7%); Group 2: 38/140 (27.1%); Group 3: 35/137 (25.5%)

Microbiological Failure: 29 patients had sinus punctures. Most common organisms isolated were S. pneumoniae and H. influenzae.

- Primary: Group 1: 1/7; Group 2: 1/7; Group 3: 2/10
- Secondary: Group1: 2/7; Group 2: 2/7; Group 3: 2/7

Adverse events: 327 patients (44%) experienced one or more treatment-emergent adverse events that were considered to be possibly related to a study med during the study. Diarrhea and nausea were the most common adverse events in each treatment group. 41 patients (5.5%) withdrew because of adverse events (group 1: 16 [6.6%], group 2: 14 [5.5%], group 3: 11 [4.5%]). 7 patients (1%) experienced at least one serious adverse event - 3 in the 10-day telithromycin group (allergy, gastroenteritis, and pseudomembranous colitis [one patient each]) and one in the amox/clav group (pseudomembranous colitis) were considered drug related. No deaths occurred during the study. No patient had QTc interval of 500 msec. or more.

Funding: Aventis Pharmaceutical

Comments: Stability problem with amox/clav; 100 patients from that group were excluded, new population were recruited. Data from the excluded patients were not reported.

## Murray et al. 2000 ID 375

Stated Purpose of the Study: To compare the clinical efficacy and tolerability of clarithromycin extended-release(ER) (1000 mg once daily) and clarithromycin immediate-release (IR) (500 mg twice daily) over a 14-day treatment course in patients with acute maxillary sinusitis

Population & Setting: 284 patients from 37 investigative sites throughout the US and Canada between 3/1998 and 10/1998 were studied.

Clarithromycin ER | 142 | mean age (range) 41.9 (13–78) | males 35%
Clarithromycin IR | 141 | mean age (range) 41 (15–73) | males 38%

Inclusion criteria: ≥ 12 y/o; presumptive dx of acute maxillary sinusitis supported by confirmatory sinus radiographs obtained within 72 hours before treatment; signs and symptoms for at least 7 days before and not longer than 28 days before the pretreatment visit (see paper for details)

Exclusion criteria: chronic maxillary sinusitis; frontal, ethmoid or sphenoid sinusitis, systemic abx within 3 weeks; significant renal or hepatic impairment; pregnant or likely to become pregnant; see paper for others

Study design: Phase III, randomized, controlled, double-blind, parallel-group, multicenter study. Randomly assigned in a 1:1 ratio at each investigative site.

Treatments:

Clarithromycin extended-release (ER) two 500 mg tablets once daily plus placebo for clarithromycin IR for 14 days

Clarithromycin immediate-release (IR) one 500 mg tablet twice daily plus placebo for clarithromycin ER for 14 days

All patients were dispensed 0.05% oxymetazoline nasal spray to be used as a decongestant twice daily in conjunction with clarithromycin during the 1^st^ 3 days of study drug administration.

Outcome: Test of cure was determined on 10 to 17 days after completion of therapy. Clinical cure was defined by resolution or improvement of symptoms, no worsening of x-ray appearance of sinuses and no further abx needed.

Results: 284 enrolled; 283 received treatment; 38 (20 ER; 18 IR) were deemed non-assessable

Calculated Clinical Failure Rate (100% - reported clinical cure rate):

Clarithromycin extended release 18/122 (14.8%)

Clarithromycin immediate release 26/123 (21.1%)

Clinical response rates were similar in the intent-to-treat analysis per study authors.

Adverse events:

Adverse events were reported by 45/142 (32%) in the clarithromycin ER group and 40/141 (28%) in the IR group. Most commonly reported drug-related adverse events were

| ER | IR
Abnormal taste | 10% | 10%
Diarrhea | 6% | 8%
Nausea | 5% | 9%

No patient in this study experienced a serious adverse event.

Premature discontinuation from treatment due to a drug-related adverse event occurred in 5/142 (4%) of patients in the ER group and 11/141 (8%) in the IR group.

2/142 (1%) in the ER group and 10/141 (7%) in the IR group prematurely discontinued treatment because of a drug-related GI or abnormal taste adverse event.

Funding: Abbott Laboratories

Comments:

## Namyslowski et al. 2002 ID 189

Stated Purpose of the Study: To compare the clinical efficacy and safety of oral amox/clav with that of cefuroxime axetil in the treatment of chronic bacterial sinusitis and acute exacerbation of chronic sinusitis in adults

Population & Setting: 231 (outpatients or inpatients) in 4 centers in Poland were enrolled.

| Intent to treat population
Amox/Clav | 115 | mean age 37 | males 57%
Cefuroxime | 116 | mean age 41 | males 47%

Inclusion criteria: ≥ 18 y/o; hospitalized and non-hospitalized; chronic sinusitis > 3 months; abnormal x-ray; acute exacerbation of chronic sinusitis confirmed by x-ray, symptoms ≤ 4 weeks with a history of at least 2 acute sinusitis requiring abx the previous 12 months; antral sinus puncture within 48 hours prior to starting therapy and evidence of the presence of an infection for which oral antibiotic therapy with either amox/clav or cefuroxime was appropriate (no further explanation given, see paper for details regarding inclusion criteria)

Exclusion criteria: history of hypersensitivity reaction to beta-lactam abx or received abx within 2 weeks prior to enrollment; confirmed or suspected allergic sinusitis; see paper for rest

Study design: prospective, randomized, parallel, open, multicenter

Treatments:

Amox/Clav 875/125 mg oral twice a day for 14 days

Cefuroxime axetil 500 mg oral twice a day for 14 days

Outcome:

Primary: clinical response at the end of therapy (study day 15–18)

Results: 231 in intention-to-treat population; 206 evaluable

Intent to treat population
Reported failure rate: | amox/clav 3/115 (2.6%) | cefuroxime 8/116 (6.9%)
Reported Indeterminate rate: | amox/clav 6/115 (5.2%) | cefuroxime 8/116 (6.9%)
Calculated failure rate (100% - reported clinical cure rate): | amox/clav 9/115 (7.8%) | cefuroxime 16/116 (13.8%)
Clinically evaluable population
Reported failure rate: | amox/clav 3/104 (2.9%) | cefuroxime 8/102 (7.8%)
Reported Indeterminate rate: | amox/clav 2/104 (1.9%) | cefuroxime 4/102 (3.9%)
Calculated failure rate (100% - reported clinical cure rate): | amox/clav 5/104 (4.8%) | cefuroxime 12/102 (11.8%)
Microbiological failure in evaluable population:
Amox/clav 22/65 (33.8%)
Cefuroxime 20/62 (32.3%)

Adverse events:

| Amox/Clav (n=115) | Cefuroxime (n=116)
Patients with at least 1 adverse event | 8 (7%) | 11 (9.5%)
Patients with serious adverse event* | 1 (0.9%) | 3 (2.6%)
Patients with drug related adverse event | 5 (4.3%) | 5 (4.3%)
Diarrhea | 2.6%) | 3 (2.6%)
Urticaria | 0 | 2 (1.7%)
Facial edema | 0 | 1 (0.9%)
Discontinuation of med 2° to adverse event | 4 (3.5%) | 9 (7.8%)

*amox/clav group: 1 experienced an eye disorder the day after starting treatment

cefuroxime group: 1 urticaria related to study drug; 1 underwent maxillary sinus surgery 7 days after starting treatment; 1 experienced a cardiovascular disorder and was hospitalized

Funding:

Comments:

## Rakkar et al. 2001 ID 97064

Stated Purpose of the Study: To compare the efficacy and safety of a 10-day oral treatment of moxifloxacin with amoxicillin/clavulanate for the outpatient management of uncomplicated acute sinusitis of suspected bacterial origin

Population & Setting: 475 patients in 85 primary care practice sites in US, study years not specified

Moxifloxacin = 234 (Intent To Treat) | Mean age (range)= 43 (19–78) | males= 31%
Amox/Clav = 237 | Mean age (range)= 42 (18–87) | males= 35%

Inclusion criteria: ≥ 18 y/o; outpatient men and non-pregnant women, clinical dx of acute suspected bacterial sinusitis ≥ 7 days but < 30 days duration (nasal congestion, post-nasal drainage, frequent coughing or throat clearing, frontal headache, malar tenderness/pain and purulent nasal discharge)

Exclusion criteria: symptoms > 4 weeks (chronic sinusitis) or frequent recurrent acute sinusitis (> 2 episodes within the past 12 months despite appropriate therapy; history of sinus surgery and others (see paper)

Study design: Prospective, multicenter, non-blinded, two-arm comparative study. Patients were randomly assigned to one of two treatment groups using a block design random code. A pill count was used to assess patient compliance at completion of the study.

Treatments:

Moxifloxacin 400 mg once a day for 10 days

Amox/Clav 875 mg twice a day for 10 days

Outcome:

Primary: Clinical response at the test-of-cure visit (13–21 days post treatment) was the primary efficacy variable.

Secondary: Clinical response at day 26–46 post treatment

Results on Intent to Treat (ITT) population:

475 patients randomized into 2 groups moxifloxacin (238) and amox/clav (237). 4 patients in the moxifloxacin group never received the study medication and were excluded from the ITT population in the study. 85% (199/234) of moxifloxacin and 82% (194/237) of amox/clav reported clinical resolution.

Clinical Failure (ITT): Primary: moxifloxacin 35/234 (15%) and amox/clav 43/237 (18.1%)

Secondary (denominator assumed): moxifloxacin 6/234 (2.6%) and amox/clav 4/237 (1.7%)

134 patients were excluded from per protocol (efficacy) analysis (see table 1 in paper).

The per protocol (efficacy) population included 170 moxifloxacin and 171 amox/clav treated patients. 86% of moxifloxain and 84% for amox/clav reported clinical resolution.

Clinical Failure (patients who actually received study medications): Primary: Moxifloxacin 24/170 (14%) and Amox/clav 27/171 (16%)

Secondary (denominator assumed): moxifloxacin 6/170 (3.5%) and amox/clav 6/171 (3.5%)

Adverse events: 471 patients were evaluated for safety, treatment emergent adverse events were reported for 136 (58%) moxifloxacin and 124 (52%) amox/clav treated patients. Premature discontinuation due to any adverse event was required in 5% (12) and 3% (8) of patients, respectively. Drug-related adverse events were reported in 30% of moxifloxacin and 25% of amox/clav treated patients and were primarily GI-related: nausea (11% moxifloxacin, 5% amox/clav) and diarrhea (3% moxifloxacin, 10% amox/clav). An elevation in hepatic enzymes (100% above baseline for ALT/AST) was noted 0–6 days post-treatment in a small number of patients. Specifically, enzyme elevations were observed in 1.7% of moxifloxacin-treated patients (n=4) compared with 4.6% of amox/clav treated patients (n=11).

Funding: Bayer

Comments: Use of oral or nasal decongestants or antihistamines was permitted during the study period, including phenylephrine nose drops as needed. Systemic or topical corticosteroids were not allowed unless the patient had been on long-term therapy before study entry.

## Roos et al. 2002 ID 240

Stated Purpose of the Study: To compare the efficacy and tolerability of a 5 and 10 day course of oral treatment with telithromycin 800 mg once daily in patients with community acquired acute maxillary sinusitis

Population & Setting: 343 from 37 centers in 9 countries (Austria, Croatia, Czech Republic, Denmark, Finland, France, Germany, Greece and Sweden) enrolled. The study was conducted between 4/1998 and 4/1999.

5-day telithromycin | 167 | median age (range) 34 (18–65) | male 49.7%
10-day telithromycin | 168 | median age (range) 39 (18–66) | male 48.2%

Inclusion criteria: 18–65 y/o with a dx of acute maxillary sinusitis; x-ray showing total sinus opacity or air-fluid level and at least 1 clinical criterion (see paper for details)

Exclusion criteria: chronic sinusitis (> 1 month); recurrent sinusitis (> 3 episodes that required abx in the previous 12 months); concomitant sphenoidal sinusitis; patients were suspected non-bacterial infections or microbiologically documented infection with pathogens known to be resistant to telithromycin before treatment were also excluded; known long QT syndrome; pregnancy; lactation; other abx 7 days prior to study entry

Study design: randomized, double-blind study; patients were pre-screened by sinus puncture; susceptibility testing was performed using disk diffusion methods at each individual center; disk zone inhibition and MIC testing were also carried out by a central laboratory;

Method of randomization not stated;

Blinding was maintained by matching placebos.

Treatments:

Telithromycin 800 mg once daily for 5 days, matching placebo once daily on study day 6–10

Telithromycin 800 mg once daily for 10 days

Outcome:

Primary - Primary efficacy variable was the rate of clinical cure at the post-therapy/test of cure visit (days 17–21) in the clinical per-protocol population. Clinical cure was defined as the improvement or return to preinfection state, or improvement with persistence of residual symptoms but with no need for subsequent abx, with a sinus x-ray or CT scan that was either normal or improved.

Secondary - Secondary efficacy variables were clinical outcome at the late post-therapy visit (days 31–36) along with bacteriologic outcome at the post-therapy/test of cure and late post-therapy visits.

Results: 343 enrolled, 341 randomized; 336 received at least 1 dose of medication; of the 336, one was excluded because x-ray was not consistent with acute maxillary sinusitis; 335 in the modified intent-to-treat population; 79 excluded for major protocol violations, leaving 256 in the clinical per-protocol population

| Telithromycin 5-day | 10-day
Post-therapy, TOC days 17–21
Calculated Clinical Failure Per-protocol | 11/123 (8.9%) | 12/133 (9%)
Calculated Failure mod ITT | 29/167 (17.4%) | 21/168 (12.5%)
Late post-therapy, days 31–36
Calculated Clinical Failure Per-protocol | 12/108 (11.1%) | 12/120 (10.8%)
Calculated Failure mod ITT | 32/167 (19.2%) | 23/168 (13.7%)
Microbiological Failure
Post-therapy, TOC days 17–21
Calculated Bacteriological Failure Per-protocol | 5/70 (7.1%) | 7/69(10.1%)
Calculated Failure mod ITT | 17/97 (17.5%) | 11/104 (10.6%)
Late post-therapy, days 31–36
Calculated Bacteriological Failure Per-protocol | 6/60 (10%) | 8/61 (13.1%)
Calculated Failure modITT | 20/97 (20.6%) | 13/104 (12.5%)

Adverse events:

166 in 5-day group and 167 in 10-day group were included in the safety analysis.

50/166 (30.1%) in 5-day group and 64/167 (38.3%) in 10-day group experienced at least 1 treatment-emergent adverse event.

6/166 (3.6%) in 5-day group and 1/167(0.6%) in 10-day group discontinued the study because of adverse events. The events in the 5-day group were diarrhea, nausea, vomiting, cholelithiasis, facial edema, infection, and increased alkaline phosphatase levels (1 each). GI pain was the reason for discontinuation of the one patient in the 10-day group.

1 patient in the 5-day group had increased aspartate transaminase that was considered to be clinically noteworthy abnormal laboratory value (CNALV, defined as >3 upper limit of normal)

1 patient in the 10-day group had increased ALT that was considered to be CNALV.

The patients recovered without sequelae.

Adverse event ≥ 2% in either Rx group | 5 day (166) | 10 day (167)
Diarrhea | 16 (9.6%) | 22 (13.2%)
Nausea | 8 (4.8%) | 4 (2.4%)
GI pain | 3 (1.8%) | 8 (4.8%)
Vaginal Moniliasis | 5 (3%) | 3 (1.8%)
Increased ALT | 4 (2.4%) | 1 (0.6%)
Vertigo | 1 (0.6%) | 4 (2.4%)

Funding:

Comments: Patients with pathogens known to be resistant to telithromycin before treatment were excluded; authors Leroy, Rangaraju and Boutalkb associated with Aventis Pharma

## Seggev et al. 1998 ID 563

Stated Purpose of the Study: To compare the safety and efficacy of amox/clav given orally every 12 hours with that given every 8 hours in patients with acute bacterial maxillary sinusitis

Population & Setting: 170 patients from 11 centers in US and Canada participated.

12-hour group | 61 (pts completed study) | mean age (range)= 39.3 (23–75) | male= 50.8%
8-hour group | 73 (pts completed study) | mean age (range)= 40.3 (18 - 81) | male= 39.7%

Inclusion criteria: ≥ 18 y/o; acute bacterial maxillary sinusitis < 4 weeks duration (see paper for clinical criteria) and abnormal x-ray (opacification, air fluid level, or ≥ 5 mm swelling of the mucosa) or abnormal CT scan; baseline serum creatinine < 2.3 mg/dL

Exclusion criteria: hx of hypersensitivity to PCN, cephalosporins, or other beta-lactams; pregnancy or lactation; chronic sinusitis as defined by 2 or more episodes within the previous 12 months or continuing symptoms for longer than 4 weeks; intraorbital or intracranial complications that interfered with the interpretation of a radiograph or CT scan of the affected sinuses; see paper for others

Study design: multi-center, randomized, double-blind, double-dummy (each patient received 1 of the 2 active treatments with a placebo of the alternative treatment, parallel; method of randomization not stated

Treatments:

Amox/Clav 875/125 mg every 12 hours plus an oral placebo every 8 hours for 14 days

Amox/Clav 500/125 mg every 8 hours plus an oral placebo every 12 hours for 14 days

Nasal steroids and decongestants, oral antihistamines and decongestants were allowed at the investigator's discretion.

Outcome:

Primary: Clinical response was assessed 2 to 3 days after completion of treatment. Clinical success was defined as either cure or improvement.

Secondary: Clinical response was assessed 2–4 weeks after the end of treatment.

Results:

Reported end of therapy Clinical Failure Rate (100% - reported clinical success rate in evaluable population): | 12 hour group = 4/61 (6.6%) | 8 hour group = 9/73 (12.3%)
Calculated Intent to treat failure rate (100% reported ITT clinical success rate): | 12 hour group = 15/87 (17.2%) | 8 hour group = 12/83 (14.5%)
Reported 2 4 wk follow up Failure Rate (100% reported persistent cure plus recurrence rate in evaluable population): | 12 hour group = 4/61 (6.6%) | 8 hour group = 10/73 (13.7%)

Adverse events: 2 patients in the 12-hour group and 2 patients in the 8-hour group reported adverse events (12-hour group, 1 with diarrhea and 1 with coughing; 8-hour group, 1 with coughing and 1 with rash) that led to withdrawal from the study.

| Amox/clav 12-hour n=87 | 8-hour n=83
possible drug related adverse | 9 (10.3%) | 17 (20.5%)
genital moniliasis | 2 (2.3%) | 6 (7.2%)
nausea | 1 (1.1%) | 3 (3.6%)
diarrhea | 2 (2.3%) | 1 (1.2%)
abdominal pain | 1 (1.1%) | 2 (2.4%)
dyspepsia | 1 (1.1%) | 2 (2.4%)
fungal infection | 2 (2.3%) | 0
dizziness | 0 | 2 (2.4%)

see table 4 in paper for others.

Funding: SmithKline Beecham

Comments: 16/87 (18.4%) in the 12-hour group and 22/83 (26.5%) in the 8-hour group received concurrent nasal steroids.

## Sher 2002 ID 209

REJECTED STUDIES: Adverse events extraction only

Stated Purpose of the Study: Evaluate the efficacy and safety of gatifloxacin 400 mg once daily in adults with acute uncomplicated bacterial sinusitis, community-acquired pneumonia and acute bacterial exacerbations of chronic bronchitis. *Note: only the diagnosis of acute uncomplicated rhinosinusitis is included in this study

Population and Setting: 11,564 adult patients enrolled by 2,795 investigators in the US over an unknown time period.

Diagnoses included in the study:

Acute uncomplicated bacterial rhinosinusitis

Treatment: Gatifloxacin 400 mg QD × 10 days

Study Design: open-label, multicenter, noncomparative study.

Adverse Events Included in Analyses: All patients who received at least one dose of gatifloxacin (N=11,476) were evaluated for safety from the first day of study drug therapy to 7–14 days after the last dose of gatifloxacin by office visit or telephone. Adverse events were monitored until resolution or stabilization. The definition of serious adverse events included cancer, death or persistent or significant disability; were life-threatening; required prolonged hospitalization; resulted in drug dependence, abuse or overdose; jeopardized the patient; or required intervention to prevent a serious outcome.

Adverse Events: 1605/11,476 subjects (14.0%) experience drug-related adverse events.

Most common adverse events deemed drug-related:

Symptom | % (N=11,476)
Nausea | 4.4%
Dizziness | 1.8%
Diarrhea | 1.4%
Headache | 1.0%

41/11,476 (0.4%) experienced adverse events related to the cardiovascular system. No patients displayed abnormal electrocardiograms. 14 serious adverse events occurred in 11,476 patients (0.1%) and included: allergic reaction, facial/tongue edema, bacterial infection, migraine, diarrhea, hepatitis, hyperglycemia, hypoglycemia, confusion, asthma, increased cough and convulsion.

Funding: Bristol-Myers Squibb Co.

Comments: Use of intranasal corticosteroids, oral or topical decongestants and antihistamines was permitted.

## Sher et al. 2002 ID 257

Stated Purpose of the Study: To compare the clinical efficacy of 5-day course of gatifloxacin, 10-day course of gatifloxacin and 10-day course of amoxicillin/clavulanate in patients with acute, uncomplicated maxillary sinusitis

Population & Setting: 445 patients from 30 study centers were enrolled. Study years not specified.

5-day Gatifloxacin | 149 | mean age (range) 41.13 (18–74) | males 36%
10-day Gatifloxacin | 141 | mean age (range) 42.38 (18–72) | males 35%
Amox/Clav | 155 | mean age (range) 41.88 (18–89) | males 36%

Inclusion criteria: >18 y/o; clinical dx of acute uncomplicated maxillary sinusitis for at least 7 days and radiographic findings, opacification, air/fluid level, or mucosal thickening of ≥ 5 mm in 1 or both maxillary sinuses (see paper for details)

Exclusion criteria: sinusitis > 28 days, complicated sinusitis, anatomic abnormalities, >1 dose of systemic antibiotic within 7 days of enrollment and others (see paper).

Study design: Multicenter, investigator-blinded, randomized. Patients were randomized to treatment by means of a centralized telephone system. A permuted block design was used to minimize imbalance in treatment arms at each site and in the study overall. Patients in each treatment group received blister cards containing the appropriate combination of active drug and matching placebo tablets to provide 10 days of twice-daily therapy.

Treatments:

Gatifloxacin 400 mg once daily for 5 days

Gatifloxacin 400 mg once daily for 10 days

Amox/Clav 875 mg twice daily for 10 days

Outcome: Primary: clinical response was determined by the investigator at each site and was classified as cure, failure, or unable to determine. Clinical cure was defined as improvement in or resolution of all acute signs and symptoms. Test of cure visit took place 7 to 14 days after the completion of study treatment.

Results: 405/445 patients were classified as clinically evaluable. 40 unevaluable patients were distributed evenly between groups (see paper for details)

Calculated Clinical Failure Rate (100% - reported clinical cure rate):

5-day Gatifloxacin 35/137 (25.6%)

10-day Gatifloxacin 26/127 (20.5%)

Amox/Clav 40/141 (28.4%)

Adverse events:

| 5-day Gatifloxacin | 10-day Gatifloxacin | Amox/Clav
vaginitis | 9% of women | 9% of women | 14% of women
diarrhea | 9% of subjects | 7% of subjects | 14% of subjects
nausea | 9% | 14% | 4% (p=0.007)

Ten patients discontinued therapy due to ≥ 1 drug-related adverse event (2, 5 and 3 patients in 5-day gatifloxacin, 10-day gatifloxacin and amox/clav, respectively).

One patient in the amox/clav group discontinued therapy due to elevated liver enzymes.

Three patients in the 10-day gatifloxacin group had abnormal baseline laboratory values (2 elevated aspartate aminotransferase level; 1 elevated bilirubin level) that had worsened 7 to 23 days after the completion of therapy.

Funding:

Comments: Authors Li & Pierce associated with Bristol-Myers Squibb

## Siegert et al. 2000 ID 415

Stated Purpose of the Study: To compare the efficacy and safety of moxifloxacin with that of cefuroxime axetil for the treatment of acute bacterial sinusitis in adults.

Population & Setting:

498 patients in 60 centers in 7 countries: Finland, France, Germany, Greece, Israel, Spain and Sweden

Moxifloxacin group (n=242) | mean age= 40.4 y/o | 109 males (45%)
Cefuroxime group (n=251) | mean age= 40.3 y/o | 111 males (44.2%)

Inclusion Criteria: ≥ 18 y/o outpatients; acute bacterial sinusitis; sinusitis diagnosed either bacteriologically or clinically on the basis of sinus x-ray together with 2 or more symptoms: purulent nasal d/c or nasal congestion, post-nasal drainage, frequent coughing or throat clearing, malar tenderness or pain, frontal headache

Exclusion Criteria: hx of hypersensitivity to study or related drug, chronic sinusitis, received systemic abx within 48 hours of enrollment; pregnancy, lactation and others (see original paper)

Study Design: Prospective, randomized, multicenter, double-blind phase III clinical trial; method of randomization not stated

Treatment: Moxifloxacin 400 mg in AM, placebo in PM for 7 days; placebo twice a day on study days 8–10

Cefuroxime Axetil 250 mg twice a day for 10 days

Outcome (Primary): End of treatment examination on study day 14 (4 days after the end of Rx);

Clinical response was the primary efficacy evaluation.

Secondary: follow up evaluation 27–31 days after the end of treatment

Results: 498 enrolled; 493 randomized; 436 evaluable

On study day 14:

In ITT population, reported Failure: 11/242 in Moxifloxacin; 22/251 in Cefuroxime

reported Indeterminate: 9/242 in Moxifloxacin; 7/251 in Cefuroxime

reported Missing: 6/242 in Moxifloxacin; 3/251 in Cefuroxime

Calculated Clinical Failure Rate in ITT population (100% - (number of clinical resolution/total ITT population)×100%): 26/242 (10.7%) in Moxifloxain; 32/251 (12.7%) in Cefuroxime

In evaluable population, reported Failure rate: 7/211 (3.3%) in Moxifloxacin; 21/225 (9.3%) in Cefuroxime

At follow up 27–31 days after the end of treatment:

Calculated Cinical Failure Rate in follow up population (100% - (number of clinical success/total follow up population)×100%): 19/204 (9.3%) in Moxifloxacin; 22/204 (10.8%) in Cefuroxime

Reported Microbiological failure rate at end of treatment (day 10): 6/109 (5.5%) in Moxifloxacin group; 19/115 (16.5%) in the Cefuroxime group.

Adverse events:

| Moxifloxacin (n=242) | Cefuroxime (n=252)
Any adverse event | 105 (43.4%) | 88(35.1%)
Drug-related adverse event | 74 (30.6%) | 56 (22.3%)
Serious adverse event* | 3 (1.2%) | 8 (3.2%)
Discontinuation 2° to adverse event | 14 (5.8%) | 11 (4.4%)
Diarrhea | 23 (9.5%) | 15 (6%)
Abdominal pain | 10 (4.1%) | 7 (2.8%)
Nausea | 9 (3.7%) | 5 (2%)
Vomiting | 8 (3.3%) | 4 (1.6%)
Vertigo | 7 (2.9%) | 2 (0.8%)

*details not provided in paper

Funding:

Comments: authors Hampel and Sommerauer associated with Bayer

## Siegert et al. 2003 ID 143

Stated Purpose of the Study: To compare the efficacy and safety of 7-day courses of faropenem daloxate (300 mg twice daily) and cefuroxime axetil (250 mg twice daily) in adult patients with acute bacterial sinusitis.

Population & Setting:

10/200–6/2001

561 patients in 43 centers: France, Germany, Greece, Israel, Lithuania, Spain and Sweden

Faropenem group (n=228) | mean age= 41.4 y/o | 90 males (39.5%)
Cefuroxime group (n=224) | mean age= 42.5 y/o | 103 males (46%)

Inclusion Criteria: ≥ 18 y/o; acute sinusitis based on at least purulent ant/post nasal d/c or nasal congestion, and at least 2 minor symptoms like frequent throat clearing, facial/malar tenderness or pressure, halitosis, ear discomfort or fever AND x-ray with air-fluid level, opacification or ≥ 6 mm mucosal thickening of at least one sinus

Exclusion Criteria: hx of hypersensitivity to study or related drug, chronic or recurrent sinusitis, received systemic abx > 24 hours within 7 days of enrollment; and others (see original paper)

Study Design: Prospective, multicenter, double-blind comparative study; randomly assigned 1:1 to one of two treatment groups using a block design computer-generated random code

Treatment: Faropenem daloxate 300 mg bid for 7 days

Cefuroxime Axetil 250 mg bid for 7 days

Outcome (Primary): Post-therapy (7 to 16 days after the end of Rx);

Clinical cure: disappearance of signs and symptoms or significant improvement and no further therapy required

Clinical Failure: no change, insufficient improvement or reappearance of Si/Sx's

Bacteriological Response: Cultures were collected pre and post Rx, eradication: causative organism was not present at the post Rx. If no sample was obtained in patient who improved, eradication was presumed

Results: 561 enrolled; 558 randomized;

Drop Outs: 51 in Faropenem group and 55 in Cefuroxime group were excluded (reasons include violation of time schedule for eval and concomitant intake of steroids)

228 in Faropenem and 224 in Cefuroxime were analyzed for clinical efficacy;

Clinical failure: 25/228 in Faropenem; 26/224 in Cefuroxime

Microbiological failure: Out of 136 patients with pathogenic organisms, most common organisms isolated at baseline were S. pneumoniae (64), H. influenzae (41), S. aureus (20) and M. catarrhalis (12).

Failure: 6/71 (8.5%) in the Faropenem group; 6/65 (9.2%) in the Cefuroxime group.

Adverse events: Faropenem, 46/274 (16.8%); cefuroxime, 49/273 (17.9%); most were in digestive and skin and appendages systems.

Drug related event: faropenem 26/274 (9.5%); cefuroxime 28/273 10.3%); 3 patients in cefuroxime group had abnormal liver function tests, 0 in faropenem group; 1 patient in faropenem group experienced a drug-related adverse event of severe intensity, i.e., the coagulation test increased. Treatment was discontinued as a result of an adverse event in 7 patients (2.6%) of the faropenem group and 2 patients (0.7%) who received cefuroxime.

Funding: Bayer

## Simon 1999 ID 475

Stated Purpose of the Study: To compare the effectiveness of 10, 15, and 20 days of ceftibuten therapy versus 14 days of erythromycin-sulfisoxazole therapy in treating acute sinusitis in childhood

Population & Setting: 200 patients from a single private practice in US were enrolled in the study. Enrollment period from 4/1996 to 7/1997.

Erythromycin-sulfisoxazole | 50 | age range = 8 mos to 11 years | males 58%
Ceftibuten 10 days | 50 | age range = 9 mos to 12 years | males 52%
Ceftibuten 15 days | 50 | age range = 6 mos to 17 years | males 44%
Ceftibuten 20 days | 50 | age range = 6 mos to 16 years | males 44%

Inclusion criteria: persistent purulent nasal drainage for at least 10 days plus day and nighttime cough

Exclusion criteria: none stated

Study design: randomized, single-blinded (patient's family), parallel study; method of randomization not stated

Treatments:

Erythromycin-sulfisoxazole (erythromycin component: 40 mg/kg/day) divided into 4 doses for 14 days

Ceftibuten 9mg/kg/day (maximum dose 400 mg/day) for 10 days

Ceftibuten 9mg/kg/day (maximum dose 400 mg/day) for 15 days

Ceftibuten 9mg/kg/day (maximum dose 400 mg/day) for 20 days

Outcome:

Primary: Effectiveness of the therapy was confirmed by the phone interview during the treatment course and confirmed by evaluation for clinical response 1 week after the treatment was completed. Success was determined by resolution of purulent nasal drainage and cough.

Failure constituted persistence of the manifestations or more intense symptoms during the treatment. Secondary: Children were followed up for recurrence 40–50days after treatment imitation.

Results: Reported failure rate, denominators not stated

Primary:
Erythromycin-sulfisoxazole | 4%
Ceftibuten 10 days | 8%
Ceftibuten 15 days | 8%
Ceftibuten 20 days | 0%
Secondary:
Erythromycin-sulfisoxazole | 10%
Ceftibuten 10 days | 12%
Ceftibuten 15 days | 8%
Ceftibuten 20 days | 8%

Adverse events: no information

Funding:

Comments: sinus films not obtained; no placebo comparison

## Stefansson et al. 1998 ID 97076

Stated Purpose of the Study: Phase IV study to compare the efficacy and safety of cefuroxime axetil and clairthromycin administered twice daily in the treatment of acute sinusitis.

Population & Setting: 370 patients with clinical dx of sinusitis from 22 centers in Czech Republic, Finland, Iceland, Israel, Jordan, Poland, South Africa & Sweden

185 in cefuroxime group | mean age = 36.5 yrs | males= 46%
185 in clarithromycin group | mean age = 37.2 yrs | males= 39%

Inclusion criteria: ≥ 18 y/o; clinical dx of sinusitis; initial onset of symptoms within 30 days of study entry; opacification and/or air fluid level in the maxillary sinus; 2 of the following symptoms: rhinorrhea, nasal congestion, facial pain

Exclusion criteria: received systemic abx within previous 7 days; a dx of chronic sinusitis (>30 days' duration) or received abx for recurrent sinusitis during the previous 30 days; received nasal steroid preparations or nasal washout; undergone or required sinus surgery; known hypersen- sitivity to cephalosporins or macrolides; reduced renal function or marked hepatic impairment; immune deficiency or participated in a clinical trial within 1 month prior to enrollment

Study design: randomized, double-blind, parallel-group, multicenter study; no further details provided

Treatments: Cefuroxime Axetil oral 250 mg twice a day for 10 days

Clarithromycin oral 250 mg twice a day for 10 days

Placebo twice daily (?)

Outcome: Primary - Cure defined by improved or resolved clinical signs and symptoms assessed 1–3 days after completion of treatment and absent at follow up 28–35 days post-treatment, confirmed by x-ray. Improvement defined by improvement but incomplete resolution of clinical signs and symptoms, confirmed by x-ray at follow up.

Secondary - follow-up 28–35 days post-treatment

Results: 370 patients were recruited; 185 randomized into each group; 357/370 (96%) had x-ray showing air fluid level and/or opacification. 22 from cefuroxime and 17 from clarithromycin group were discontinued. Principal reasons were failure to return (11 cefuroxime, 8 clairthromycin), lack of efficacy (7 in each group) and adverse events (2 clairthromycin). 24 excluded from clinically-evaluable population as a result of protocol violations

Calculated Clinical failure rate in ITT (100%-reported rate of cured or improved):

9% in cefuroxime group

7% in clarithromycin group

At follow up 28–35 days post treatment, relapse, failure or unevaluable:

32/185 in cefuroxime group

42/185 in clarithromycin group

Adverse events: 17/185 in cefuroxime and 18/185 in clarithromycin reported drug-related adverse event. These were mainly GI (13 cefuroxime and 8 clarithromycin). 3 clarithromycin had infection or inflammation of the reproductive tract. Serious adverse events recorded in clarithromycin group: maxillary antral abscess, convulsions and collapse during local anesthesia.

Funding:

Comments: x-ray results obtained after randomization (even though it is one of the inclusion criteria); overlapping definitions of “Cure” and “Improvement”; unclear why placebo is mentioned in the methods section; 39 patients were discontinued from the study but 354 patients had results reported (39+354=393>370 sample size)???

Authors Sedani & Staley associated with GlaxoWellcome Research & Development, UK.

## Sterkers 1997 ID 633

Stated Purpose of the Study: To compare the efficacy and tolerability of 8 days of ceftibuten 400 mg once a day, ceftibuten 200 mg twice a day, and amox/clav 500/125 mg three times a day in the treatment of acute sinusitis in adults

Population & Setting:

458 patients enrolled from 58 centers in France, study years not specified.
Ceftibuten 400 mg once a day | 152 | mean age 38.4 | males 32%
Ceftibuten 200 mg twice a day | 157 | mean age 41.8 | males 41%
Amox/clav 500/125 mg thrice a day | 149 | mean age 43.1 | males 44%

Inclusion criteria: sinusitis with purulent nasal discharge, confirmed by rhinoscopy; presence of fluid or opacification of the maxillary sinus on a plain radiograph

Exclusion criteria: age < 15 y/o; chronic sinusitis; abx treatment within 8 days of enrollment; allergy to beta lactam or lidocaine; renal insufficiency and others (see paper)

Study design: Multi-center, comparative, randomized, open-label, parallel-group design; method of randomization not stated

Treatments:

Ceftibuten 400 mg once a day for 8 days

Ceftibuten 200 mg twice a day for 8 days

Amox/clav 500/125 mg thrice a day for 8 days

Outcome:

Primary - clinical and radiological outcome 2 days after the end of treatment

Secondary - follow up on study day 40

Results:

Reported Clinical failure rate on day 10: | Ceftibuten 400 mg once a day | 23/134 (17.2%)
| Ceftibuten 200 mg twice a day | 18/138 (13%)
| Amox/clav 500/125 thrice a day | 14/128 (10.9%)
Reported Clinical failure rate on day 40: | Ceftibuten 400 mg once a day | 25/134 (18.7%)
| Ceftibuten 200 mg twice a day | 24/138 (17.4%)
| Amox/clav 500/125 thrice a day | 16/128 (12.5%)

Bacteriological Failure according to pathogen (Date of assessment not specified)

| Ceftibuten 400 once a day | 200 twice a day | Amox/Clav thrice a day
H. Flu | 2/19 (10.5%) | 4/33 (12.1%) | 2/26 (7.7%)
S. Pneumoniae | 6/23 (26.1%) | 2/23 (8.7%) | 4/25 (16%)
M. Catarrhalis | 2/7 (28.6%) | 1/5 (20%) | 1/10 (10%)

Adverse events:

| Ceftibuten 400 once a day | 200 twice a day | Amox/Clav thrice a day
At least 1 adverse event | 20/150 (13.3%) | 16/154 (10.4%) | 16/146(11%)
Drug related adverse event | 13/150 (8.7%) | 6/154 (3.9%) | 7/146 (4.8%)
GI adverse event | 17/150 (11.3%) | 11/154 (7.1%)) | 15/146 (10.3%)
# withdrawn 2° adverse | 3/150 (2%) | 4/154 (2.6%) | 5/146 (3.4%)

Funding:

Comments:

## Steurer & Schenk 2000 ID 417

Stated Purpose of the Study: To compare the efficacy and safety of cefdinir and amox/clav in patients with acute maxillary sinusitis.

Population & Setting: 569 (Intent-to-treat) patients in 16 medical centers in Europe participated

Cefdinir 600 mg once a day = 182 | Median age= 30 | Males= 58.8%
Cefdinir 300 mg twice a day = 198 | Median age= 32 | Males= 58.1%
Amox/Clav 500/125 thrice a day=189 | Median age= 29 | Males= 60.3%

Inclusion criteria: ≥13 y/o; males and non-lactating females unlikely to be pregnant during Rx; all patients had maxillary sinus aspirations

Exclusion criteria: subacute or chronic maxillary sinusitis (> 3 weeks); frontal and ethmoid sinusitis, diseases that precluded evaluation of response to study medication (i.e., chronic dental disease, foreign bodies, local traumas) and others (see paper)

Study design: Investigator-blinded, randomized, comparative, multicenter phase III study with 3 parallel treatment groups. For each study center an independent randomized schedule was prepared that was consistent with the planned ratio of 1:1:1 for the 3 treatment groups. Patients were given consecutive patient numbers after screening. Medication was dispensed by a third person; the patients were instructed not to reveal the type of medication to the investigator.

Treatments:

Cefdinir 600 mg once a day for 10 days

Cefdinir 300 mg twice a day for 10 days

Amoxicillin 500 mg/Clavulanate 125 mg three time a day for 10 days

Outcome:

Primary: Clinical cure based on professional opinion and microbiological response at test of cure visit on days 7–15 post therapy

Secondary: Long-term follow up on days 21–25 post therapy

Results:

Clinical failure (evaluable patients): | Cefdinir 600 mg once a day | 5/93 (5.4%)
| Cefdinir 300 mg twice a day | 10/96 (10.4%)
| Amox/Clav thrice a day | 4/106 (3.8%)
Microbiological failure (evaluable patients): | Cefdinir 600 mg once a day | 2/123 (1.6%)
| Cefdinir 300 mg twice a day | 13/131 (9.9%)
| Amox/Clav thrice a day | 10/138 (7.2%)
Long term follow up microbiological failure (evaluable patients): | Cefdinir 600 mg twice a day | 3/109 (2.8%)
| Cefdinir 300 mg twice a day | 11/103 (10.7%)
| Amox/Clav thrice a day | 6/116 (5.2%)

Adverse events:

Cefdinir once a day 75/181 (41%); Cefdinir twice a day 88/197 (45%); Amox/Clav 94/189 (50%) experienced at least one adverse event (see table 7 in paper). The most frequent adverse event is GI related. Diarrhea was the most common reason for discontinuation of treatment.

3 patients of the cefdinir OD group and 12 patients of the cefdinir BD and amox/clav groups discontinued treatment because of an adverse event.

Funding: Parke-Davis

Comments: This data reported previously in Gwaltney 1997 ID 648 article?

## Sydnor 1998 ID 590

REJECTED STUDIES: Adverse Events extraction only

Stated Purpose of the Study: Evaluate the efficacy and safety of levofloxacin in treating adult outpatients with acute bacterial sinusitis

Population and Setting: 329 patients at 24 centers in unknown countries over an unknown time period.

Diagnoses included in the study:

Acute, bacterial maxillary sinusitis

Treatment: Levofloxacin 500 mg QD × 10–21 days

Study Design: multicenter, noncomparative prospective study. Tablets were film coated possibly for masking purposes.

Adverse Events Included in Analyses: Safety evaluations were performed from the first dose of the study drug until the first post-therapy visit (2–5 days after completion of therapy or upon early withdrawal for subjects discontinuing the study). Evaluation included assessment of adverse events, results of laboratory tests, physical examination findings and vital sign measurements.

Funding: R W Johnson Pharmaceutical Research Institute

Comments: Use of intranasal or systemic corticosteroids was permitted and use of decongestants was encouraged.

Adverse Events: 29/329 (9%) subjects reported at least one adverse event considered to definitely or probably related to levofloxacin. Most adverse events were mild to moderate in severity.

Most common adverse events:

Symptom | % (N=329)
Diarrhea | 2.7%
Flatulence | 1.5%
Nausea | 1.2%

8 subjects (2.4%) reported serious adverse events were reported, two of which were considered related to levofloxacin administration (genital moniliasis and rash). 6 subjects (1.8%) discontinued the study due to adverse events (including rash, pruritus, edema, diarrhea, nausea and abdominal pain) all of which were considered related to levofloxacin administration. One subject had a myocardial infarction while on levofloxacin, although the episode was not considered related to study drug. There were no significant changes in lab tests, vital signs or physical exam findings.

## Varonen et al. 2003 ID 97080

Stated Purpose of Study: Compare the effects of antibiotics to that of placebo in clinically diagnosed acute maxillary sinusitis (AMS) in adults and to study whether sinus ultrasound would help to detect patients who would benefit from antibiotic therapy.

Population & Setting: 150 patients from 9 primary care centers in Finland were randomized. Study took place from 11/1998 to 10/1999. 148 analyzed (2/150 had missing data).

Antibiotic group (n=88) | Mean age= 40.6 yrs | Males= 24 (27%)
Placebo group (n=60) | Mean age= 38.1 yrs | Males= 20 (33%)

Inclusion Criteria: >18 y.o.; clinical diagnosis of acute maxillary sinusitis (minimum 3 symptoms and one sign; symptoms: nasal obstruction, discharge, headache, postnasal drip, cough, sinus pain, unilateral facial pain, maxillary toothache, hyposmia, anosmia, malaise and fever; signs: purulent secretion in nasal cavity, discharge in pharynx and tenderness in sinus tapping).

Exclusion Criteria: AMS symptoms > 30 days, abx the previous month, allergy to study meds, pregnancy or breast feeding, exacerbation of chronic sinusitis, previous paranasal sinus or sinus surgery, clinical suspicion of dental or frontal sinusitis or pan-sinusitis or suspicion of a severe complication.

Study Design: a double-blind, randomized (treatments were previously randomized in blocks of 20 consecutive patients at the Military Pharmacy in Helsinki and distributed in identical sealed bottles; the study medications were coded with six-number individual codes and physicians, patients and the main researcher remained blind until the recruitment ended), placebo-controlled multicenter trial.

Treatments: 4 treatment groups, all for 7 days: amoxicillin 750 mg ×2, penicillin V 1500 IU ×2, doxycline 100 mg ×2 or placebo ×2. Placebo group was doubled: 2/5 received placebo.

Outcome: (Primary) Recovery at the 2- week (after initial consultation) follow up by telephone survey of patients own reported symptoms. (Secondary) subjective symptom scores on days 3 and 10 in patient diaries, frequency of side effects, duration of sinusitis, use of additional meds and the frequency of chronic or recurrent sinusitis and number of physician consultations during the 1-year follow up.

Results:

Clinical Failure: 18/88 in antibiotic group; 19/59 in placebo (chi square 3.33, df=1, p=0.068)

Drop outs: Out of 60 in the placebo group, one was excluded for pregnancy, one was not reached by phone.

Other outcome: On day 3, the difference in symptom scores was 2.1 (p=0.048). Patients receiving abx recovered faster than those receiving placebo. By day 10, the difference had disappeared.

Adverse events:

Out of 82 in abx group (stomach pain 18 (22%), diarrhea 6 (7%), fatigue 5 (6%), rash 2 (2%), headache 3 (6%), vaginal discharge 3 (4%))

Out of 48 in placebo group (stomach pain 6 (12%), diarrhea 3 (6%), fatigue 3 (6%), headache 3 (4%).

Funding: Government and industry

Comments: subgroup data for each antibiotic was not reported

## Weis et al. 1998 ID 545

Stated Purpose of the study: To compare the efficacy and safety of 10-day oral regimens of ciprofloxacin and cefuroxime axetil in the treatment of clinical acute rhinosinusitis in adult in primary care settings

Population & Setting: 1414 patients were enrolled by 127 physicians in US between 2/17/98 and 5/29/98

Ciprofloxacin | 712 | mean age | 43.5 | Males 31.5%
Cefuroxime | 702 | mean age | 43.5 | males 34.3%

Inclusion criteria: ≥ 18 y/o; < 4 weeks duration of acute rhinosinusitis; at least 2 major or 1 major and 2 minor factors (Major: facial congestion/fullness, nasal drainage/purulence/discoloration, hyposmia/anosmia, facial pain/pressure, fever, nasal obstruction/blockage; Minor: headache, halitosis, fatigue, dental pain, cough, ear pain/pressure/fullness)

Exclusion criteria: hypersensitivity to carboxyquinolones or beta-lactam agents or anaphylaxis to PCN or its derivatives; hx of chronic sinusitis; pregnancy or lactation; baseline serum creatinine > 3 mg/dL; see paper for rest

Study design: open-label, prospective, randomized, nationwide, multicenter, outpatient comparative trial; randomly assigned to one of two treatment groups through the use of a block-design random code computer-generated at Bayer Corporation

Treatments:

Ciprofloxacin 500 mg tablet twice a day for 10 days

Cefuroxime 250 mg tablet twice a day for 10 days

Outcome: Primary efficacy: clinical response 4–16 days post therapy

Results: 1414 randomized; 1223 were efficacy valid; 1219 clinically evaluable

Clinical Failure rate (100% - reported clinical resolution rate):

Ciprofloxacin 54/613 (8.8%)

Cefuroxime 60/606 (9.9%)

Adverse events:

| Ciprofloxacin (n=711) | Cefuroxime (n=700)
Drug-related adverse event: | 80 (11.3) | 81 (11.6)
Nausea | 18 (2.5%) | 12 (1.7%)
Diarrhea | 7 (1.0%) | 14 (2.0%)
Headache | 4 (0.6%) | 7 (1.0%)
Vaginitis | 4 (0.6%) | 7 (1.0%)
Discontinuation 2° to adverse events | 27/712 (3.8%) | 26/702 (3.7%)

Funding: Bayer

Comments: