# Appendix B: Data Extraction Form

## Extraction Form

Name Year ID#

Stated Purpose of the Study:

Population & Setting:

X patients from? # of (ENT?, Primary care?) centers in ? country from ? study years.

Drug1 group (n=): | Mean age (range)= N yrs (J K) | Males= N (M%)
Drug2 group (n=): | Mean4 age (range)= N yrs (J K) | Males= N (M%)

Inclusion Criteria:

≥X y.o. in outpatient? setting with Si/Sx of acute sinusitis/acute exacerbation of chronic sinusitis (based on ?) of X duration AND radiologic signs (air-fluid levels?, opacification? or mucosal thickening≥6mm?)

Exclusion Criteria: ?

Study Design: Randomized (? method of randomization and concealment), double / not blinded (list method of masking), multi-center? trial. ? if pre-stratified by center.

Treatments: Drug 1 × mg D for × days

Drug 2 × mg D for Y days

Outcome: (Primary) End of study? (X weeks after enrollment)

(Secondary) End of therapy? (Y weeks after enrollment)

## Stated definitions of success and failure..

Results: ? enrolled and randomized. X/Y in Drug1group and A/B in Drug2 group were evaluated for clinical efficacy (intent to treat analysis / per protocol analysis). X/Y in Drug1 group and A/B in Drug2 group were excluded for reasons including: ?

1. Clinical Failure: (Primary) X/Y in Drug1 group and A/B in Drug2 group failed. (Secondary) X/Y in Drug1 group and A/B in Drug2 group failed.
2. Microbiological Failure: Most common pathogens isolated at baseline: A, B, C. Determined by sinus aspiration? at baseline and X weeks after treatment. X/Y in Drug1 group and A/B in Drug2 group failed.

Adverse Events: Adverse events occurred in X/Y in Drug1 group (nausea=#, diarrhea=#, other=#), and A/B in Drug2 goup (nausea=#, diarrhea=#, other=#). Discontinuation due to major adverse events occurred in X/Y in Drug1 group (symptoms causing d/c) and A/B in Drug2 group (symptoms).

Funding: ?

Comments: Use of adjuvant therapy? Compliance with study medications is?