# Appendix A: Search Strategies

## Ovid: Search from MEDLINE ®

<1966 to September Week 2 2004>

Sinusitis Update

# | Search History | Results
1 | rhinosinus$.tw. | 1103
2 | sinusitis.tw. | 6979
3 | exp Sinusitis/ | 9502
4 | or/1–3 | 11736
5 | (upper adj6 respirat$).tw. | 9698
6 | Infect$.tw. | 643403
7 | sinus$.tw. | 74358
8 | 6 and (5 or 7) | 9665
9 | 4 or 8 | 19042
10 | limit 9 to human | 17756
11 | limit 10 to english language | 12205
12 | In Vitro/ | 327623
13 | 11 not 12 | 12162
14 | 196$.yr. | 888556
15 | 197$.yr. | 2410634
16 | 198$.yr. | 3208775
17 | (1991$ or 1992$ or 1993$ or 1994$ or 1995$ or 1996$).yr. | 2480047
18 | 13 not (or/14–17) | 5737
19 | exp ANTIMICROBIAL CATIONIC PEPTIDES/ | 2756
20 | exp Anti-Infective Agents/ | 815121
21 | exp Anti-Bacterial Agents/ | 324676
22 | trimethoprim.mp. | 11682
23 | Amdinocillin.mp. | 523
24 | alamethicin.mp. | 490
25 | amikacin.mp. | 4730
26 | amphotericin.mp. | 12324
27 | ampicillin.mp. | 17897
28 | amoxicillin.mp. | 8189
29 | anisomycin.mp. | 1232
30 | ANTIMYCIN.mp. | 3401
31 | aurodox.mp. | 31
32 | azithromycin.mp. | 2513
33 | azlocillin.mp. | 724
34 | aztreonam.mp. | 1982
35 | bacitracin.mp. | 2443
36 | bambermycin$.mp. | 92
37 | Bongkrekic.mp. | 302
38 | brefeldin.mp. | 2693
39 | butirosin sulfate.mp. | 61
40 | calcimycin.mp. | 11117
41 | candicidin.mp. | 241
42 | capreomycin sulfate.mp. | 137
43 | carbenicillin.mp. | 2899
44 | carfecillin.mp. | 37
45 | cefaclor.mp. | 1398
46 | exp Cefadroxil/ | 394
47 | Cefadroxil.mp. | 529
48 | exp Cefamandole/ | 1907
49 | Cefamandole.mp. | 1544
50 | cefazolin.mp. | 2933
51 | cefixime.mp. | 883
52 | cefmenoxime.mp. | 480
53 | cefmetazole.mp. | 542
54 | cefonicid.mp. | 234
55 | cefoperazone.mp. | 1774
56 | cefotaxime.mp. | 6872
57 | cefotetan.mp. | 652
58 | cefotiam.mp. | 592
59 | cefoxitin.mp. | 2981
60 | cefsulodin.mp. | 554
61 | ceftazidime.mp. | 4564
62 | ceftizoxime.mp. | 1325
63 | ceftriaxone.mp. | 4735
64 | cefuroxime.mp. | 2722
65 | Cephacetrile.mp. | 156
66 | Cephalexin.mp. | 2489
67 | cephaloglycin.mp. | 119
68 | Cephaloridine.mp. | 1967
69 | exp Cephalosporins/ | 29060
70 | cephalothin.mp. | 3513
71 | Cephamycins.mp. | 1391
72 | cephapirin.mp. | 306
73 | cephradine.mp. | 721
74 | Chloramphenicol.mp. | 28895
75 | chlortetracycline.mp. | 2203
76 | citrinin.mp. | 318
77 | clarithromycin.mp. | 4329
78 | Clavulanic Acid$.mp. | 3306
79 | clindamycin.mp. | 5827
80 | Cloxacillin.mp. | 1869
81 | colistin.mp. | 1648
82 | cyclacillin.mp. | 103
83 | dactinomycin.mp. | 16697
84 | daptomycin.mp. | 286
85 | demeclocycline.mp. | 653
86 | dibekacin.mp. | 518
87 | dicloxacillin.mp. | 690
88 | dihydrostreptomycin sulfate.mp. | 639
89 | distamycins.mp. | 672
90 | doxycycline.mp. | 5949
91 | echinomycin.mp. | 178
92 | edeine.mp. | 116
93 | enviomycin.mp. | 69
94 | Erythromycin.mp. | 15895
95 | Erythromycin Estolate.mp. | 190
96 | Erythromycin Ethylsuccinate.mp. | 505
97 | filipin.mp. | 808
98 | floxacillin.mp. | 421
99 | fosfomycin.mp. | 1341
100 | framycetin.mp. | 268
101 | fusidic acid.mp. | 1464
102 | Gentamicin$.mp. | 18514
103 | gramicidin.mp. | 2713
104 | hygromycin b.mp. | 901
105 | imipenem.mp. | 4800
106 | josamycin.mp. | 550
107 | Kanamycin.mp. | 8823
108 | kitasamycin.mp. | 45
109 | exp Lactams/ | 78059
110 | Lactams.mp. | 7122
111 | lasalocid.mp. | 728
112 | Leucomycins.mp. | 1703
113 | Lincomycin.mp. | 2387
114 | lymecycline.mp. | 105
115 | mepartricin.mp. | 92
116 | methacycline.mp. | 360
117 | methicillin.mp. | 8925
118 | mezlocillin.mp. | 990
119 | mikamycin.mp. | 23
120 | minocycline.mp. | 2908
121 | miocamycin.mp. | 291
122 | moxalactam.mp. | 1455
123 | mupirocin.mp. | 679
124 | mycobacillin.mp. | 49
125 | nafcillin.mp. | 680
126 | natamycin.mp. | 502
127 | nebramycin.mp. | 101
128 | Neomycin.mp. | 8741
129 | netilmicin.mp. | 1578
130 | netropsin.mp. | 557
131 | nigericin.mp. | 1575
132 | nisin.mp. | 771
133 | novobiocin.mp. | 2049
134 | nystatin.mp. | 3316
135 | Oleandomycin.mp. | 794
136 | Oligomycins.mp. | 2565
137 | oxacillin.mp. | 2863
138 | oxytetracycline.mp. | 3880
139 | paromomycin.mp. | 979
140 | penicillanic acid.mp. | 1524
141 | penicillic acid.mp. | 153
142 | exp Penicillins/ | 48539
143 | penicillin.mp. | 29069
144 | piperacillin.mp. | 3081
145 | pivampicillin.mp. | 308
146 | polymyxin$.mp. | 5058
147 | pristinamycin.mp. | 291
148 | prodigiosin.mp. | 315
149 | ribostamycin.mp. | 131
150 | Rifabutin.mp. | 806
151 | rifamycin$.mp. | 1518
152 | ristocetin.mp. | 2162
153 | rolitetracycline.mp. | 262
154 | roxarsone.mp. | 78
155 | roxithromycin.mp. | 955
156 | rutamycin.mp. | 73
157 | sirolimus.mp. | 3153
158 | Sisomicin.mp. | 678
159 | spectinomycin.mp. | 1697
160 | spiramycin.mp. | 915
161 | exp Streptogramins/ | 1072
162 | Streptogramin$.mp. | 742
163 | Streptomycin.mp. | 13591
164 | Streptovaricin.mp. | 123
165 | sulbactam.mp. | 1677
166 | sulbenicillin.mp. | 165
167 | talampicillin.mp. | 103
168 | teicoplanin.mp. | 1915
169 | tetracycline.mp. | 22308
170 | thiamphenicol.mp. | 609
171 | thiostrepton.mp. | 311
172 | ticarcillin.mp. | 1650
173 | tobramycin.mp. | 4593
174 | troleandomycin.mp. | 648
175 | tunicamycin.mp. | 3618
176 | tylosin.mp. | 887
177 | tyrocidine.mp. | 170
178 | Tyrothricin.mp. | 507
179 | valinomycin.mp. | 3665
180 | vancomycin.mp. | 10205
181 | vernamycin.mp. | 19
182 | Virginiamycin.mp. | 1099
183 | cycloserine.mp. | 1546
184 | rifampin.mp. | 12623
185 | viomycin.mp. | 441
186 | Amoxicillin-Potassium Clavulanate Combination.mp. | 1184
187 | antitreponemal.mp. | 89
188 | ethambutol.mp. | 3654
189 | ethionamide.mp. | 989
190 | iproniazid.mp. | 938
191 | isoniazid.mp. | 11012
192 | prothionamide.mp. | 223
193 | pyrazinamide.mp. | 2312
194 | thioacetazone.mp. | 391
195 | p-aminosalicylic acid.mp. | 470
196 | Thalidomide.mp. | 3133
197 | Acedapsone.mp. | 42
198 | Clofazimine.mp. | 985
199 | Dapsone.mp. | 4057
200 | Ethionamide.mp. | 989
201 | Sulfameter.mp. | 50
202 | telithromycin.mp. | 366
203 | exp ciprofloxacin/ | 6711
204 | ciprofloxacin.mp. | 10454
205 | exp fluroquinolones/ | 0
206 | fluroquino$.mp. | 24
207 | Trimethoprim-Sulfamethoxazole.mp. | 6168
208 | or/19–207 | 873109
209 | 18 and 208 | 1391
210 | limit 209 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or guideline or interview or lectures or legal cases or legislation or letter or meta analysis or news or newspaper article or patient education handout or periodical index or practice guideline or “review” or review, academic or “review literature” or review, multicase or “review of reported cases” or review, tutorial) | 687
211 | 209 not 210 | 704
212 | from 211 keep 1 | 1

## Ovid MEDLINE(R)

<1966 to September Week 3 2004>

Pneumococcal Vaccine

# | Search History | Results
1 | exp vaccines/ | 97637
2 | vaccin$.mp. | 139243
3 | 1 or 2 | 142925
4 | exp Pneumonia/ | 46421
5 | pneumo$.tw. | 108436
6 | 4 or 5 | 126474
7 | 3 and 6 | 5881
8 | exp pneumococcal vaccines/ | 1599
9 | 7 or 8 | 6054
10 | limit 9 to human | 4797
11 | limit 10 to “all child (0 to 18 years)” | 2297
12 | 10 not 11 | 2500
13 | limit 12 to “all adult (19 plus years)” | 1220
14 | 10 not 13 | 3577
15 | limit 14 to english language | 3055
16 | limit 15 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or guideline or interview or lectures or legal cases or legislation or letter or meta analysis or news or newspaper article or patient education handout or periodical index or practice guideline or “review” or review, academic or “review literature” or review, multicase or “review of reported cases” or review, tutorial) | 1125
17 | 15 not 16 | 1930
18 | limit 17 to yr=1996-2004 | 1129
19 | exp ANTIMICROBIAL CATIONIC PEPTIDES/ | 2763
20 | exp Anti-Infective Agents/ | 815813
21 | exp Anti-Bacterial Agents/ | 324881
22 | trimethoprim.mp. | 11684
23 | Amdinocillin.mp. | 523
24 | alamethicin.mp. | 490
25 | amikacin.mp. | 4731
26 | amphotericin.mp. | 12332
27 | ampicillin.mp. | 17907
28 | amoxicillin.mp. | 8194
29 | anisomycin.mp. | 1232
30 | ANTIMYCIN.mp. | 3405
31 | aurodox.mp. | 31
32 | azithromycin.mp. | 2519
33 | azlocillin.mp. | 724
34 | aztreonam.mp. | 1982
35 | bacitracin.mp. | 2445
36 | bambermycin$.mp. | 92
37 | Bongkrekic.mp. | 302
38 | brefeldin.mp. | 2695
39 | butirosin sulfate.mp. | 61
40 | calcimycin.mp. | 11122
41 | candicidin.mp. | 242
42 | capreomycin sulfate.mp. | 137
43 | carbenicillin.mp. | 2899
44 | carfecillin.mp. | 37
45 | cefaclor.mp. | 1399
46 | exp Cefadroxil/ | 394
47 | Cefadroxil.mp. | 529
48 | exp Cefamandole/ | 1907
49 | Cefamandole.mp. | 1544
50 | cefazolin.mp. | 2933
51 | cefixime.mp. | 883
52 | cefmenoxime.mp. | 480
53 | cefmetazole.mp. | 542
54 | cefonicid.mp. | 234
55 | cefoperazone.mp. | 1774
56 | cefotaxime.mp. | 6872
57 | cefotetan.mp. | 652
58 | cefotiam.mp. | 592
59 | cefoxitin.mp. | 2981
60 | cefsulodin.mp. | 554
61 | ceftazidime.mp. | 4566
62 | ceftizoxime.mp. | 1325
63 | ceftriaxone.mp. | 4740
64 | cefuroxime.mp. | 2724
65 | Cephacetrile.mp. | 156
66 | Cephalexin.mp. | 2491
67 | cephaloglycin.mp. | 119
68 | Cephaloridine.mp. | 1967
69 | exp Cephalosporins/ | 29070
70 | cephalothin.mp. | 3513
71 | Cephamycins.mp. | 1391
72 | cephapirin.mp. | 306
73 | cephradine.mp. | 721
74 | Chloramphenicol.mp. | 28903
75 | chlortetracycline.mp. | 2204
76 | citrinin.mp. | 318
77 | clarithromycin.mp. | 4333
78 | Clavulanic Acid$.mp. | 3306
79 | clindamycin.mp. | 5828
80 | Cloxacillin.mp. | 1869
81 | colistin.mp. | 1648
82 | cyclacillin.mp. | 103
83 | dactinomycin.mp. | 16699
84 | daptomycin.mp. | 286
85 | demeclocycline.mp. | 653
86 | dibekacin.mp. | 518
87 | dicloxacillin.mp. | 690
88 | dihydrostreptomycin sulfate.mp. | 639
89 | distamycins.mp. | 672
90 | doxycycline.mp. | 5954
91 | echinomycin.mp. | 178
92 | edeine.mp. | 116
93 | enviomycin.mp. | 69
94 | Erythromycin.mp. | 15904
95 | Erythromycin Estolate.mp. | 190
96 | Erythromycin Ethylsuccinate.mp. | 505
97 | filipin.mp. | 809
98 | floxacillin.mp. | 421
99 | fosfomycin.mp. | 1341
100 | framycetin.mp. | 268
101 | fusidic acid.mp. | 1464
102 | Gentamicin$.mp. | 18524
103 | gramicidin.mp. | 2717
104 | hygromycin b.mp. | 901
105 | imipenem.mp. | 4800
106 | josamycin.mp. | 550
107 | Kanamycin.mp. | 8824
108 | kitasamycin.mp. | 45
109 | exp Lactams/ | 78094
110 | Lactams.mp. | 7130
111 | lasalocid.mp. | 729
112 | Leucomycins.mp. | 1703
113 | Lincomycin.mp. | 2388
114 | lymecycline.mp. | 106
115 | mepartricin.mp. | 92
116 | methacycline.mp. | 360
117 | methicillin.mp. | 8933
118 | mezlocillin.mp. | 990
119 | mikamycin.mp. | 23
120 | minocycline.mp. | 2908
121 | miocamycin.mp. | 291
122 | moxalactam.mp. | 1455
123 | mupirocin.mp. | 679
124 | mycobacillin.mp. | 49
125 | nafcillin.mp. | 680
126 | natamycin.mp. | 502
127 | nebramycin.mp. | 101
128 | Neomycin.mp. | 8747
129 | netilmicin.mp. | 1578
130 | netropsin.mp. | 558
131 | nigericin.mp. | 1575
132 | nisin.mp. | 771
133 | novobiocin.mp. | 2050
134 | nystatin.mp. | 3316
135 | Oleandomycin.mp. | 794
136 | Oligomycins.mp. | 2567
137 | oxacillin.mp. | 2864
138 | oxytetracycline.mp. | 3882
139 | paromomycin.mp. | 981
140 | penicillanic acid.mp. | 1526
141 | penicillic acid.mp. | 153
142 | exp Penicillins/ | 48564
143 | penicillin.mp. | 29083
144 | piperacillin.mp. | 3082
145 | pivampicillin.mp. | 308
146 | polymyxin$.mp. | 5059
147 | pristinamycin.mp. | 292
148 | prodigiosin.mp. | 316
149 | ribostamycin.mp. | 131
150 | Rifabutin.mp. | 807
151 | rifamycin$.mp. | 1519
152 | ristocetin.mp. | 2162
153 | rolitetracycline.mp. | 262
154 | roxarsone.mp. | 79
155 | roxithromycin.mp. | 956
156 | rutamycin.mp. | 73
157 | sirolimus.mp. | 3173
158 | Sisomicin.mp. | 678
159 | spectinomycin.mp. | 1697
160 | spiramycin.mp. | 915
161 | exp Streptogramins/ | 1074
162 | Streptogramin$.mp. | 742
163 | Streptomycin.mp. | 13593
164 | Streptovaricin.mp. | 123
165 | sulbactam.mp. | 1678
166 | sulbenicillin.mp. | 165
167 | talampicillin.mp. | 103
168 | teicoplanin.mp. | 1916
169 | tetracycline.mp. | 22315
170 | thiamphenicol.mp. | 609
171 | thiostrepton.mp. | 311
172 | ticarcillin.mp. | 1650
173 | tobramycin.mp. | 4594
174 | troleandomycin.mp. | 650
175 | tunicamycin.mp. | 3618
176 | tylosin.mp. | 889
177 | tyrocidine.mp. | 170
178 | Tyrothricin.mp. | 507
179 | valinomycin.mp. | 3666
180 | vancomycin.mp. | 10208
181 | vernamycin.mp. | 19
182 | Virginiamycin.mp. | 1101
183 | cycloserine.mp. | 1547
184 | rifampin.mp. | 12633
185 | viomycin.mp. | 441
186 | Amoxicillin-Potassium Clavulanate Combination.mp. | 1184
187 | antitreponemal.mp. | 89
188 | ethambutol.mp. | 3655
189 | ethionamide.mp. | 989
190 | iproniazid.mp. | 938
191 | isoniazid.mp. | 11017
192 | prothionamide.mp. | 223
193 | pyrazinamide.mp. | 2313
194 | thioacetazone.mp. | 391
195 | p-aminosalicylic acid.mp. | 471
196 | Thalidomide.mp. | 3140
197 | Acedapsone.mp. | 42
198 | Clofazimine.mp. | 987
199 | Dapsone.mp. | 4058
200 | Ethionamide.mp. | 989
201 | Sulfameter.mp. | 50
202 | telithromycin.mp. | 368
203 | exp ciprofloxacin/ | 6719
204 | ciprofloxacin.mp. | 10462
205 | exp fluroquinolones/ | 0
206 | fluroquino$.mp. | 24
207 | Trimethoprim-Sulfamethoxazole.mp. | 6169
208 | or/19–207 | 873848
209 | 18 and 208 | 273
210 | rhinosinus$.tw. | 1103
211 | sinusitis.tw. | 6984
212 | exp Sinusitis/ | 9506
213 | or/210–212 | 11742
214 | (upper adj6 respirat$).tw. | 9703
215 | Infect$.tw. | 644056
216 | sinus$.tw. | 74408
217 | 215 and (214 or 216) | 9675
218 | 213 or 217 | 19055
219 | limit 218 to human | 17767
220 | limit 219 to english language | 12215
221 | In Vitro/ | 327772
222 | 220 not 221 | 12172
223 | 196$.yr. | 888556
224 | 197$.yr. | 2410634
225 | 198$.yr. | 3208776
226 | (1991$ or 1992$ or 1993$ or 1994$ or 1995$ or 1996$).yr. | 2480055
227 | 222 not (or/223–226) | 5747
228 | exp ANTIMICROBIAL CATIONIC PEPTIDES/ | 2763
229 | exp Anti-Infective Agents/ | 815813
230 | exp Anti-Bacterial Agents/ | 324881
231 | trimethoprim.mp. | 11684
232 | Amdinocillin.mp. | 523
233 | alamethicin.mp. | 490
234 | amikacin.mp. | 4731
235 | amphotericin.mp. | 12332
236 | ampicillin.mp. | 17907
237 | amoxicillin.mp. | 8194
238 | anisomycin.mp. | 1232
239 | ANTIMYCIN.mp. | 3405
240 | aurodox.mp. | 31
241 | azithromycin.mp. | 2519
242 | azlocillin.mp. | 724
243 | aztreonam.mp. | 1982
244 | bacitracin.mp. | 2445
245 | bambermycin$.mp. | 92
246 | Bongkrekic.mp. | 302
247 | brefeldin.mp. | 2695
248 | butirosin sulfate.mp. | 61
249 | calcimycin.mp. | 11122
250 | candicidin.mp. | 242
251 | capreomycin sulfate.mp. | 137
252 | carbenicillin.mp. | 2899
253 | carfecillin.mp. | 37
254 | cefaclor.mp. | 1399
255 | exp Cefadroxil/ | 394
256 | Cefadroxil.mp. | 529
257 | exp Cefamandole/ | 1907
258 | Cefamandole.mp. | 1544
259 | cefazolin.mp. | 2933
260 | cefixime.mp. | 883
261 | cefmenoxime.mp. | 480
262 | cefmetazole.mp. | 542
263 | cefonicid.mp. | 234
264 | cefoperazone.mp. | 1774
265 | cefotaxime.mp. | 6872
266 | cefotetan.mp. | 652
267 | cefotiam.mp. | 592
268 | cefoxitin.mp. | 2981
269 | cefsulodin.mp. | 554
270 | ceftazidime.mp. | 4566
271 | ceftizoxime.mp. | 1325
272 | ceftriaxone.mp. | 4740
273 | cefuroxime.mp. | 2724
274 | Cephacetrile.mp. | 156
275 | Cephalexin.mp. | 2491
276 | cephaloglycin.mp. | 119
277 | Cephaloridine.mp. | 1967
278 | exp Cephalosporins/ | 29070
279 | cephalothin.mp. | 3513
280 | Cephamycins.mp. | 1391
281 | cephapirin.mp. | 306
282 | cephradine.mp. | 721
283 | Chloramphenicol.mp. | 28903
284 | chlortetracycline.mp. | 2204
285 | citrinin.mp. | 318
286 | clarithromycin.mp. | 4333
287 | Clavulanic Acid$.mp. | 3306
288 | clindamycin.mp. | 5828
289 | Cloxacillin.mp. | 1869
290 | colistin.mp. | 1648
291 | cyclacillin.mp. | 103
292 | dactinomycin.mp. | 16699
293 | daptomycin.mp. | 286
294 | demeclocycline.mp. | 653
295 | dibekacin.mp. | 518
296 | dicloxacillin.mp. | 690
297 | dihydrostreptomycin sulfate.mp. | 639
298 | distamycins.mp. | 672
299 | doxycycline.mp. | 5954
300 | echinomycin.mp. | 178
301 | edeine.mp. | 116
302 | enviomycin.mp. | 69
303 | Erythromycin.mp. | 15904
304 | Erythromycin Estolate.mp. | 190
305 | Erythromycin Ethylsuccinate.mp. | 505
306 | filipin.mp. | 809
307 | floxacillin.mp. | 421
308 | fosfomycin.mp. | 1341
309 | framycetin.mp. | 268
310 | fusidic acid.mp. | 1464
311 | Gentamicin$.mp. | 18524
312 | gramicidin.mp. | 2717
313 | hygromycin b.mp. | 901
314 | imipenem.mp. | 4800
315 | josamycin.mp. | 550
316 | Kanamycin.mp. | 8824
317 | kitasamycin.mp. | 45
318 | exp Lactams/ | 78094
319 | Lactams.mp. | 7130
320 | lasalocid.mp. | 729
321 | Leucomycins.mp. | 1703
322 | Lincomycin.mp. | 2388
323 | lymecycline.mp. | 106
324 | mepartricin.mp. | 92
325 | methacycline.mp. | 360
326 | methicillin.mp. | 8933
327 | mezlocillin.mp. | 990
328 | mikamycin.mp. | 23
329 | minocycline.mp. | 2908
330 | miocamycin.mp. | 291
331 | moxalactam.mp. | 1455
332 | mupirocin.mp. | 679
333 | mycobacillin.mp. | 49
334 | nafcillin.mp. | 680
335 | natamycin.mp. | 502
336 | nebramycin.mp. | 101
337 | Neomycin.mp. | 8747
338 | netilmicin.mp. | 1578
339 | netropsin.mp. | 558
340 | nigericin.mp. | 1575
341 | nisin.mp. | 771
342 | novobiocin.mp. | 2050
343 | nystatin.mp. | 3316
344 | Oleandomycin.mp. | 794
345 | Oligomycins.mp. | 2567
346 | oxacillin.mp. | 2864
347 | oxytetracycline.mp. | 3882
348 | paromomycin.mp. | 981
349 | penicillanic acid.mp. | 1526
350 | penicillic acid.mp. | 153
351 | exp Penicillins/ | 48564
352 | penicillin.mp. | 29083
353 | piperacillin.mp. | 3082
354 | pivampicillin.mp. | 308
355 | polymyxin$.mp. | 5059
356 | pristinamycin.mp. | 292
357 | prodigiosin.mp. | 316
358 | ribostamycin.mp. | 131
359 | Rifabutin.mp. | 807
360 | rifamycin$.mp. | 1519
361 | ristocetin.mp. | 2162
362 | rolitetracycline.mp. | 262
363 | roxarsone.mp. | 79
364 | roxithromycin.mp. | 956
365 | rutamycin.mp. | 73
366 | sirolimus.mp. | 3173
367 | Sisomicin.mp. | 678
368 | spectinomycin.mp. | 1697
369 | spiramycin.mp. | 915
370 | exp Streptogramins/ | 1074
371 | Streptogramin$.mp. | 742
372 | Streptomycin.mp. | 13593
373 | Streptovaricin.mp. | 123
374 | sulbactam.mp. | 1678
375 | sulbenicillin.mp. | 165
376 | talampicillin.mp. | 103
377 | teicoplanin.mp. | 1916
378 | tetracycline.mp. | 22315
379 | thiamphenicol.mp. | 609
380 | thiostrepton.mp. | 311
381 | ticarcillin.mp. | 1650
382 | tobramycin.mp. | 4594
383 | troleandomycin.mp. | 650
384 | tunicamycin.mp. | 3618
385 | tylosin.mp. | 889
386 | tyrocidine.mp. | 170
387 | Tyrothricin.mp. | 507
388 | valinomycin.mp. | 3666
389 | vancomycin.mp. | 10208
390 | vernamycin.mp. | 19
391 | Virginiamycin.mp. | 1101
392 | cycloserine.mp. | 1547
393 | rifampin.mp. | 12633
394 | viomycin.mp. | 441
395 | Amoxicillin-Potassium Clavulanate Combination.mp. | 1184
396 | antitreponemal.mp. | 89
397 | ethambutol.mp. | 3655
398 | ethionamide.mp. | 989
399 | iproniazid.mp. | 938
400 | isoniazid.mp. | 11017
401 | prothionamide.mp. | 223
402 | pyrazinamide.mp. | 2313
403 | thioacetazone.mp. | 391
404 | p-aminosalicylic acid.mp. | 471
405 | Thalidomide.mp. | 3140
406 | Acedapsone.mp. | 42
407 | Clofazimine.mp. | 987
408 | Dapsone.mp. | 4058
409 | Ethionamide.mp. | 989
410 | Sulfameter.mp. | 50
411 | telithromycin.mp. | 368
412 | exp ciprofloxacin/ | 6719
413 | ciprofloxacin.mp. | 10462
414 | exp fluroquinolones/ | 0
415 | fluroquino$.mp. | 24
416 | Trimethoprim-Sulfamethoxazole.mp. | 6169
417 | or/228–416 | 873848
418 | 227 and 417 | 1394
419 | limit 418 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or guideline or interview or lectures or legal cases or legislation or letter or meta analysis or news or newspaper article or patient education handout or periodical index or practice guideline or “review” or review, academic or “review literature” or review, multicase or “review of reported cases” or review, tutorial) | 689
420 | 418 not 419 | 705
421 | 209 not 420 | 262
422 | from 421 keep 1 | 1