# Appendixes

Appendix A: Search Strategies

Appendix B: Data Extraction Form

Appendix C: Evidence Tables

Appendix D: Peer Reviewers