# Summary Tables

- Table 1. Summary of Studies on the Prevalence of Depression During Hospitalization for Acute Myocardial Infarction (Question 1).
- Table 2. Summary of Studies on the Prevalence of Depression After Hospitalization for Acute Myocardial Infarction (Question 2).
- Table 3. Summary of Studies on Relation of Depression to Survival after Myocardial Infarction (Question 3).
- Table 4. Summary of Studies on the Relation of Depression to Cardiac Events after Myocardial Infarction (Question 3).
- Table 5. Summary of Studies on the Relation of Depression to Quality of Life after Myocardial Infarction (Question 3).
- Table 6. Summary of Studies on the Relation of Depression to Biomarkers after Myocardial Infarction (Question 3a).
- Table 7. Summary of Studies on Treatment of Post-Myocardial Infarction Depression (Question 4).
- Table 8. Summary of Studies on Methods of Screening for Depression in Myocardial Infarction Patients (Question 5).
- Table 9. Summary of Characteristics of Studies on the Relation of Depression to Use of Treatment after Hospitalization for Myocardial Infarction (Question 6).
- Table 10. Summary of Results of Studies on the Relation of Depression to Use of Treatment after Hospitalization for Myocardial Infarction (Question 6).

Table 1 Summary of Studies on the Prevalence of Depression During Hospitalization for Acute Myocardial Infarction (Question 1)

Study Author, Year | Study Design | Location | No. of Subjects | Mean Age | Male (%) | White (%) | HTN^a^(%) | DM^b^(%) | Smoking (%) | Lipid^c^(%) | Method & Time of Assessment of Depression | Prevalence (%)
Taylor, 1986 | RCT^d^ | USA | 173 | 52 | 100 | NR^e^ | NR | NR | NR | NR | HAMD^f^; 3 wk^g^ post-MI^h^ | 13
Bennett, 1988 | Pro cohort^i^ | Europe | 37 | 62 | 73 | NR | NR | NR | NR | NR | HADS^j^; In hospital^k^ | 13
Davis, 1988 | Pro cohort | Canada | 52 | 51 | 90 | NR | NR | NR | NR | NR | SCID^l^, and BDI^m^;In hospital^k^ | 6, 10
Carney, 1990 | Case control | USA | 70 | 53 | 76 | NR | 43 | 16 | 48 | NR | DIS^n^; In hospital | 23
Silverstone 1990 | Pro cohort | Europe | 100 | NR | NR | NR | NR | NR | NR | NR | Montgomery-Asberg; In hospital | 19
Gilutz, 1991 | Pro cohort | Europe; | Europe: 98; | NR^o^ | NR | NR | NR | NR | Europe: 32; | NR | Holland Sgroi Anxiety Depression Scale; | 31, 35
| | Middle East | Middle East: 87 | | | | | | Middle East: 35 | | In hospital, and 10–15 d^p^ post-MI
Schleifer, 1991 | Pro cohort | USA | 335 | 63 | 64 | NR | NR | NR | NR | NR | Nurse Interview; 8–10 d post-MI^k^ | 30, 17
Forrester, 1992 | Cross-sectional | USA | 129 | 59 | 74 | 62 | NR | NR | NR | NR | PSE^q^; In hospital within 10 d post-MI | 19
Legault, 1992 | Pro cohort | Canada | 52 | 55 | 78 | NR | NR | NR | NR | NR | BDI; In hospital^k^ | 18
Kaufmann, 1999 | Pro cohort | USA | 331 | NR^r^ | 66 | NR | 50 | 27 | 28 | 38 | DIS; In hospital 3–15 d post-MI | 27
O'Rourke, 1999 | Pro cohort | Europe | 70 | 58 | 74 | NR | NR | NR | NR | NR | HADS; 3 – 5 d post-MI | 17
Mayou, 2000 | Pro cohort | Europe | 344 | 63 | 73 | NR | NR | 34 | 58 | NR | HADS;In hospital, and within 3 d post-MI | 18, 8
Bush, 2001 | Pro cohort | USA | 267 | 65 | 58 | 82 | 43 | 33 | 27 | 59 | SCID, and BDI; In hospital within 2–5 d post-MI | 17, 20
Brink, 2002 | Pro cohort | Europe | 114 | 68 | 68 | NR | 35 | 15 | 31 | NR | HADS; In hospital, and within 1 wk post-MI | 11, 8
Lane, 2002 | Pro cohort | Europe | 288 | 63 | 75 | 93 | 39 | 13 | 43 | 72 | BDI; In hospital within 15 d post-MI^k^ | 31
Lesperance, 2002 | Pro cohort | Canada | 896 | 59 | 68 | NR | 35 | 16 | 47 | NR | BDI; In hospital^k^ | 32
Luutonen, 2002 | Pro cohort | Europe | 85 | 61 | 77 | NR | NR | NR | NR | NR | BDI; In hospital^k^ | 21
Watkins, 2002 | Cross-sectional | USA | 204 | 59 | 58 | 65 | NR | Non- depressed 31, Depressed 49 | Non- depressed 53, Depressed 81 | NR | DIS; In hospital 3–9 d post-MI | 18
Barefoot, 2003 | Pro cohort | USA | 196 | 61 | 63 | 67 | NR | NR | NR | NR | HAMD, and BDI; within 2 wk post-MI^k^ | 28, 37
Berkman, 2003 | RCT | USA | 9279^s^ | 63 | 61 | 26 | 60^t^ | 33^t^ | 64^t^ | 57^t^ | SCID; 2–4 wk post-MI | 27
Lauzon, 2003 | Pro cohort | Canada | 550 | 60 | 80 | 96 | 35 | 16 | 40 | 38 | BDI; Within 2 – 3 d of hospitalization^k^ | 35
Martin, 2003 | Pro cohort | Europe | 335 | 67 | 67 | NR | NR | NR | NR | NR | HADS; In hospital, and within 1 wk post-MI^k^ | 15, 6
Rafanelli, 2003 | Pro cohort | Europe | 61 | 61 | 85 | NR | NR | NR | NR | NR | SCID; Within 1 mo^u^ post-MI | Minor 10, Major 2
Strik,2003 | Pro cohort | Europe | 318 | 52 | 1 | NR | 28 | 9 | 54 | 20 | SCL-90; 1 mo post-MI | 47
Steeds,2004 | Pro cohort | Europe | 131 | NR | NR | NR | NR | NR | NR | NR | BDI-II; In hospital | 47

a Hypertension

b Diabetes mellitus

c Hyperlipidemia

d Randomized controlled trial

e Not reported

f Hamilton Rating Scale for Depression

g Week

h Myocardial infarction

i Prospective cohort study

j Hospital Anxiety and Depression Scale

k Also assessed at a later point. See Question 2

l Structured Clinical Interview for Diagnostic & Statistical Manual of Mental Disorders - IV

m Beck Depression Inventory

n Diagnostic Interview Schedule

o In the European population 21% were less than 45 years old, 54% were 46 – 55 years old and 25% were 56 – 60 years old. In the Middle Eastern population 30% were less than 45 years old, 46% were 46 – 55 years old and 24% were 56 – 60 years old

p Day

q Psychological Stress Evaluator

r 45% were less than 65 years old and 56% were greater than 65 years old

s Medically eligible and screened for depression

t Of those with depression or low social support

u Month

Table 2 Summary of Studies on the Prevalence of Depression After Hospitalization for Acute Myocardial Infarction (Question 2)

Study Author, Year | Study Design | Location | No. of Subjects | Mean Age | Male (%) | White (%) | HTN^a^(%) | DM^b^(%) | Smoking (%) | Lipid^c^(%) | Method & Time of Assessment of Depression | Prevalence
Trelawny, 1987 | NR^d^ | Europe | 32 | NR | 100 | NR | NR | NR | 71 | NR | Goldberg's CIS^e^; In hospital,
| | | | | | | | | | | 10 d^f^ post d/c^g^, | At 10 d: 20,
| | | | | | | | | | | 2 mo^h^ post d/c, | At 2 mo: 26,
| | | | | | | | | | | 6 mo post d/c | At 6 mo: 26
Davis, 1988 | Retro cohort^i^ | Canada | 52 | 51 | 90 | NR | NR | NR | NR | NR | BDI^j^;
| | | | | | | | | | | 6 – 8 wk^k^ post-MI^l^ | At 6 – 8 wk 10
Follick, 1988 | RCT^m^ | USA | 238 | 55 | 72 | NR | NR | NR | 53 | NR | SCL-90^n^;
| | | | | | | | | | | Baseline,
| | | | | | | | | | | 1 mo,
| | | | | | | | | | | 3 mo,
| | | | | | | | | | | 9 mo | At 9 mo: 10
Schleifer, 1991 | Retro cohort | USA | 335 | 64 | 64 | NR | NR | NR | NR | NR | RDC^o^ (Nurse Interview); | At 3 – 4 mo:
| | | | | | | | | | | 8–10 d, | Major^p^ 14,
| | | | | | | | | | | 3–4 mo | Minor^q^ 19
Legault, 1992 | Pro cohort^r^ | Canada | 52 | 55 | 78 | NR | NR | NR | NR | NR | BDI;
| | | | | | | | | | | In hospital,
| | | | | | | | | | | 3 mo post-MI, | At 3 mo: 7,
| | | | | | | | | | | 12 mo post-MI | At 12 mo: 9
Garcia, 1994 | Cross-sectional | Europe | 97 | 50 | 100 | NR | NR | NR | NR | NR | RDC; | Major 11,
| | | | | | | | | | | In hospital, | Minor 27
| | | | | | | | | | | 1 mo post-MI
Travella, 1994 | Pro cohort | USA | 70^s^ | 58 | 74 | NR | NR | NR | NR | NR | HAMD^t^, | At 3 mo:
| | | | | | | | | | | PSE; | Major 15,
| | | | | | | | | | | 3 mo post-MI, | Dysthymia 4 ;
| | | | | | | | | | | | At 6 mo: Major 21,
| | | | | | | | | | | 6 mo post-MI, | Dysthymia 3 ;
| | | | | | | | | | | | At 9 mo: Major 28,
| | | | | | | | | | | 9 mo post-MI, | Dysthymia 3;
| | | | | | | | | | | | At 12 mo: Major 16,
| | | | | | | | | | | 12 mo post-MI | Dysthymia 13
Clarke, 1996 | Pro cohort | Canada | 52 | NR | 100 | NR | NR | NR | NR | NR | ZDS^u^;
| | | | | | | | | | | 3 mo post-MI | At 3 mo: 24
Lesperance, 1996 | Pro cohort | Canada | 222 | 60 | 78 | NR | NR | NR | NR | NR | DIS^v^;
| | | | | | | | | | | 6 mo post-MI, | At 6 mo: 20,
| | | | | | | | | | | 12 mo post-MI | At 12 mo: 9
Bennett, 1998 | Pro cohort | Europe | 37 | 62 | 73 | NR | NR | NR | NR | NR | HADS^w^;
| | | | | | | | | | | In hospital,
| | | | | | | | | | | 3 mo post-MI | At 3 mo: 3
Lehto, 2000 | Retro cohort | Europe | 101 | 62 | 69 | NR | 28 | 15 | 12 | 63 | DEPS^x^;
| | | | | | | | | | | 20.5 mo (median) post-MI | 20.5 mo: 15.8 (median)
Strik, 2001 | Pro cohort | Europe | 206 | 60 | 76 | NR | NR | NR | NR | NR | SCID^z^, | At 1 mo
| | | | | | | | | | | HAMD, | Major 11
| | | | | | | | | | | SCL-90, | Minor 8
| | | | | | | | | | | BDI,
| | | | | | | | | | | HADS;
| | | | | | | | | | | 1 mo post-MI
Lane, 2002 | Pro cohort | Europe | 288^q^ | 63 | 75 | 93 | NR | NR | NR | NR | BDI;
| | | | | | | | | | | In hospital,
| | | | | | | | | | | 4 mo post-MI, | At 4 mo: 38
| | | | | | | | | | | 12 mo post-MI | At 12 mo: 37
Luutonen, 2002 | Pro cohort | Europe | 85 | 61 | 77 | NR | NR | NR | NR | NR | BDI;
| | | | | | | | | | | 6 mos, | At 6 mos: 30
| | | | | | | | | | | 18 mos | At 18 mos 34
Shiotani, 2002 | Pro cohort | Asia | 1042 | 64 | 80 | NR | 48 | 32 | 66 | 37 | ZDS; | Within first 3 mo: 42
| | | | | | | | | | | within 3 mo post-MI
Strik, 2002 | Retro cohort | Europe | 140 | 58 | 76 | NR | NR | NR | NR | NR | BDI, HADS, SCL-90 if any one positive assessment with SCID; | Major 11
| | | | | | | | | | | 3 mo post-MI | Minor 2
Aben, 2003 | Pro cohort | Europe | 200 | 60 | 77 | NR | NR | NR | NR | NR | BDI, HADS, SCL-90 if any one positive assessment with SCID and HAMD;
| | | | | | | | | | | 1 mo after MI, | At 1 mo: 14
| | | | | | | | | | | 3 mo after MI, | At 3 mo: 19
| | | | | | | | | | | 6 mo after MI, | At 6 mo: 21
| | | | | | | | | | | 9 mo after MI, | At 9 mo: 27
| | | | | | | | | | | 12 mo after MI | At < 1 yr^aa^: 28
Barefoot, 2003 | NR | USA | 196 | 61 | 63 | 67 | NR | NR | NR | NR | HAMD, BDI; | At 2 wks by HAM- D: 17;
| | | | | | | | | | | In hospital, | by BDI: 27
| | | | | | | | | | | 2 wk after first assessment hospitalization
Lauzon, 2003 | Pro cohort | Canada | 550 | 60 | 80 | 96 | 35 | 16 | 40 | 38 | BDI;
| | | | | | | | | | | In hospital,
| | | | | | | | | | | 1 mo post-MI, | At 1 mo: 39
| | | | | | | | | | | 6 mo post-MI, | At 6 mo: 39
| | | | | | | | | | | 12 mo post-MI | At 1 yr: 30
Martin, 2003 | Cross-sectional | Europe | 335 | 67 | 67 | NR | NR | NR | NR | NR | HADS;
| | | | | | | | | | | 6 wk post-MI, | At 6 wk: 5^o^
| | | | | | | | | | | 6 mo post-MI | At 6 mo: 5.4^o^
| | | | | | | | | | | | 6 wk: 13^p^
| | | | | | | | | | | | 6 mo: 10^p^
Strik, 2003 | Pro cohort | Europe | 318 | 52 | 1 | NR | 28 | 9 | 54 | 20 | SCL-90;
| | | | | | | | | | | 1 mo post-MI | At 1 mo: 47
Lesperance, 2004 | Pro cohort | Canada | 481 | 60 | 81 | NR | 66 | NR | 15 | NR | SCID;
| | | | | | | | | | | Approx. 2 mo post-MI | Approx 2 mo: 7

a Hypertension

b Diabetes mellitus

c Hyperlipidemia

d Sample of suspected myocardial infarction patients 28 of 32 confirmed

e Clinical Interview Schedule

f Day

g Discharge

h Month

i Retrospective cohort study

j Beck Depression Inventory

k Week

l Myocardial Infarction

m Randomized controlled trial

n Symptom Check List 90

o Research Diagnostic Criteria

p Major depression

q Minor depression

r Prospective cohort study

s With variable numbers at different time points

t Hamilton Rating Scale for Depression

u Zung Depression Scale

v Diagnostic Interview Schedule

w Hospital Anxiety and Depression Scale

x Depression scale

z Structured Clinical Interview for Diagnostic & Statistical Manual of Mental Disorders - IV

aa Year

Table 3 Summary of Studies on Relation of Depression to Survival after Myocardial Infarction (Question 3)

Study Author, Year | No. Enrolled | Depression Instrument | Outcome Reported | | | Stat^a^ | Dep vs Non Dep^b^ | Multivariate Comparison
| | | Cardiac Mortality | Total Mortality | Other
Ahern, 1990 | 265 | BDI^c^ profile of mood states | NA^d^ | NA | TM^e^ or cardiac arrest at baseline | RR^f^ | NR^g^ | 1.38 (CI^h^ 0.99 – 1.93)
Ladwig, 1991 | 560 | NR | Low: 0.9; Medium: 2.4; High: 7.5 | NA | Sustained VT^i^ admission | OR^j^ | Mantel-Haenszel p<0.001 | 2.8 low/med depression, 4.9 low/high depression p=0.07
Frasure-Smith, 1993 | 222 | MIMH DIS^k^ | NA | At 6 mos^l^ | NA | HR^m^ | 5.74 | 4.29 (CI 3.14 – 5.44)
Frasure-Smith, 1999 | 904 | BDI | NA | NA | Arrhythmia; MI recurrence; Revascularization Any hard event | OR | CV^n^ death 3.23 (CI 1.65 – 6.33); | 3.66 (CI 1.68 – 7.99)
| | | | | | | Arrhythmia 3.11 (CI 1.32 – 7.37);
| | | | | | | MI recurrence 1.62 (CI 0.93 – 2.8);
| | | | | | | Revascularization 0.82 (CI 0.53 – 1.26);
| | | | | | | Any hard events 1.97 (CI 1.25 – 3.13)
Irvine, 1999 | 703 | BDI | Sudden cardiac death | NA | NA | HR | AMI^o^ 0.52 (CI 0.15 – 1.76) | NR
Denollet, 2000 | 319 | ZDS^p^ | Cardiac events | NA | QOL^q^ poor perceived health at 5 yrs^r^, Depressive effect | OR | NR | 1.31 (CI 0.53 – 3.24)
Lane, 2000 | 288 | BDI | Dep 9%, NonDep 0.7% | Dep 10.1%, NonDep 8% | Dartmouth chart | OR | NR | NR
Welin, 2000 | 275 | ZDS | 17% | 24% | Non-fatal recurrent MI; Stroke; Cancer | HR | TM: 2.45 (CI 1.49 – 4.02), | TM 1.75 (CI 1.02 – 2.99),
| | | | | | | CM^s^3.54 (CI 1.85 – 6.79) | CM 3.16 (CI 1.38 – 7.25)
Bush, 2001 | 285 | SCID^t^ BDI | NA | Dep: 13%, NonDep: 3.8% | NA | RR | 3.8 p=0.008 | 3.5 p=0.001
Druss, 2001 | 88241 | NR | NA | NA | NA | HR | Mental 1.19 (CI 1.04 – 1.36), | NR
| | | | | | | Affective 1.11 (CI 1.03 – 1.18)
Lane, 2001 | 288 | BDI | 10% | 10% | QOL | OR | CM 1.15 (CI 0.49 – 2.69) | NR
Lane, 2002 | 288 | BDI | Dep: 10% | NA | NA | OR | TM 1.04 (CI 0.5 – 2.16), | NR
| | | | | | | CM 0.84 (CI 0.37 – 1.90)
Lesperance, 2002 | 896 | BDI | < 5 yrs: 7.2%; | < 5 yr: 10.7%; | NA | HR | BDI 5 – 9: 1.94 (CI 1.16 – 3.25); | TM
| | | 5 – 9 yr: 13.7%; | 5 – 9 yr: 16.2%; | | | BDI 10 – 18: 2.8 (CI 1.68 – 4.66); | BDI 10 – 18: 2.35 (CI 1.53 – 3.61)
| | | 10–18 yr: 18.5%; | 10–18 yr: 23.2%; | | | BDI > 19: 1.32 (CI 2.4 – 7.75) | BDI ≥ 19 (CI 2.16 – 5.92) TM
| | | > 19 yr: 26.6% | > 19 yr: 32.9% | | | | BDI 10 – 18: 3.17 (CI 1.79 – 5.6)
| | | | | | | | BDI ≥ 19: 3.13 (CI 1.56 – 6.27)
Carney, 2003 | NR | Depression interview: structured HAMD^u^, BDI | NA | Non-fatal AMI | NA | HR | TM 2.4 (CI 1.2 – 4.7) | TM 2.4 (CI 1.2 – 4.7)
| | | | | | | Non-fatal AMI 1.2 (CI 0.7 – 2.0) | Non-fatal AMI 1.2 (CI 0.7 – 2.0)
Frasure-Smith, 2003 | NR | NR | At 5 yr | NA | NA | HR | NR | 1.44 (CI 91.17-1.78)

a Comparison statistic

b Depressed versus non-depressed

c Beck Depression Inventory

d Not applicable

e Total mortality

f Relative risk

g Not reported

h Confidence Interval

i Ventricular tachycardia

j Odds Ratio

k National Institute of Mental Health Diagnostic Interview Schedule

l Month

m Hazard ratio

n Cardiovascular

o Acute myocardial infarction

p Zung Depression Scale

q Quality of life

r Year

s Cardiac Mortality

t Structured Clinical Interview for DSM-IV

u Hamilton Rating Scale for Depression

Table 4 Summary of Studies on the Relation of Depression to Cardiac Events after Myocardial Infarction (Question 3)

Study Author, Year | No Enrolled | Depression Instrument | Outcome | | | Stat^a^ | Dep vs. Non-Dep^b^ | Multivariate Comparison
| | | Cardiac Events | Cardiac Mortality | Other
Irvine, 1999 | 703 | Psychological questionnaire | NR^c^ | Sudden cardiac death 34, | Vascular death 1, | RR^d^ | NR^e^ | Amiodarone group:
| | | | Other cardiac death 16 | Non-cardiac death 12 | | | BDI^f^ somatic score 1.10 (CI 0.93,1.29);
| | | | | | | | BDI cognitive-affective score 0.73 (CI 0.52,1.01);
| | | | | | | | Placebo Group:
| | | | | | | | BDI somatic score 1.00 (CI 0.88,1.13);
| | | | | | | | BDI cognitive-affective score 1.09 (CI 0.99,1.89)
Frasure-Smith, 2000 | 222 | Structured baseline interview | Recurrent cardiac events^g^ | NA^h^ | NA | OR^i^ | Any cardiac event: 3.32 (CI 1.69,6.53); | Recurrent cardiac events 1.99 (CI 0.92,4.31)
| | | | | | | ACS^j^: 2.75 (CI 1.32,5.72);
| | | | | | | Arrhythmic event: 3.65 (CI 0.99,10.47)
Druss, 2000 | NR | ICD-9CM | NA | TM at 1 mo^k^ | Likelihood of PTCA^l^ or CABG^m^ during index hospitalization | OR | TM^n^: | TM 0.63 ( p=0.2) in patients with affective disorders;
| | | | | | | Affective disorders 7.3%; | Use of PTCA and CABG in patients with affective disorders:
| | | | | | | No mental disorders 10.8% | PTCA: 0.51
| | | | | | | | CABG : 0.63
Shiotani, 2002 | 1086 | ZDS^o^ | Annual cardiac event rate: Dep 31%, Non-dep 24%; | CM^p^: Dep 4, Non-dep 1 | Readmission: Dep: 34, Non-dep: 26 | OR | Cardiac events: 1.46 (CI^q^ 1.11 – 1.92) | Cardiac events: 1.41 (CI 1.04 – 1.92)
| | | Cardiac events: Dep 138, Non-dep 145;
| | | MI: Dep 19, Non-dep 15;
| | | Arrhythmias: Dep 2, Non-dep 1;
| | | RePTCA: Dep 94, Non-dep 110;
| | | Heart Failure: Dep 7, Non-dep 5;
| | | Angina: Dep 6, Non-dep 5
Strik, 2003 | 318 | SCL-90^r^ | Non-fatal MI at 3–4 yrs^s^ | Fatal MI at 3 – 4 yrs | Consumption at 3–4yrs^t^ | HR^u^ OR^v^ | Consumption^x^: 1.61 (CI 1.00 – 2.57)^w^ | MI:CI 2.32 (CI 1.04 – 5.18);
| | | | | | | | Consumption: 1.55 (CI 0.96 – 2.52)
Strik, 2004 | 422 | Baseline: SCID; Follow-up: 3 psychiatric self rating scales BDI, SCL-90, HADS^aa^ | Major cardiac events 1 mo – 3 yrs^y^; | NR | Consumption 1 mo – 3 yrs | HR^ab^ | Cardiac events: 1.1(0.36,3.42); | Cardiac Events: 0.88 (CI 0.26,2.93);
| | | Increased consumption | | | OR^ac^ | Consumption: 1.66 (CI 0.90 – 3.07) | Consumption: 1.98 (CI 1.0 – 3.93)

a Comparison statistic

b Depressed versus non depressed

c Not reported

d Risk ratio

e Depression reported not to be significant predictor of sudden cardiac death in univariate analysis

f Beck Depression Inventory

g Survived and nonsurvived reinfarctions, admission for unstable angina, arrhythmic deaths, survived cardiac arrests

h Not applicable

i Odds ratio

j Acute coronary syndrome

k Month

l Percutaneous transluminal coronary angioplasty

m Coronary artery bypass graft

n Total mortality

o Zung Depression Scale

p Cardiac mortality

q Confidence interval

r Symptom Checklist - 90

s Years

t Cardiac rehospitalization and/or frequent visits

u Cardiac events

v Health care consumption

w Confidence intervals not reported as single variables

x Heath care consumption

y Death or recurrent myocardial infarction

z > 6 visits at cardiac outpatient clinic during follow-up

aa Hospital Anxiety and Depression Scale

ab Depression as predictor of major cardiac event

ac Depression as predictor of health care

Table 5 Summary of Studies on the Relation of Depression to Quality of Life after Myocardial Infarction (Question 3)

Study Author, Year | No. Enrolled | Depression Instrument | Outcome | | Stat^b^ | Dep vs. Non Dep^c^ | Multivariate Comparison
| | | QOL^a^ | Other
Travella, 1994 | 129 | Present state examination - modified,HAMD^d^ | Johns Hopkins functioning inventory, Social functioning exam | NA^e^ | Multivariate Rank | NR^f^ | Social functioning exam with depression at
| | | | | | | baseline f=1.85 p=0.17;
| | | | | | | 3 mos^g^ f=7.73 p=0.1;
| | | | | | | 6 mos f=4.38 p=0.45;
| | | | | | | 9 mos f=13.45 p=0.001;
| | | | | | | 12 mos f=7.94 p=09
Drory, 1998 | 276 | BDI^h^ | Frequency of sexual activity after MI^i^ at 3 – 6 mos, | Depression | Pearson Correlation | Frequency of sexual activity 0.16 (p<0.01); | Frequency of sexual activity: 0.14 (p<0.01);
| | | Satisfaction with sexual activity after MI | | | Satisfaction with sexual activity 0.14 (p<0.01) | Satisfaction with sexual activity: 0.15 (p<0.01))
Irvine, 1999 | 703 | BDI symptom checklist | Social perception and help, daily living | Sudden cardiac death | Cox^j^ | OR^k^ | NR
Ladwig, 1999 | 552 | D-S | NA | Perception of angina pectoris | OR | NR | 2.98 (CI^l^ 1.50 – 5.90)
O'Rourke, 1999 | 70 | HADS^m^ | Illness perception questionaire | NA | Regression ANOVA | NR | NR
Soejima, 1999 | 134 | Depression Index | RTW ^m^ | NA | Logistic regression OR | NR | RTW Extroversion: 3.72 (CI 1.33 – 10.4)
| | | | | | | Depressive sx ^o^ in hospital 0.15 (CI 0.02 – 0.87)
Bogg, 2000 | 220 | HADS (II) Global Mood Scale | QOL after MI measure | NA | Regression | NR | Physical QOL male R^2^ =46, Physical QOL female R^2^ =27, Baseline anxiety R^2^ =54
Denollet, 2000 | 322 | ZDS p | Global Mood Scale, Health complaint scale | NA | Regression OR | NR | Failure to quit smoking 2.3 (CI 1.2 – 4.5);
| | | | | | | Depressive s/x 3.3 (CI 1.9 – 5.8);
| | | | | | | Type D personality 2.2 (CI 1.2 – 3.8);
| | | | | | | EF^q^ < 50% 2.0 (CI 1.0 – 3.9);
| | | | | | | Hyperlipidemia 2.0 (CI 1.1 – 3.4)
Lane, 2000 | 288 | BDI | Dartmouth COOP^r^ Charts, BDI | NA | Correlation score | Gender r=0.31, Partner status r=0.24, | BDI R^2^ 0.11 p=0.0001, Partner status 0.05 p=0.002, Peel Index 0.05 p=0.001, State anxiety 0.02
| | | | | | Living alone r=0.20,
| | | | | | Employment status r=0.18,
| | | | | | Frequency of exercise r= -0.21,
| | | | | | Duration of exercise r= -0.17
| | | | | | BDI r=0.37,
| | | | | | State anxiety r=0.28,
| | | | | | Treat anxiety r=0.32,
| | | | | | Peel Index r=0.27,
| | | | | | LOS^s^ r=0.15
Mayou, 2000 | 344 | HADS | SF-36 Score^t^ | NA | HR | At baseline: | NR
| | | | | | 51.2 (distressed),
| | | | | | 67.5 (non-distressed)
| | | | | | p < 0.05;
| | | | | | At 3 mos:
| | | | | | 38.7 (distressed),
| | | | | | 62.3 (non-distressed)
| | | | | | p < 0.05;
| | | | | | At 12 mos:
| | | | | | 47.2 (distressed),
| | | | | | 64.0 (non-distressed)
| | | | | | p < 0.05
Lane, 2001 | 288 | BDI | NR | NA | Regression Correlation | Gender r=0.2, | BDI 0.11,
| | | | | | Partner status r=0.22, | Living alone 0.07,
| | | | | | Living alone r=0.3, | Peel Index 0.07,
| | | | | | Employment status r=0.18, | State anxiety 0.03
| | | | | | Frequency of exercise r= -0.18,
| | | | | | BDI r=0.32,
| | | | | | State anxiety r=0.28,
| | | | | | Treat anxiety r=0.24,
| | | | | | Peel Index r=0.29,
| | | | | | Killip class r=0.15,
| | | | | | LOS r=0.25
Brink, 2002 | 134 | HADS | Physical Component SF-36, | NA | Zero order correlation | NR | Physical Component: 0.47**;
| | | Mental Component SF-36 | | | | Mental Component: 0.66**
Drory, 2002 | NR | BDI | Perceived health status | NA | Hierarchical regression | NR | Psychological well being
Drory, 2003 | NR | BDI | Perceived health status | NA | Regression | NR | NR

a Quality of life

b Comparison statistic

c Depressed versus non-depressed

d Hamilton Rating Scale for Depression

e Not applicable

f Not reported

g Month

h Beck Depression Inventory

i Myocardial infarction

j Cox regression

k Odds ratio

l Hospital Anxiety and Depression Scale

m Confidence interval

n Return to work

o Symptoms

p Zung Depression Scale

q Ejection fraction

r Charts for Primary Care Practices

s Length of stay

t Medical Outcomes Study Short Form 36 Health Survey

Table 6 Summary of Studies on the Relation of Depression to Biomarkers after Myocardial Infarction (Question 3a)

Study Author, Year | No. Enrolled | Depression Instrument | Outcome | Stat^a^ | Depressed vs Non-Depressed | Multivariate Comparison
| | | Biomarkers
Carney, 2001 | Dep^b^ 380 NonDep^c^ 424 | Screening: ENRICHD^d^ modified DSM-IV^e^ DISH^f^ present depressive episode BDI^g^ severity of depression | In univariate analysis all 4 indices of 24 hour HRV^h^ were significantly lower in patients with depression. | Linear regression | NR^i^ | NR
| | | In multivariate analysis all 3 indices except 24 hour HRV were significantly lower in patients with depression.
Kuijpers, 2002 | NR | DSM-IV | PF4^j^ was significantly higher in Dep post-MI patients compared to NonDep post-MI patients, p=0.021. | Mann-Whitney U | PF4 mean rank 15.75 IU/ml vs. 9.25 IU/ml | NR
| | | There was a trend toward a significantly increased B-TG^k^ level with p=0.08, inspite of use of aspirin | | B-TG mean rank 15.04 IU/ml vs. 9.96 IU/ml
Lesperance, 2004 | 965 | SCID^l^ | Dep patients had significantly higher sICAM 1 levels even after adjustment for confounders.These results were only slightly attenuated by adjustment for antidepressant treatment. | Linear regression | NR | sICAM
| | | No significant association between depression and IL6^n^. | | | 0.095+/-0.044 (with Dep)
| | | Uncertain about the relationship of CRP^o^ on depression as patients were on statins. | | | 0.086+/-0.045 (with antidepressant added to the model)

a Comparison statistic

b Depressed

c Non-depressed

d Enhancing Recovery in Coronary Heart Disease Trial

e Diagnostic & Statistical Manual of Mental Disorders

f Depression Interview and Structured Hamilton

g Beck Depression Inventory

h Heart rate variability

i Not reported

j Platelet factor 4

k β-thromboglobulin

l Structured Clinical Interview for Diagnostic & Statistical Manual of Mental Disorders-IV

m Soluble intracellular adhesion molecule 1

n Interleukin 6

o C-reactive protein

Table 7 Summary of Studies on Treatment of Post-Myocardial Infarction Depression (Question 4)

Study Author, Year | Study Design | Intervention Description | Duration of Intervention; Duration of Follow-Up | Depression Scores | Cumulative Cardiac Events | Other Outcomes
Dracup, 1991 | Pro cohort^a^ | Group A: Cardiac rehabilitation program; Group B: No participation in a formal program | 12 wks^b^; 8 mos^c^ | Multiple Affective Adjective Checklist @ 6 mos | NA | Multiple Affective Adjective Checklist - Anxiety score
| | | | Group A: 8, Group B: 13 | | Group A: baseline 7, 6 mos 5; Group B: baseline 7, 6 mos 6;
| | | | | | Psychosocial Adjustment to Illness Score
| | | | | | Group A: baseline 42, 6 mos 36; Group B: baseline 44; 6 mos 42;
| | | | | | Marital Adjustment Score
| | | | | | Group A: baseline 115, 6 mos 121; Group B: baseline 114; 6 mos 111
Brown, 1993 | RCT^d^ | Group C: Cognitive behavioral therapy; Group D: Control | 12 weekly 1 hour sessions; 3, 9, 15 mos | SCL 90-R^e^ | NA | NA
| | | | Group C: pre 65.1, 3 mos 62.1, 15 mos 56.1; Group D: pre 71.2, 3 mos 62.3, 15 mos 63.3;
| | | | BDI^f^
| | | | Group C: pre 12.1, 3 mos 6.9, 15 mos 5.6; Group D: pre 17.3, 3 mos 9.4, 15 mos 10.5;
| | | | MMPI-168^g^
| | | | Group C: pre 74.1, 3 mos 68.1, 15 mos 67.5; Group D: pre 79.2, 3 mos 72.8, 15 mos 77.4
Crowe, 1996 | RCT | NR | NR; 1 yr^h^ | BDI | NA | NA
| | | | Group E: 3 d 4.1, 3 mos 3.3, 6 mos 2.6, 14 mos 3.2 Group F: 3 d 3.9, 3 mos 3.7; 6 mos 3.3, 14 mos 2.9
Frasure-Smith, 1997 | RCT | Group G: Intervention involved combination of emotional support, reassurance, education, practical advice, and referral health resources; Group H: Usual care | 1 yr; 12 mos | BDI | Cardiac mortality | Total mortality
| | | | Group G: baseline 8.1, 12 mos 6.9; Group H: baseline 8.4, 12 mos 7.6 | Group G: 4.8%; Group H: 3.4%; | Group G: 5.5%, Group H: 3.9%
| | | | | Myocardial infarction
| | | | | Group G: 4.8%; Group H: 5%;
| | | | | Revascularization
| | | | | Group G: 13.4%; Group H: 14%
Taylor, 1997 | RCT | Group I: Nurse managed, home based system for coronary risk factor modification and stress management; Group J: Usual medical care | 1 yr; Upto 1 yr | Low levels depressed mood | Mortality | Low levels anxious mood
| | | | Group I: baseline 1.7, 12 mos 1.3; | Group I: 4%; Group J: 3% | Group I: baseline 1.9, 12 mos 1.4; Group J: baseline 1.5, 12 mos 1.5;
| | | | Group J: baseline 1.8, 12 mos 1.2; | | Moderate-high levels anxious mood
| | | | Moderate-high levels depressed mood | | Group I: baseline 6.1, 12 mos 2.6; Group J: baseline 5.9, 12 mos 2.7;
| | | | Group I: baseline 6.1, 12 mos 1.4; Group J: baseline 5.7, 12 mos 1.5 | | Low levels stress
| | | | | | Group I: baseline 2.0, 12 mos 1.7; Group J: baseline 2.0; 12 mos 1.8;
| | | | | | Moderate-high levels stress
| | | | | | Group I: baseline 6.4, 12 mos 2.8; Group J: baseline 6.7, 12 mos 3.7;
| | | | | | Low anger frequency
| | | | | | Group I: baseline 2.8, 12 mos 2.2; Group J: baseline 2.6, 12 mos 2.2;
| | | | | | Moderate-high anger frequency
| | | | | | Group I: baseline 5.6, 12 mos 3.1; Group J: baseline 5.6, 12 mos 3.0
Roose, 1998 | RCT | Group K: Paroxetine 10 20 mg/day; Group L: Nortriptyline 25 mg/day | 2 wks; 6 wks | NA | Heart rate | NA
| | | | | Group K: baseline 10%, 6 wks 6%; Group L: baseline 11%, 6 wks 7%;
| | | | | Standing pulse rate standing
| | | | | Group K: baseline 11%, 6 wks 11%; Group L: baseline 14%, 6 wks 16%;
| | | | | Supine pulse rate supine
| | | | | Group K: baseline 10%, 6 wks 10%; Group L: baseline 12%, 6 wks 14%;
| | | | | HRV SDNN^i^
| | | | | Group K: baseline 37%, 6 wks 27; Group L: baseline 19%, 6 wks 16%;
| | | | | HRV pNN50^j^
| | | | | Group K: baseline 10%, 6 wks 4%; Group L: baseline 9%, 6 wks 7%
Johnston, 1999 | RCT | Group M: Extended program involving additional sessions in the 2 mos after discharge; Group N: Inpatient cardiac rehabilitation program; Group O: Control | 6 wks; Up to 1 yr | HADS^k^ | NA | HADS Anxiety Score
| | | | Group M: baseline 4.1, 12 mos 3; Group N: baseline 4.4, 12 mos 3.6; Group O: baseline 4.6, 12 mos 5.8 | | Group M: 1 mo 4.8, 12 mos 3; Group N: 1 mo 5, 12 mos 4.5; Group O: 1 mo 5; 12 mos 6
Strik, 2000 | RCT | Group P: Fluoxetine 20 mg/day; Group Q: Placebo | Up to 25 wks; 1, 3, 6, 9 wks then monthly untill 1 yr | HAMD^l^ change @ 25 wks | Chest pain | GI^m^ complaints
| | | | Group P: -9.65(7.2), Group Q: -6.9(6.9) | Group P: 5; Group Q: 4 | Group P: 8, Group Q: 6;
| | | | | | Agitation
| | | | | | Group P: 6, Group Q: 3;
| | | | | | Other
| | | | | | Group P: 17, Group Q: 12;
| | | | | | Rehospitalization
| | | | | | Group P: 1, Group Q: 6;
| | | | | | Decrease in ATVI^n^
| | | | | | Group P: 9, Group Q: 0;
| | | | | | QRS^o^ interval decrease
| | | | | | Group P: 15;
| | | | | | QRS interval increase
| | | | | | Group Q:9
McFarlane, 2001 | RCT | Group R: Sertraline 50 mg/day; Group S: Placebo | 6 mos; 6 mos | NR | NA | SDNN (SEM)^p^
| | | | | | Group R: 1.5 mos 119 (10), 5.5 mos 121 (17); Group S: 1.5 mos 103 (7.9), 5.5 mos 86 (10) ;
| | | | | | RMSSD(SEM)^q^
| | | | | | Group R: 1.5 mos 28.8 (4,7), 5.5 mos 30 (7.1); Group S: 1.5 mos 26.7 (3), 5.5 mos 23.7 (5.7);
| | | | | | LF/HF^r^ ratio @ 1.5 mos
| | | | | | Group R: 1.34 (0.15), Group S: 1.62 (0.22)
Glassman, 2002 | RCT | Group T: Sertraline 50 mg/day daily; Group U: | Group T: 149.5 d; 24 wks; Group U: 153.8 d; 24 wks | CGI 1^s^ mean score | MI | Total mortality
| | Placebo daily | | Group T: 2.57, Group U: 2.75; | Group T: 5, Group U: 7; | Group T: 2, Group U: 5;
| | | | HAMD mean change in score @ 6 mos | Congestive heart failure | Composite end-point
| | | | Group T: -8.4, Group U: -7.6 | Group T: 5, Group U:7; | Group T: 32, Group U:41
| | | | | Angina
| | | | | Group T: 26, Group U:30
Berkman, 2003 ENRICHD | RCT | Group V: Cognitive behavioral therapy, Social problem solving, plus SSRI^t^ certain conditions (Sertraline 50 mg/day) Group W: Usual care | 180 d; 18 mos | BDI change (baseline 6 mos) | Cardiac Mortality | Total mortality
| | | | Group V -8.6(9.2), Group W: -5.8(8.9); | Group V: 7.8%, Group W: 9.3%; | Group V: 13.6%, Group W: 13.8%;
| | | | HAMD change (baseline 6 mos) | MI | Cardiovascular hospitalization
| | | | Group V -10.1(7.8), Group W: -8.4(7.7) | Group V: 13.6%, Group W: 13.7%; | Group V: 35.7%, Group W: 37.6%
| | | | | Revascularization
| | | | | Group V: 17.4%, Group W: 18.5%
Swenson, 2003 | RCT | Group X: Sertraline 50 mg/day; Group Y: Placebo | 24 wks; 18 mos | HAMD score change @ 16 wks | NA | SF 36^u^
| | | | Group X: -8.4(0.4), Group Y: -7.6(0.4) | | Mental Component score change
| | | | BDI score change @ 16 wks | | Group X: 17.4, Group Y: 15.2;
| | | | Group X: -8.0(0.6), Group Y: -7.3(0.6) | | Physical Component score change
| | | | | | Group A: 10.6, Group Y:10.1

a Prospective cohort study

b Weeks

c Months

d Randomized controlled trial

e Symptom Checklist - 90

f Beck Depression Inventory

g Minnesota Multiphase Personality Inventory

h Year

i Heart rate variability - Standard deviation of normal R R interval

j Heart rate variability - the proportion of pairs of adjacent intervals differing by more than 50 ms

k Hospital Anxiety and Depression Scale

l Hamilton Rating Scale for Depression

m Gastrointestinal

n Aortic time velocity integral

o QRS Interval

p Standard deviation of normal R R interval (Standard error of mean)

q Root mean square of successive differences (Standard error of mean)

r Low frequency/high frequency

s Clinical Global Inventory

t Selective serotonin re-uptake inhibitors

u Medical Outcomes Study Short form 36 health survey

Table 8 Summary of Studies on Methods of Screening for Depression in Myocardial Infarction Patients (Question 5)

Study Author, Year | Study Design | Location | No. of Subjects | Mean Age | Male (%) | Test | | Sensitivity | Specificity | Other
Davis, 1988 | Pro cohort^a^ | Canada | 52 | 51 | 90 | #1 | SCID^b^ nurse & therapist interview | | | Concordance: 80.8%
| | | | | | #2 | SCID nurse and BDI^c^ | | | Concordance: 13.5%
| | | | | | #3 | Therapist interview and BDI | | | Concordance: 11.5%
Martin, 2000 | Cross-sectional | Europe | 194 | 63.4 | 73 | #1 | HADS^d^ all items | | | Internal consistency: 0.82
| | | | | | #2 | HADS Depression subscale | | | Internal consistency: 0.72
| | | | | | | | | | Exploratory factor analysis reported
Wojciechowski, 2000 | Pro cohort | Europe | 143 | 57.8 | 81 | #1 | Zung SDS^e^/ SCL-90-Dep^f^ | | | Pearson correlations:
| | | | | | | | | | 0.70; 0.76; 0.77; 0.75, @ 1, 3, 6, 12 mos^g^ post-MI
| | | | | | #2 | Zung SDS / Maastricht Quest (vital exhaustion) | | | Pearson correlations:
| | | | | | | | | | 0.79; 0.76; 0.78; 0.81, @ 1, 3, 6, 12 mos post-MI
| | | | | | #3 | SCL-90-Dep / Maastricht Quest (vital exhaustion) | | | Pearson correlations:
| | | | | | | | | | 0.75; 0.83; 0.76; 0.76, @ 1, 3, 6, 12 mos post-MI
Strik, 2001 | Cross-sectional | Europe | 206 | 59.9 | 76 | #1 | SCL - 90 | 81% major/ minor^h^, 96% major^i^ only | 84% major/minor, 74% major only | PPV^j^:
| | | | | | | | | | 40% major/minor, 36.8% major only;
| | | | | | | | | | NPV^k^:
| | | | | | | | | | 93.3% major/minor, 96.2% major only
| | | | | | #2 | BDI | 84% major/minor, 82% major only | 72% major/minor, 79% major only | PPV:
| | | | | | | | | | 25% major/minor, 33% major only;
| | | | | | | | | | NPV:
| | | | | | | | | | 98% major/minor, 98% major only
| | | | | | #3 | HADS/ HADS-Depression subscale | HADS: | HADS: | HADS PPV:
| | | | | | | | 78% major/minor, 90% major only; | 85% major/minor, 84% major only; | 45% major/minor, 45% major only;
| | | | | | | | HADS-D: | HADS-D: | HADS NPV:
| | | | | | | | 75% major/minor, 85% major only | 78% major/minor, 75% major only | 99% major/minor, 99% major only;
| | | | | | | | | | HADS-D PPV:
| | | | | | | | | | 32% major/minor, 32% major only;
| | | | | | | | | | HADS-D NPV:
| | | | | | | | | | 98% major/minor, 98% major only^l^
| | | | | | #4 | 17-item HAMD^m^ | 76% major/minor, 86% major only | 86% major/minor, 92% major only | PPV:
| | | | | | | | | | 41% major/minor;
| | | | | | | | | | NPV:
| | | | | | | | | | 99% major/minor, 98% major only
Freedland, 2002 | Pro cohort | USA | 2404 | 61 | 56 | | BDI / HAMD | | | Pearson correlation: 0.64
Martin, 2003 | Pro cohort | Europe | 335 | 67.4 | 67 | #1 | HADS all items | | | Internal consistency:
| | | | | | | | | | 0.87 @ 1 wk, 0.88 @ 6 wks, 0.90 @ 6 mos
| | | | | | #2 | HADS depression subscale | | | Internal consistency:
| | | | | | | | | | 0.76 @ 1 wk, 0.8 @ 6 wks, 0.81 6 mos
| | | | | | | | | | Confirmatory factor analysis reported

a Prospective cohort study

b Structured Clinical Interview for Diagnostic & Statistical Manual of Mental Disorders - IV

c Beck Depression Inventory

d Hospital Anxiety and Depression Scale

e Zung Self-Rating Depression Scale

f Symptom Check List 90

g Months

h Major and minor depression

i Major depression

j Positive predictive value

k Negative predictive value

l There appears to be a misprint in original article tables listing positive predictive value and negative predictive value as equal for both major and major/minor depression,which does not reconcile with their statistical data presented.

m Hamilton Rating Scale for Depression

Table 9 Summary of Characteristics of Studies on the Relation of Depression to Use of Treatment after Hospitalization for Myocardial Infarction (Question 6)

Study Author, Year | Study Design | Location | Study Group | No. of Subjects | Mean Age | Male (%) | HTN^a^ (%) | DM^b^ (%) | Smoking (%) | Lipid^c^ (%)
Bennet, 2003 | Pro cohort^d^ | Europe | NA^e^ | 37 | 62 | 73 | NR^f^ | NR | NR | NR
Blumenthal, 1982 | Pro cohort | USA | NA | 35 | 54 | 94 | NR | NR | NR | NR
Druss, 2000 | Retro cohort^g^ | USA | Mental disorders | 5365 | 76 | 52 | 42 | 22 | 23 | NR
| | | No mental disorders | 108288 | 76 | 46 | 40 | 26 | 15 | NR
Ziegelstein, 2000 | Pro cohort | USA | BDI^h^ ≥10 | 35 | 46 | 46 | 71 | 31 | 31 | 69
| | | BDI <10 | 169 | 55 | 59 | 62 | 30 | 27 | 61
| | | Major Depression/ Dysthymia | 31 | 42 | 52 | 71 | 36 | 29 | 71
| | | No Major Depression/ Dysthymia | 173 | 54 | 58 | 63 | 31 | 27 | 60
Romanelli, 2002 | Pro cohort | USA | Depressed | 35 | 75 | 57 | 71 | 49 | NR | 57
| | | Not depressed | 118 | 73 | 55 | 70 | 33 | NR | 60
Bennet, 2003 | Pro cohort | Europe | NA | 37 | 62 | 73 | NR | NR | NR | NR
Lauzon, 2003 | Pro cohort | Canada | Depressed | 191 | 60 | 75 | 34 | 16 | 40 | 35
| | | Not depressed | 359 | 60 | 81 | 36 | 16 | 40 | 39
Whitmarsh, 2003 | Pro cohort | Europe | NA | 93 | 64 | 76 | NR | NR | 61 | NR
Steeds, 2004 | Pro cohort | Europe | BDI^f^ ≥12 | 62 | NR | NR | NR | NR | NR | NR
| | | BDI < 12 | 69 | NR | NR | NR | NR | NR | NR
Strik, 2004 | Pro cohort | Europe | Depressed | 63 | NR | 67 | NR | NR | 10 | 35
| | | Not depressed | 143 | NR | 80 | NR | NR | 13 | 29

a Hypertension

b Diabetes mellitus

c Hyperlipidemia

d Prospective cohort study

e Not applicable

f Not reported

g Retrospective cohort study

h Beck Depression Inventory

Table 10 Summary of Results of Studies on the Relation of Depression to Use of Treatment after Hospitalization for Myocardial Infarction (Question 6)

Study Author, Year | Study Group | Diagnosis of MI | Method of Assessing of Depression used for Analysis | No. of Subjects | Follow-Up | Cardiac Cath^a^ (% ) | PTCA^b^(%) | CABG^c^(%) | Aspirin/ Antiplatelet (%) | Beta Blockers (%)
Druss, 2000 | Major depression/affective | ICD-^d^ 9 | ICD-9 | 315 | 16 mos^e^ | 33^f^ | 9 | 8 | NR | NR
| No mental disorders | | | 108288 | 16 mos | 44^f^ | 17 | 13 | NR | NR
Ziegelstein, 2000 | Major depression/ dysthmia | Pain, EKG^g^, CPK MB^h^ | SCID^i^ BDI^j^ > 10 | 31 | 4 mos | NR | NR | NR | NR | 72
| Not depressed | | | 173 | 4 mos | NR | NR | NR | NR | 88
Romanelli, 2002 | Depressed (BDI ≥ 10) | Pain, EKG, CPK MB | SCID | 35 | 4 mos | NR | NR | NR | 86 | 74
| Not depressed | | | 118 | 4 mos | NR | NR | NR | 84 | 86
Lauzon, 2003 | Depressed | NR | BDI-10 | 191 | 30 d^k^ | 57 | 32 | 7 | NR | NR
| Not depressed | NR | | 359 | 30 d | 47 | 25 | 8 | NR | NR
| Depressed | NR | BDI-10 | 191 | 1 yr^l^ | 67 | 39 | 19 | 84 | 56
| Not depressed | NR | | 359 | 1 yr | 55 | 30 | 16 | 86 | 64
Steeds, 2004 | Depressed | Pain, EKG, CPK MB | BDI-12 | 62 | 32 mos | NR | NR | NR | NR | 32
| Not depressed | | | 69 | 32 mos | NR | NR | NR | NR | 55
Strik, 2004 | Depressed/ Minor depression | Pain, EKG, ASAT^m^ | SCID | 63 | 1 yr | NR | 36 | NR | 81^f^ | 40
| Not depressed | | | 143 | 1 yr | NR | 36 | NR | 95^f^ | 40

a Cardiac catheterization

b Percutaneous transluminal coronary angioplasty

c Coronary artery bypass graft

d The International Statistical Classification of Diseases and Related Health Problems

e Months

f p < 0.001

g Electrocardiogram

h Creatine phosphokinase - muscle brain

i Structured Clinical Interview for DSM IV

j Beck Depression Inventory

k Day

l Year

m Aspartate aminotransferase

## References for Summary Tables

Aben I, Verhey F, Strik J, et al. A comparative study into the one year cumulative incidence of depression after stroke and myocardial infarction. J Neurol Neurosurg Psychiatry. 2003;74(5):581-5. [pmid: 12700297]. [pmcid: 1738412].
Ahern DK, Gorkin L, Anderson JL, et al. Biobehavioral variables and mortality or cardiac arrest in the Cardiac Arrhythmia Pilot Study (CAPS). Am J Cardiol. 1990;66(1):59-62. [pmid: 2193497].
Barefoot JC, Burg MM, Carney RM, et al. Aspects of social support associated with depression at hospitalization and follow-up assessment among cardiac patients. J Cardiopulm Rehabil. 2003;23(6):404-12. [pmid: 14646786].
Bennett P, Mayfield T. Mood and behaviour change following first myocardial infarction. Cor Health Care. 1998;2(4):210-4.
Berkman LF, Blumenthal J, Burg M, et al. Effects of treating depression and low perceived social support on clinical events after myocardial infarction: the Enhancing Recovery in Coronary Heart Disease Patients (ENRICHD) Randomized Trial. JAMA. 2003;289(23):3106-16. [pmid: 12813116].
Blumenthal JA, Williams RS, Wallace AG. Physiological and psychological variables predict compliance to prescribed exercise therapy in patients recovering from myocardial infarction. Psychosom Med. 1982;44(6):519-27. [pmid: 7163455].
Bogg J, Thornton E, Bundred P. Gender variability in mood, quality of life and coping following primary myocardial infarction. Cor Health Care. 2000;4(4):163-168.
Brink E, Karlson BW, Hallberg LR. Health experiences of first-time myocardial infarction: factors influencing women's and men's health-related quality of life after five months. Psychology Health & Medicine. 2002;7(1):5-16.
Brown MA, Munford AM, Munford PR. Behavior therapy of psychological distress in patients after myocardial infarction or coronary bypass. J Cardiopulm Rehabil. 1993;13(3):201-210.
Bush DE, Ziegelstein RC, Tayback M, et al. Even minimal symptoms of depression increase mortality risk after acute myocardial infarction. Am J Cardiol. 2001;88(4):337-41. [pmid: 11545750].
Carney RM, Blumenthal JA, Catellier D, et al. Depression as a risk factor for mortality after acute myocardial infarction. Am J Cardiol. 2003;92(11):1277-81. [pmid: 14636903].
Carney RM, Blumenthal JA, Stein PK, et al. Depression, heart rate variability, acute myocardial infarction. Circulation. 2001;104(17):2024-8. [pmid: 11673340].
Carney RM, Freedland KE, Jaffe AS. Insomnia and depression prior to myocardial infarction. Psychosom Med. 1990;52(6):603-9. [pmid: 2287700].
Clarke DE, Walker JR, Cuddy TE. The role of perceived overprotectiveness in recovery 3 months after myocardial infarction. J Cardiopulm Rehabil. 1996;16(6):372-7. [pmid: 8985795].
Conn VS, Taylor SG, Wiman P. Anxiety, depression, quality of life, self-care among survivors of myocardial infarction. Issues Ment Health Nurs. 1991;12(4):321-31. [pmid: 1938339].
Crowe JM, Runions J, Ebbesen LS, et al. Anxiety and depression after acute myocardial infarction. Heart Lung. 1996;25(2):98-107. [pmid: 8682691].
Davis T, Jensen L. Identifying depression in medical patients. Image J Nurs Sch. 1988;20(4):191-5. [pmid: 3203939].
Denollet J, Vaes J, Brutsaert DL. Inadequate response to treatment in coronary heart disease : adverse effects of type D personality and younger age on 5-year prognosis and quality of life. Circulation. 2000;102(6):630-5. [pmid: 10931802].
Dracup K, Moser DK, Marsden C, et al. Effects of a multidimensional cardiopulmonary rehabilitation program on psychosocial function. Am J Cardiol. 1991;68(1):31-4. [pmid: 2058556].
Drory Y, Kravetz S, Florian V, et al. Sexual activity after first acute myocardial infarction in middle-aged men: demographic, psychological and medical predictors. Cardiology. 1998;90(3):207-11. [pmid: 9892770].
Drory Y, Kravetz S, Hirschberger G. Long-term mental health of men after a first acute myocardial infarction. Arch Phys Med Rehabil. 2002;83(3):352-9. [pmid: 11887116].
Drory Y, Kravetz S, Hirschberger G. Long-term mental health of women after a first acute myocardial infarction. Arch Phys Med Rehabil. 2003;84(10):1492-8. [pmid: 14586917].
Druss BG, Bradford DW, Rosenheck RA, et al. Mental disorders and use of cardiovascular procedures after myocardial infarction. JAMA. 2000;283(4):506-11. [pmid: 10659877].
Druss BG, Bradford D, Rosenheck RA, et al. Quality of medical care and excess mortality in older patients with mental disorders. Arch Gen Psychiatry. 2001;58(6):565-72. [pmid: 11386985].
Follick MJ, Gorkin L, Smith TW, et al. Quality of life post-myocardial infarction: effects of a transtelephonic coronary intervention system. Health Psychol. 1988;7(2):169-82. [pmid: 3371309].
Forrester AW, Lipsey JR, Teitelbaum ML, et al. Depression following myocardial infarction. Int J Psychiatry Med. 1992;22(1):33-46. [pmid: 1577547].
Frasure-Smith N, Lesperance F, Gravel G, et al. Depression and health-care costs during the first year following myocardial infarction. J Psychosom Res. 2000;48(45):471-8. [pmid: 10880668].
Frasure-Smith N, Lesperance F, Juneau M, et al. Gender, depression, one-year prognosis after myocardial infarction. Psychosom Med. 1999;61(1):26-37. [pmid: 10024065].
Frasure-Smith N, Lesperance F, Prince RH, et al. Randomised trial of home-based psychosocial nursing intervention for patients recovering from myocardial infarction. Lancet. 1997;350(9076):473-9. [pmid: 9274583].
Frasure-Smith N, Lesperance F, Talajic M. Depression following myocardial infarction. Impact on 6-month survival. JAMA. 1993;270(15):1819-25. [pmid: 8411525].
Frasure-Smith N, Lesperance F. Depression and other psychological risks following myocardial infarction. Arch Gen Psychiatry. 2003;60(6):627-36. [pmid: 12796226].
Freedland KE, Skala JA, Carney RM, et al. The Depression Interview and Structured Hamilton (DISH): Rationale, development, characteristics and clinical validity. Psychosom Med. 2002;64(6):897-905. [pmid: 12461195].
Garcia L, Valdes M, Jodar I, et al. Psychological factors and vulnerability to psychiatric morbidity after myocardial infarction. Psychother Psychosom. 1994;61(34):187-94. [pmid: 8066156].
Gilutz H, Bar-On D, Billing E, et al. The relationship between causal attribution and rehabilitation in patients after their first myocardial infarction. A cross cultural study. Eur Heart J. 1991;12(8):883-8. [pmid: 1915426].
Glassman AH, O'Connor CM, Califf RM, et al. Sertraline treatment of major depression in patients with acute MI or unstable angina. JAMA. 2002;288(6):701-9. [pmid: 12169073].
Havik OE, Maeland JG. Patterns of emotional reactions after a myocardial infarction. J Psychosom Res. 1990;34(3):271-85. [pmid: 2341995].
Irvine J, Basinski A, Baker B, et al. Depression and risk of sudden cardiac death after acute myocardial infarction: testing for the confounding effects of fatigue. Psychosom Med. 1999;61(6):729-37. [pmid: 10593621].
Jenkinson CM, Madeley RJ, Mitchell JR, et al. The influence of psychosocial factors on survival after myocardial infarction. Public Health. 1993;107(5):305-17. [pmid: 8248465].
Johnston M, Foulkes J, Johnston DW, et al. Impact on patients and partners of inpatient and extended cardiac counseling and rehabilitation: a controlled trial. Psychosom Med. 1999;61(2):225-33. [pmid: 10204976].
Kaufmann MW, Fitzgibbons JP, Sussman EJ, et al. Relation between myocardial infarction, depression, hostility, death. Am Heart J. 1999;138(3 Pt 1):549-54. [pmid: 10467207].
Kuijpers PM, Hamulyak K, Strik JJ, et al. Beta-thromboglobulin and platelet factor 4 levels in post-myocardial infarction patients with major depression. Psychiatry Res. 2002;109(2):207-10. [pmid: 11927146].
Ladwig KH, Kieser M, Konig J, et al. Affective disorders and survival after acute myocardial infarction. Results from the post-infarction late potential study. Eur Heart J. 1991;12(9):959-64. [pmid: 1936008].
Ladwig Kh, Roll G, Breithardt G, et al. Extracardiac contributions to chest pain perception in patients 6 months after acute myocardial infarction. Am Heart J. 1999;137(3):528-35. [pmid: 10047637].
Lane D, Carroll D, Ring C, et al. Effects of depression and anxiety on mortality and quality-of-life 4 months after myocardial infarction. J Psychosom Res. 2000;49(4):229-38. [pmid: 11119779].
Lane D, Carroll D, Ring C, et al. In-hospital symptoms of depression do not predict mortality 3 years after myocardial infarction. Int J Epidemiol. 2002;31(6):1179-82. [pmid: 12540719].
Lane D, Carroll D, Ring C, et al. The prevalence and persistence of depression and anxiety following myocardial infarction. Br J Health Psychol. 2002;7(1):11-21. [pmid: 14596714].
Lane D, Carroll D, Ring C, et al. Mortality and quality of life 12 months after myocardial infarction: effects of depression and anxiety. Psychosom Med. 2001;63(2):221-30. [pmid: 11292269].
Lauzon C, Beck CA, Huynh T, et al. Depression and prognosis following hospital admission because of acute myocardial infarction. Can Med Assoc J. 2003;168(5):547-52. [pmid: 12615746]. [pmcid: 149246].
Legault SE, Joffe RT, Armstrong PW. Psychiatric morbidity during the early phase of coronary care for myocardial infarction: association with cardiac diagnosis and outcome. Can J Psychiatry. 1992;37(5):316-25. [pmid: 1638455].
Lehto S, Koukkunen H, Hintikka J, et al. Depression after coronary heart disease events. Scand Cardiovasc J. 2000;34(6):580-3. [pmid: 11214011].
Lesperance F, Frasure-Smith N, Talajic M. Major depression before and after myocardial infarction: its nature and consequences. Psychosom Med. 1996;58(2):99-110. [pmid: 8849624].
Lesperance F, Frasure-Smith N, Talajic M, et al. Five-year risk of cardiac mortality in relation to initial severity and one-year changes in depression symptoms after myocardial infarction. Circulation. 2002;105(9):1049-53. [pmid: 11877353].
Lesperance F, Frasure-Smith N, Theroux P, et al. The association between major depression and levels of soluble intercellular adhesion molecule 1, interleukin-6, C-reactive protein in patients with recent acute coronary syndromes. Am J Psychiatry. 2004;161(2):271-7. [pmid: 14754776].
Luutonen S, Holm H, Salminen JK, et al. Inadequate treatment of depression after myocardial infarction. Acta Psychiatr Scand. 2002;106(6):434-39. [pmid: 12392486].
Martin CR, Lewin RJ, Thompson DR. A confirmatory factor analysis of the Hospital Anxiety and Depression Scale in coronary care patients following acute myocardial infarction. Psychiatry Res. 2003;120(1):85-94. [pmid: 14500117].
Martin CR, Thompson DR. A psychometric evaluation of the Hospital Anxiety and Depression Scale in coronary care patients following acute myocardial infarction. Psychol Health Med. 2000;5(2):193-201.
Mayou RA, Gill D, Thompson DR, et al. Depression and anxiety as predictors of outcome after myocardial infarction. Psychosom Med. 2000;62(2):212-9. [pmid: 10772399].
McFarlane A, Kamath MV, Fallen EL, et al. Effect of sertraline on the recovery rate of cardiac autonomic function in depressed patients after acute myocardial infarction. Am Heart J. 2001;142(4):617-23. [pmid: 11579351].
O'Rourke A, Hampson SE. Psychosocial outcomes after an MI: an evaluation of two approaches to rehabilitation. Psychology Health & Medicine. 1999;4(4):393-402.
Rafanelli C, Roncuzzi R, Finos L, et al. Psychological assessment in cardiac rehabilitation. Psychother Psychosom. 2003;72(6):343-9. [pmid: 14526137].
Romanelli J, Fauerbach JA, Bush DE, et al. The significance of depression in older patients after myocardial infarction. J Am Geriatr Soc. 2002;50(5):817-22. [pmid: 12028166].
Roose SP, Laghrissi-Thode F, Kennedy JS, et al. Comparison of paroxetine and nortriptyline in depressed patients with ischemic heart disease. JAMA. 1998;279(4):287-91. [pmid: 9450712].
Schleifer SJ, Slater WR, Macari-Hinson MM, et al. Digitalis and beta-blocking agents: effects on depression following myocardial infarction. Am Heart J. 1991;121(5):1397-402. [pmid: 1673283].
Shiotani I, Sato H, Kinjo K, et al. Depressive symptoms predict 12-month prognosis in elderly patients with acute myocardial infarction. J Cardiovasc Risk. 2002;9(3):153-60. [pmid: 12202838].
Silverstone PH. Changes in depression scores following life-threatening illness. J Psychosom Res. 1990;34(6):659-63. [pmid: 2290138].
Soejima Y, Steptoe A, Nozoe S, et al. Psychosocial and clinical factors predicting resumption of work following acute myocardial infarction in Japanese men. Int J Cardiol. 1999;72(1):39-47. [pmid: 10636631].
Steeds RP, Bickerton D, Smith MJ, et al. Assessment of depression following acute myocardial infarction using the Beck depression inventory. Heart. 2004;90(2):217-8. [pmid: 14729806]. [pmcid: 1768075].
Strik JJ, Denollet J, Lousberg R, et al. Comparing symptoms of depression and anxiety as predictors of cardiac events and increased health care consumption after myocardial infarction. J Am Coll Cardiol. 2003;42(10):1801-7. [pmid: 14642691].
Strik JJ, Honig A, Lousberg R, et al. Clinical correlates of depression following myocardial infarction. Int J Psychiatry Med. 2001;31(3):255-64. [pmid: 11841123].
Strik JJ, Lousberg R, Cheriex EC, et al. One year cumulative incidence of depression following myocardial infarction and impact on cardiac outcome. J Psychosom Res. 2004;56(1):59-66. [pmid: 14987965].
Strik JJ, Lousberg R, Crijns HJ, et al. Relation of levels of serum lipoproteins to depression after acute myocardial infarction. Am J Cardiol. 2002;90(12):1368-70. [pmid: 12480046].
Strik JJMH, Honig A, Lousberg R, et al. Efficacy and safety of fluoxetine in the treatment of patients with major depression after first myocardial infarction: Findings from a double-blind, placebo-controlled trial. Psychosom Med. 2000;62(6):783-9. [pmid: 11138997].
Strik JJ, Honig A, Lousberg R, et al. Sensitivity and specificity of observer and self-report questionnaires in major and minor depression following myocardial infarction. Psychosomatics. 2001;42(5):423-8. [pmid: 11739910].
Swenson JR, O'Connor CM, Barton D, et al. Influence of depression and effect of treatment with sertraline on quality of life after hospitalization for acute coronary syndrome. Am J Cardiol. 2003;92(11):1271-6. [pmid: 14636902].
Taylor CB, DeBusk RF, Davidson DM, et al. Optimal methods for identifying depression following hospitalization for myocardial infarction. J Chronic Dis. 1981;34(4):127-33. [pmid: 7228981].
Taylor CB, Houston-Miller N, Ahn DK, et al. The effects of exercise training programs on psychosocial improvement in uncomplicated postmyocardial infarction patients. J Psychosom Res. 1986;30(5):581-7. [pmid: 3772840].
Taylor CB, Miller NH, Smith PM, et al. The effect of a home-based, case-managed, multifactorial risk-reduction program on reducing psychological distress in patients with cardiovascular disease. J Cardiopulm Rehabil. 1997;17(3):157-62. [pmid: 9187981].
Travella JI, Forrester AW, Schultz SK, et al. Depression following myocardial infarction: a one year longitudinal study. Int J Psychiatry Med. 1994;24(4):357-69. [pmid: 7737790].
Trelawny-Ross C, Russell O. Social and psychological responses to myocardial infarction: multiple determinants of outcome at six months. J Psychosom Res. 1987;31(1):125-30. [pmid: 3820141].
Watkins LL, Blumenthal JA, Carney RM. Association of anxiety with reduced baroreflex cardiac control in patients after acute myocardial infarction. Am Heart J. 2002;143(3):460-6. [pmid: 11868052].
Welin C, Lappas G, Wilhelmsen L. Independent importance of psychosocial factors for prognosis after myocardial infarction. J Intern Med. 2000;247(6):629-39. [pmid: 10886484].
Whitmarsh A, Koutantji M, Sidell K. Illness perceptions, mood and coping in predicting attendance at cardiac rehabilitation. Br J Health Psychol. 2003;8(2):209-21. [pmid: 12804334].
Wiklund I, Herlitz J, Johansson S, et al. Subjective symptoms and well-being differ in women and men after myocardial infarction. Eur Heart J. 1993;14(10):1315-9. [pmid: 8262076].
Wiklund I, Sanne H, Elmfeldt D, et al. Emotional reaction, health preoccupation and sexual activity two months after a myocardial infarction. Scand J Rehabil Med. 1984;16(2):47-56. [pmid: 6463617].
Wojciechowski FL, Strik JJ, Falger P, et al. The relationship between depressive and vital exhaustion symptomatology post-myocardial infarction. Acta Psychiatr Scand. 2000;102(5):359-65. [pmid: 11098808].
Ziegelstein RC, Fauerbach JA, Stevens SS, et al. Patients with depression are less likely to follow recommendations to reduce cardiac risk during recovery from a myocardial infarction. Arch Intern Med. 2000;160(12):1818-23. [pmid: 10871976].