# References and Included Studies

1 American Heart Association. Heart Disease and Stroke Statistics — 2004 Update. Dallas, Tex.: American Heart Association; 2003.
2 Furman MI, Dauerman HL, Goldberg RJ, et al. Twenty-two year (1975 to 1997) trends in the incidence, in-hospital and long-term case fatality rates from initial Q-wave and non-Q-wave myocardial infarction: a multi-hospital, community-wide perspective. J Am Coll Cardiol. 2001;37(6):1571-80. [pmid: 11345367].
3 Ziegelstein RC. Depression in patients recovering from a myocardial infarction. JAMA. 2001;286(13):1621-7. [pmid: 11585486].
4 Guck TP, Kavan MG, Elsasser GN, et al. Assessment and treatment of depression following myocardial infarction. Am Fam Physician. 2001;64(4):641-8. [pmid: 11529263].
5 Schleifer SJ, Macari-Hinson MM, Coyle DA, et al. The nature and course of depression following myocardial infarction. Arch Intern Med. 1989;149(8):1785-9. [pmid: 2788396].
6 Denollet J, Vaes J, Brutsaert DL. Inadequate response to treatment in coronary heart disease: adverse effects of type D personality and younger age on 5-year prognosis and quality of life. Circulation. 2000;102(6):630-5. [pmid: 10931802].
7 Lepine JP, Gastpar M, Mendlewicz J, et al. Depression in the community: the first pan-European study DEPRES (Depression Research in European Society). Int Clin Psychopharmacol. 1997;12(1):19-29. [pmid: 9179630].
8 Antman EM, Anbe DT, Armstrong PW, et al. ACC/AHA guidelines for the management of patients with ST-elevation myocardial infarction — executive summary: a report of the American Heart Association Task Force on Practice Guidelines (Writing Committee to Revise the 1999 Guidelines for the Management of Patients With Acute Myocardial Infarction. Circulation. 2004;110(5):588-636. [pmid: 15289388].
9 Frasure-Smith N, Lesperance F, Talajic M. Depression and 18-month prognosis after myocardial infarction. Circulation. 1995;91(4):999-1005. [pmid: 7531624].
10 Aben I, Verhey F, Strik J, et al. A comparative study into the one year cumulative incidence of depression after stroke and myocardial infarction. J Neurol Neurosurg Psychiatry. 2003;74(5):581-5. [pmid: 12700297]. [pmcid: 1738412].
11 Executive Summary of The Third Report of The National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, And Treatment of High Blood Cholesterol In Adults (Adult Treatment Panel III). JAMA. 2001; 285(19): 2486–97.
12 Anda R, Williamson D, Jones D, et al. Depressed affect, hopelessness, and the risk of ischemic heart disease in a cohort of U.S. adults. Epidemiology. 1993;4(4):285-94. [pmid: 8347738].
13 Aromaa A, Raitasalo R, Reunanen A, et al. Depression and cardiovascular diseases. Acta Psychiatr Scand Suppl. 1994;377:77-82. [pmid: 8053372].
14 Barefoot JC, Schroll M. Symptoms of depression, acute myocardial infarction, and total mortality in a community sample. Circulation. 1996;93(11):1976-80. [pmid: 8640971].
15 Pratt LA, Ford DE, Crum RM, et al. Depression, psychotropic medication, and risk of myocardial infarction. Prospective data from the Baltimore ECA follow-up. Circulation. 1996;94(12):3123-9. [pmid: 8989119].
16 Sesso HD, Kawachi I, Vokonas PS, et al. Depression and the risk of coronary heart disease in the Normative Aging Study. Am J Cardiol. 1998;82(7):851-6. [pmid: 9781966].
17 Ferketich AK, Schwartzbaum JA, Frid DJ, et al. Depression as an antecedent to heart disease among women and men in the NHANES I study. National Health and Nutrition Examination Survey. Arch Intern Med. 2000;160(9):1261-8. [pmid: 10809028].
18 Cohen HW, Madhavan S, Alderman MH. History of treatment for depression: risk factor for myocardial infarction in hypertensive patients. Psychosom Med. 2001;63(2):203-9. [pmid: 11292266].
19 Penninx BW, Beekman AT, Honig A, et al. Depression and cardiac mortality: results from a community-based longitudinal study. Arch Gen Psychiatry. 2001;58(3):221-7. [pmid: 11231827].
20 Ford DE, Mead LA, Chang PP, et al. Depression is a risk factor for coronary artery disease in men: the Precursors Study. Arch Intern Med. 1998;158(13):1422-6. [pmid: 9665350].
21 Ariyo AA, Haan M, Tangen CM, et al. Depressive symptoms and risks of coronary heart disease and mortality in elderly Americans. Cardiovascular Health Study Collaborative Research Group. Circulation. 2000;102(15):1773-9. [pmid: 11023931].
22 Welin C, Lappas G, Wilhelmsen L. Independent importance of psychosocial factors for prognosis after myocardial infarction. J Intern Med. 2000;247(6):629-39. [pmid: 10886484].
23 Lane D, Carroll D, Ring C, et al. Mortality and quality of life 12 months after myocardial infarction: effects of depression and anxiety. Psychosom Med. 2001;63(2):221-30. [pmid: 11292269].
24 Irvine J, Basinski A, Baker B, et al. Depression and risk of sudden cardiac death after acute myocardial infarction: testing for the confounding effects of fatigue. Psychosom Med. 1999;61(6):729-37. [pmid: 10593621].
25 Lesperance F, Frasure-Smith N, Talajic M, et al. Five-year risk of cardiac mortality in relation to initial severity and one-year changes in depression symptoms after myocardial infarction. Circulation. 2002;105(9):1049-53. [pmid: 11877353].
26 Stein PK, Carney RM, Freedland KE, et al. Severe depression is associated with markedly reduced heart rate variability in patients with stable coronary heart disease. J Psychosom Res. 2000;Vol 48(45):493-500. [pmid: 10880671].
27 Carney RM, Freedland KE, Rich MW, et al. Ventricular tachycardia and psychiatric depression in patients with coronary artery disease. Am J Med. 1993;95(1):23-8. [pmid: 8328494].
28 Franke L, Schewe HJ, Muller B, et al. Serotonergic platelet variables in unmedicated patients suffering from major depression and healthy subjects: relationship between 5HT content and 5HT uptake. Life Sci. 2000;67(3):301-5. [pmid: 10983874].
29 Hrdina PD, Bakish D, Ravindran A, et al. Platelet serotonergic indices in major depression: up-regulation of 5-HT2A receptors unchanged by antidepressant treatment. Psychiatry Res. 1997;66(23):73-85. [pmid: 9075272].
30 Vanhoutte PM. Platelet-derived serotonin, the endothelium, and cardiovascular disease. J Cardiovasc Pharmacol. 1991;17(Suppl 5):S6-12. [pmid: 1717775].
31 Laghrissi-Thode F, Wagner WR, Pollock BG, et al. Elevated platelet factor 4 and beta-thromboglobulin plasma levels in depressed patients with ischemic heart disease. Biol Psychiatry. 1997;42(4):290-5. [pmid: 9270907].
32 Musselman DL, Marzec UM, Manatunga A, et al. Platelet reactivity in depressed patients treated with paroxetine: preliminary findings. Arch Gen Psychiatry. 2000;57(9):875-82. [pmid: 10986551].
33 Libby P, Ridker PM, Maseri A. Inflammation and atherosclerosis. Circulation. 2002;105(9):1135-43. [pmid: 11877368].
34 Libby P, Ridker PM. Inflammation and atherosclerosis: role of C-reactive protein in risk assessment. Am J Med. 2004;116(Suppl 6A):9S-16S. [pmid: 15050187].
35 Ridker PM, Rifai N, Stampfer MJ, et al. Plasma concentration of interleukin-6 and the risk of future myocardial infarction among apparently healthy men. Circulation. 2000;101(15):1767-72. [pmid: 10769275].
36 Albert CM, Ma J, Rifai N, et al. Prospective study of C-reactive protein, homocysteine, and plasma lipid levels as predictors of sudden cardiac death. Circulation. 2002;105(22):2595-9. [pmid: 12045163].
37 Ford DE, Erlinger TP. Depression and C-reactive protein in US adults: data from the Third National Health and Nutrition Examination Survey. Arch Intern Med. 2004;164(9):1010-4. [pmid: 15136311].
38 Druss BG, Rohrbaugh RM, Rosenheck RA. Depressive symptoms and health costs in older medical patients. Am J Psychiatry. 1999;156(3):477-9. [pmid: 10080569].
39 Katon WJ, Lin E, Russo J, et al. Increased medical costs of a population-based sample of depressed elderly patients. Arch Gen Psychiatry. 2003;60(9):897-903. [pmid: 12963671].
40 Lane D, Carroll D, Ring C, et al. Effects of depression and anxiety on mortality and quality-of-life 4 months after myocardial infarction. J Psychosom Res. 2000;49(4):229-38. [pmid: 11119779].
41 Hughes JW, Watkins L, Blumenthal JA, et al. Depression and anxiety symptoms are related to increased 24-hour urinary norepinephrine excretion among healthy middle-aged women. J Psychosom Res. 2004;57(4):353-8. [pmid: 15518669].
42 O'Connor TM, O'Halloran DJ, Shanahan F. The stress response and the hypothalamic-pituitary-adrenal axis: from molecule to melancholia. QJM. 2000;93(6):323-33. [pmid: 10873181].
43 Severus WE, Littman AB, Stoll AL. Omega-3 fatty acids, homocysteine, and the increased risk of cardiovascular mortality in major depressive disorder. Harv Rev Psychiatry. 2001;9(6):280-93. [pmid: 11600487].
44 Jiang W, Krishnan RR. Should selective serotonin reuptake inhibitors be prescribed to all patients with ischemic heart disease?. Curr Psychiatry Rep. 2004;6(3):202-9. [pmid: 15142473].
45 Brown MA, Munford AM, Munford PR. Behavior therapy of psychological distress in patients after myocardial infarction or coronary bypass. J Cardiopulm Rehabil. 1993;13(3):201-210.
46 Crowe JM, Runions J, Ebbesen LS, et al. Anxiety and depression after acute myocardial infarction. Heart Lung. 1996;25(2):98-107. [pmid: 8682691].
47 Dracup K, Moser DK, Marsden C, et al. Effects of a multidimensional cardiopulmonary rehabilitation program on psychosocial function. Am J Cardiol. 1991;68(1):31-4. [pmid: 2058556].
48 Frasure-Smith N, Lesperance F, Prince RH, et al. Randomised trial of home-based psychosocial nursing intervention for patients recovering from myocardial infarction. Lancet. 1997;350(9076):473-9. [pmid: 9274583].
49 Johnston M, Foulkes J, Johnston DW, et al. Impact on patients and partners of inpatient and extended cardiac counseling and rehabilitation: a controlled trial. Psychosom Med. 1999;61(2):225-33. [pmid: 10204976].
50 Strik JJMH, Honig A, Lousberg R, et al. Efficacy and safety of fluoxetine in the treatment of patients with major depression after first myocardial infarction: Findings from a double-blind, placebo-controlled trial. Psychosom Med. 2000;62(6):783-9. [pmid: 11138997].
51 DiMatteo MR, Lepper HS, Croghan TW. Depression is a risk factor for noncompliance with medical treatment: meta-analysis of the effects of anxiety and depression on patient adherence. Arch Intern Med. 2000;160(14):2101-7. [pmid: 10904452].
52 Druss BG, Bradford DW, Rosenheck RA, et al. Mental disorders and use of cardiovascular procedures after myocardial infarction. JAMA. 2000;283(4):506-11. [pmid: 10659877].
53 U.S. Preventive Services Task Force. Screening for depression: recommendations and rationale. Ann Intern Med. 2002;136(10):760-4. [pmid: 12020145].
54 Pignone MP, Gaynes BN, Rushton JL, et al. Screening for depression in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;136(10):765-76. [pmid: 12020146].
55 Kessler RC, McGonagle KA, Zhao S, et al. Lifetime and 12-month prevalence of DSM-III-R psychiatric disorders in the United States. Results from the National Comorbidity Survey. Arch Gen Psychiatry. 1994;51(1):8-19. [pmid: 8279933].
56 Murray CJ, Lopez AD. Global mortality, disability, and the contribution of risk factors: Global Burden of Disease Study. Lancet. 1997;349(9063):1436-42. [pmid: 9164317].
57 Greenberg PE, Stiglin LE, Finkelstein SN, et al. The economic burden of depression in 1990. J Clin Psychiatry. 1993;54(11):405-18. [pmid: 8270583].
58 Berkman LF, Blumenthal J, Burg M, et al. Effects of treating depression and low perceived social support on clinical events after myocardial infarction: the Enhancing Recovery in Coronary Heart Disease Patients (ENRICHD) Randomized Trial. JAMA. 2003;289(23):3106-16. [pmid: 12813116].
59 Glassman AH, O'Connor CM, Califf RM, et al. Sertraline treatment of major depression in patients with acute MI or unstable angina. JAMA. 2002;288(6):701-9. [pmid: 12169073].
60 Roose SP, Glassman AH, Dalack GW. Depression, heart disease, and tricyclic antidepressants. J Clin Psychiatry. 1989;50(Suppl):12-6. discussion 17. [pmid: 2661547].
61 Berlin J. Does blinding of readers affect the results of meta-analyses?. Lancet. 1997;350(9072):185-6. [pmid: 9250191].
62 Grade Working Group. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490-7. [pmid: 15205295]. [pmcid: 428525].
63 O'Rourke A, Hampson SE. Psychosocial outcomes after an MI: an evaluation of two approaches to rehabilitation. Psychology Health & Medicine. 1999;4(4):393-402.
64 Bennett P, Mayfield T. Mood and behaviour change following first myocardial infarction. Cor Health Care. 1998;2(4):210-4.
65 Mayou RA, Gill D, Thompson DR, et al. Depression and anxiety as predictors of outcome after myocardial infarction. Psychosom Med. 2000;62(2):212-9. [pmid: 10772399].
66 Martin CR, Lewin RJ, Thompson DR. A confirmatory factor analysis of the Hospital Anxiety and Depression Scale in coronary care patients following acute myocardial infarction. Psychiatry Res. 2003;120(1):85-94. [pmid: 14500117].
67 Brink E, Karlson BW, Hallberg LR. Health experiences of first-time myocardial infarction: factors influencing women's and men's health-related quality of life after five months. Psychology Health & Medicine. 2002;7(1):5-16.
68 Carney RM, Freedland KE, Jaffe AS. Insomnia and depression prior to myocardial infarction. Psychosom Med. 1990;52(6):603-9. [pmid: 2287700].
69 Schleifer SJ, Slater WR, Macari-Hinson MM, et al. Digitalis and beta-blocking agents: effects on depression following myocardial infarction. Am Heart J. 1991;121(5):1397-402. [pmid: 1673283].
70 Forrester AW, Lipsey JR, Teitelbaum ML, et al. Depression following myocardial infarction. Int J Psychiatry Med. 1992;22(1):33-46. [pmid: 1577547].
71 Kaufmann MW, Fitzgibbons JP, Sussman EJ, et al. Relation between myocardial infarction, depression, hostility, and death. Am Heart J. 1999;138(3 Pt 1):549-54. [pmid: 10467207].
72 Watkins LL, Blumenthal JA, Carney RM. Association of anxiety with reduced baroreflex cardiac control in patients after acute myocardial infarction. Am Heart J. 2002;143(3):460-6. [pmid: 11868052].
73 Rafanelli C, Roncuzzi R, Finos L, et al. Psychological assessment in cardiac rehabilitation. Psychother Psychosom. 2003;72(6):343-9. [pmid: 14526137].
74 Bush DE, Ziegelstein RC, Tayback M, et al. Even minimal symptoms of depression increase mortality risk after acute myocardial infarction. Am J Cardiol. 2001;88(4):337-41. [pmid: 11545750].
75 Davis T, Jensen L. Identifying depression in medical patients. Image J Nurs Sch. 1988;20(4):191-5. [pmid: 3203939].
76 Legault SE, Joffe RT, Armstrong PW. Psychiatric morbidity during the early phase of coronary care for myocardial infarction: association with cardiac diagnosis and outcome. Can J Psychiatry. 1992;37(5):316-25. [pmid: 1638455].
77 Lane D, Carroll D, Ring C, et al. In-hospital symptoms of depression do not predict mortality 3 years after myocardial infarction. Int J Epidemiol. 2002;31(6):1179-82. [pmid: 12540719].
78 Barefoot JC, Burg MM, Carney RM, et al. Aspects of social support associated with depression at hospitalization and follow-up assessment among cardiac patients. J Cardiopulm Rehabil. 2003;23(6):404-12. [pmid: 14646786].
79 Steeds RP, Bickerton D, Smith MJ, et al. Assessment of depression following acute myocardial infarction using the Beck depression inventory. Heart. 2004;90(2):217-8. [pmid: 14729806]. [pmcid: 1768075].
80 Luutonen S, Holm H, Salminen JK, et al. Inadequate treatment of depression after myocardial infarction. Acta Psychiatr Scand. 2002;106(6):434-39. [pmid: 12392486].
81 Lauzon C, Beck CA, Huynh T, et al. Depression and prognosis following hospital admission because of acute myocardial infarction. Can Med Assoc J. 2003;168(5):547-52. [pmid: 12615746]. [pmcid: 149246].
82 Taylor CB, Houston-Miller N, Ahn DK, et al. The effects of exercise training programs on psychosocial improvement in uncomplicated postmyocardial infarction patients. J Psychosom Res. 1986;30(5):581-7. [pmid: 3772840].
83 Silverstone PH. Changes in depression scores following life-threatening illness. J Psychosom Res. 1990;34(6):659-63. [pmid: 2290138].
84 Strik JJ, Denollet J, Lousberg R, et al. Comparing symptoms of depression and anxiety as predictors of cardiac events and increased health care consumption after myocardial infarction. J Am Coll Cardiol. 2003;42(10):1801-7. [pmid: 14642691].
85 Trelawny-Ross C, Russell O. Social and psychological responses to myocardial infarction: multiple determinants of outcome at six months. J Psychosom Res. 1987;31(1):125-30. [pmid: 3820141].
86 Garcia L, Valdes M, Jodar I, et al. Psychological factors and vulnerability to psychiatric morbidity after myocardial infarction. Psychother Psychosom. 1994;61(34):187-94. [pmid: 8066156].
87 Lesperance F, Frasure-Smith N, Talajic M. Major depression before and after myocardial infarction: its nature and consequences. Psychosom Med. 1996;58(2):99-110. [pmid: 8849624].
88 Strik JJ, Lousberg R, Crijns HJ, et al. Relation of levels of serum lipoproteins to depression after acute myocardial infarction. Am J Cardiol. 2002;90(12):1368-70. [pmid: 12480046].
89 Strik JJ, Lousberg R, Cheriex EC, et al. One year cumulative incidence of depression following myocardial infarction and impact on cardiac outcome. J Psychosom Res. 2004;56(1):59-66. [pmid: 14987965].
90 Strik JJ, Honig A, Lousberg R, et al. Sensitivity and specificity of observer and self-report questionnaires in major and minor depression following myocardial infarction. Psychosomatics. 2001;42(5):423-8. [pmid: 11739910].
91 Lesperance F, Frasure-Smith N, Theroux P, et al. The association between major depression and levels of soluble intercellular adhesion molecule 1, interleukin-6, and C-reactive protein in patients with recent acute coronary syndromes. Am J Psychiatry. 2004;161(2):271-7. [pmid: 14754776].
92 Lane D, Carroll D, Ring C, et al. The prevalence and persistence of depression and anxiety following myocardial infarction. Br J Health Psychol. 2002;7(1):11-21. [pmid: 14596714].
93 Travella JI, Forrester AW, Schultz SK, et al. Depression following myocardial infarction: a one year longitudinal study. Int J Psychiatry Med. 1994;24(4):357-69. [pmid: 7737790].
94 Clarke DE, Walker JR, Cuddy TE. The role of perceived overprotectiveness in recovery 3 months after myocardial infarction. J Cardiopulm Rehabil. 1996;16(6):372-7. [pmid: 8985795].
95 Shiotani I, Sato H, Kinjo K, et al. Depressive symptoms predict 12-month prognosis in elderly patients with acute myocardial infarction. J Cardiovasc Risk. 2002;9(3):153-60. [pmid: 12202838].
96 Follick MJ, Gorkin L, Smith TW, et al. Quality of life post-myocardial infarction: effects of a transtelephonic coronary intervention system. Health Psychol. 1988;7(2):169-82. [pmid: 3371309].
97 Gilutz H, Bar-On D, Billing E, et al. The relationship between causal attribution and rehabilitation in patients after their first myocardial infarction. A cross cultural study. Eur Heart J. 1991;12(8):883-8. [pmid: 1915426].
98 Lehto S, Koukkunen H, Hintikka J, et al. Depression after coronary heart disease events. Scand Cardiovasc J. 2000;34(6):580-3. [pmid: 11214011].
99 Ahern DK, Gorkin L, Anderson JL, et al. Biobehavioral variables and mortality or cardiac arrest in the Cardiac Arrhythmia Pilot Study (CAPS). Am J Cardiol. 1990;66(1):59-62. [pmid: 2193497].
100 Ladwig KH, Kieser M, Konig J, et al. Affective disorders and survival after acute myocardial infarction. Results from the post-infarction late potential study. Eur Heart J. 1991;12(9):959-64. [pmid: 1936008].
101 Frasure-Smith N, Lesperance F, Talajic M. Depression following myocardial infarction. Impact on 6-month survival. JAMA. 1993;270(15):1819-25. [pmid: 8411525].
102 Frasure-Smith N, Lesperance F, Juneau M, et al. Gender, depression, and one-year prognosis after myocardial infarction. Psychosom Med. 1999;61(1):26-37. [pmid: 10024065].
103 Carney RM, Blumenthal JA, Catellier D, et al. Depression as a risk factor for mortality after acute myocardial infarction. Am J Cardiol. 2003;92(11):1277-81. [pmid: 14636903].
104 Druss BG, Bradford D, Rosenheck RA, et al. Quality of medical care and excess mortality in older patients with mental disorders. Arch Gen Psychiatry. 2001;58(6):565-72. [pmid: 11386985].
105 Frasure-Smith N, Lesperance F. Depression and other psychological risks following myocardial infarction. Arch Gen Psychiatry. 2003;60(6):627-36. [pmid: 12796226].
106 Frasure-Smith N, Lesperance F, Gravel G, et al. Depression and health-care costs during the first year following myocardial infarction. J Psychosom Res. 2000;48(45):471-8. [pmid: 10880668].
107 Drory Y, Kravetz S, Florian V, et al. Sexual activity after first acute myocardial infarction in middle-aged men: demographic, psychological and medical predictors. Cardiology. 1998;90(3):207-11. [pmid: 9892770].
108 Soejima Y, Steptoe A, Nozoe S, et al. Psychosocial and clinical factors predicting resumption of work following acute myocardial infarction in Japanese men. Int J Cardiol. 1999;72(1):39-47. [pmid: 10636631].
109 Drory Y, Kravetz S, Hirschberger G. Long-term mental health of men after a first acute myocardial infarction. Arch Phys Med Rehabil. 2002;83(3):352-9. [pmid: 11887116].
110 Drory Y, Kravetz S, Hirschberger G. Long-term mental health of women after a first acute myocardial infarction. Arch Phys Med Rehabil. 2003;84(10):1492-8. [pmid: 14586917].
111 Bogg J, Thornton E, Bundred P. Gender variability in mood, quality of life and coping following primary myocardial infarction. Cor Health Care. 2000;4(4):163-168.
112 Carney RM, Blumenthal JA, Stein PK, et al. Depression, heart rate variability, and acute myocardial infarction. Circulation. 2001;104(17):2024-8. [pmid: 11673340].
113 Kuijpers PM, Hamulyak K, Strik JJ, et al. Beta-thromboglobulin and platelet factor 4 levels in post-myocardial infarction patients with major depression. Psychiatry Res. 2002;109(2):207-10. [pmid: 11927146].
114 Miller TD, Taliercio CP, Zinsmeister AR, et al. Risk stratification of single or double vessel coronary artery disease and impaired left ventricular function using exercise radionuclide angiography. Am J Cardiol. 1990;65(20):1317-21. [pmid: 2343819].
115 Putini RL, Natale E, Ricci R, et al. Dipyridamole echocardiography evaluation of acute inferior myocardial infarction with concomitant anterior ST segment depression. Eur Heart J. 1993;14(10):1328-33. [pmid: 8262078].
116 Linden W, Stossel C, Maurice J. Psychosocial interventions for patients with coronary artery disease: a meta-analysis. Arch Intern Med. 1996;156(7):745-52. [pmid: 8615707].
117 Swenson JR, O'Connor CM, Barton D, et al. Influence of depression and effect of treatment with sertraline on quality of life after hospitalization for acute coronary syndrome. Am J Cardiol. 2003;92(11):1271-6. [pmid: 14636902].
118 Czajkowski SM. Effects of Treating Depression and Low Perceived Social Support on Clinical Events after Myocardial Infarction: The Enhancing Recovery in Coronary Heart Disease Patients (ENRICHD) Randomized Trial. JAMA. 2003;289(23):3106-16. [pmid: 12813116].
119 Taylor CB, Miller NH, Smith PM, et al. The effect of a home-based, case-managed, multifactorial risk-reduction program on reducing psychological distress in patients with cardiovascular disease. J Cardiopulm Rehabil. 1997;17(3):157-62. [pmid: 9187981].
120 Roose SP, Laghrissi-Thode F, Kennedy JS, et al. Comparison of paroxetine and nortriptyline in depressed patients with ischemic heart disease. JAMA. 1998;279(4):287-91. [pmid: 9450712].
121 McFarlane A, Kamath MV, Fallen EL, et al. Effect of sertraline on the recovery rate of cardiac autonomic function in depressed patients after acute myocardial infarction. Am Heart J. 2001;142(4):617-23. [pmid: 11579351].
122 Freedland KE, Skala JA, Carney RM, et al. The Depression Interview and Structured Hamilton (DISH): Rationale, development, characteristics and clinical validity. Psychosom Med. 2002;64(6):897-905. [pmid: 12461195].
123 Wojciechowski FL, Strik JJ, Falger P, et al. The relationship between depressive and vital exhaustion symptomatology post-myocardial infarction. Acta Psychiatr Scand. 2000;102(5):359-65. [pmid: 11098808].
124 Beck AT, Steer RA, Garbin JJ. Psychometric properties of the Beck Depression Inventory: Twenty-five years of evaluation. Clin Psych Research. 1988;8(1):77-100.
125 Decorato D, Derogatis AJ. Prominent gallium uptake associated with silicone implants in an asymptomatic patient. Clin Nucl Med. 1994;19(12):1107-8. [pmid: 7874816].
126 Zung WW. A Self-rating depression scale. Arch Gen Psychiatry. 1965;12:63-70. [pmid: 14221692].
127 Martin CR, Thompson DR. A psychometric evaluation of the Hospital Anxiety and Depression Scale in coronary care patients following acute myocardial infarction. Psychol Health Med. 2000;5(2):193-201.
128 Ziegelstein RC, Fauerbach JA, Stevens SS, et al. Patients with depression are less likely to follow recommendations to reduce cardiac risk during recovery from a myocardial infarction. Arch Intern Med. 2000;160(12):1818-23. [pmid: 10871976].
129 Conn VS, Taylor SG, Wiman P. Anxiety, depression, quality of life, and self-care among survivors of myocardial infarction. Issues Ment Health Nurs. 1991;12(4):321-31. [pmid: 1938339].
130 Romanelli J, Fauerbach JA, Bush DE, et al. The significance of depression in older patients after myocardial infarction. J Am Geriatr Soc. 2002;50(5):817-22. [pmid: 12028166].
131 Schreiber W, Kittler H, Pieper O, et al. Prediction of 24 h, nonfatal complications in patients with acute myocardial infarction receiving thrombolytic therapy by calculation of the ST segment deviation score. Can J Cardiol. 2003;19(2):151-7. [pmid: 12601440].
132 Blumenthal JA, Williams RS, Wallace AG. Physiological and psychological variables predict compliance to prescribed exercise therapy in patients recovering from myocardial infarction. Psychosom Med. 1982;44(6):519-27. [pmid: 7163455].
133 Whitmarsh A, Koutantji M, Sidell K. Illness perceptions, mood and coping in predicting attendance at cardiac rehabilitation. Br J Health Psychol. 2003;8(2):209-21. [pmid: 12804334].