# Acknowledgments

We thank Karen A. Robinson, M.Sc., for her guidance with the literature process and the methodology; Sachin Agarwal, M.D., M.P.H., and Teerath Tampikopongse for assistance with review of the literature; Dhwani Mankad, M.D., M.P.H., for database management and review of literature; Christine Napolitano for literature retrieval and data management; and Brenda Zacharko for preparation of tables.

We also thank our Task Order Officer, Captain Ernestine Murray, for her support with the project.