# Results

## Literature Search and Abstract Review

The literature search process identified 3,770 unique citations potentially relevant to key questions for which the EPC team evaluated primary literature (see Figure 2). Fifteen duplicate citations were found and excluded. During the title review process 2,597 citations were excluded because they did not appear to pertain to the subject. At abstract review 825 citations were found not to meet the criteria for inclusion. Abstracts were excluded for the following reasons: the article was not in English; did not include human data; did not have original data; or was a meeting abstract (hence no full article available for review). For articles related to only key question 4, the team excluded studies that did not have a concurrent comparison study; for key question 5, the team excluded articles without a validated reference model.

Figure 2. Literature Search

## Articles Eligible for Review

Following the abstract review process 318 articles were found to be eligible. Of these, 128 were tagged for key question 1 and 2; 56 were tagged for question 3; 54 were tagged for question 4; 12 for question 5; and 13 for question 6. Added together the total number of articles pertaining to key questions exceeded the actual number of articles reviewed because some articles were identified as relevant for more than one key question.

## Key Questions 1 and 2

Question 1. In patients diagnosed with and hospitalized for acute MI, what is the prevalence of depression during initial hospitalization for MI?

Question 1a. What is the prevalence of depression during initial hospitalization for MI in patients with or without a known history of depression as reported by study investigators?

Question 2. What percentage of patients with post-MI depression continue to have depression (or depressive symptoms) 1 month or longer after initial hospital discharge?

### Introduction

Most studies that examined the prevalence of depression after MI examined patients at the time of the initial hospitalization and at various times after discharge. Because question 2 refers to the percentage of patients who continue to have depression after hospital discharge, these two questions are interrelated, and therefore questions 1 and 2 are combined for the purposes of this report.

Important technical and methodological issues should be clarified before examining this review. First, depression is defined and addressed differently from study to study. For the purposes of this review, we have defined depression as “symptoms meeting established clinical threshold criteria for depression as measured by validated questionnaires or standardized psychiatric interviews.” It must be noted, however, that the manner in which “clinical threshold criteria” is interpreted varies considerably across studies. For example, one study used a score of 8 or higher on the depression subscale of the Hospital Anxiety and Depression Scale (HADS) to report a prevalence of “clinically significant levels of depression”, ^63^ whereas another used a cutoff of 11 to denote “clinical levels of depression”. ^64^ Three other studies referred to a score in the 8 to 10 range as “possibly clinically significant” or “borderline” depression and a score of 11 or higher as “probably clinically significant” depression. ^65^ – ^67^ This review found similar variability in threshold criteria and designation when other screening instruments were used. Wherever possible, this has been specifically noted given that prevalence data may become confusing when “depression” is characterized according to different threshold criteria. In addition, although the definition of depression for the purposes of this review includes measurements by validated questionnaires and standardized interviews, the former typically measure symptoms of depression whereas the latter typically use a version of the Diagnostic and Statistical Manual (DSM) to establish a diagnosis of major or minor depression or dysthymia. Again, wherever possible, this is noted in the report. Finally, it should be noted that the screening instruments typically used for depression are referred to in this report as “validated questionnaires or rating scales.” Some validation evidence is available for all of these, but the quality varies and no systematic validation has been carried out in patient populations with recent MI. Indeed, question 5 of this report addresses the performance characteristics of instruments or methods used to screen for depression after an acute MI.

Question 2 asks specifically about the percentage of patients with post-MI depression who continue to have depression (or depressive symptoms) 1 month or longer after initial hospital discharge. To address this question, a study must provide data on the prevalence of depression during the initial hospitalization and then reassess those patients with depression after hospital discharge and specifically indicate the prevalence of depression at follow-up in those patients initially depressed. Whereas data are provided in the tables (Appendix G Evidence Tables 2.1, 2.2, 2.3, 2.4) from studies that report prevalence data only at follow-up (i.e., no data were available on the prevalence of depression during the hospitalization), these studies do not specifically address question 2 and therefore are handled separately in this report. To specifically address question 2, a study would have to report the prevalence of depression at follow-up in those patients depressed during the hospitalization. Several studies reported prevalence data at hospitalization and follow-up, but did not report the prevalence of depression after discharge among the group initially depressed; these studies also are handled separately in this report.

### Results of Literature Search

After the final article review, 51 articles were eligible pertaining to question 1. Of these, 22 were studies reporting data that were also reported in at least one other study. For example, some investigators reported the prevalence of in-hospital depression and outcome at 6 months. In another study by the same investigators, the prevalence of in-hospital depression was again reported but with a 12-month outcome. In such instances, only one article was considered eligible for question 1. After these 22 articles were excluded, 5 others were excluded because the prevalence of depression was determined by using a non-standard screening instrument for which no validation was provided. This left 25 articles for question 1.

After article review, 30 articles were eligible pertaining to question 2. One of these was excluded as duplicative, and six others were excluded because the prevalence of depression was determined by using a non-standard screening instrument for which no validation was provided. One study was excluded because the follow-up data were collected 2 weeks after discharge rather than the minimum 1 month after discharge that was required for this question. This left 22 articles for question 2. Of these 22 articles, seven reported prevalence data both at hospitalization and follow-up. However, only three of these separately reported prevalence data at follow-up for those depressed during hospitalization. The other four articles and the 15 that reported only follow-up data are reported separately because they did not directly address question 2.

### Characteristics of Studies

Tables are presented separately for questions 1 and 2 (see Tables 1 and 2, and Appendix G). In Evidence Table 1 and 2 (Appendix G) for each question we have summarized the study aims, number of subjects included, and study quality scores for the 24 studies for question 1 and the 22 studies for question 2. The articles were published between 1986 and 2004.

Of the 25 articles for question 1, eight used a standardized clinical interview for the diagnosis of depression (e.g., Structured Clinical Interview or the Diagnostic Interview Schedule). ^58^ , ^68^ – ^74^ One of these ^72^ interviewed patients within a month of their MI, but the exact timing of the assessment relative to the hospitalization is unclear, and so data from this study are not included in summary tabulations. Seventeen used one or more validated questionnaires or rating scales such as the Beck Depression Inventory (BDI), ^25^ , ^74^ – ^81^ Hamilton Rating Scale for Depression (HAMD), ^78^ , ^82^ HADS, ^63^ – ^67^ Montgomery and Asberg Depression Rating Scale, ^83^ or Symptom Check List-90 (SCL-90) Depression Subscale. ^84^

Of the 22 articles for question 2, nine used a standardized clinical interview for the diagnosis of depression. ^10^ , ^69^ , ^85^ – ^91^ Seventeen used one or more validated questionnaires or rating scales such as the BDI, ^10^ , ^75^ , ^76^ , ^78^ , ^80^ , ^81^ , ^88^ , ^89^ , ^92^ HAMD, ^10^ , ^78^ , ^93^ Zung Depression Rating Scale (ZDS), ^94^ , ^95^ HADS, ^10^ , ^64^ , ^66^ , ^88^ , ^89^ or SCL-90 Depression Subscale. ^10^ , ^84^ , ^88^ , ^89^ , ^96^

### Quality of Studies

As shown in Appendix G Table 1.3, the number of eligible studies on question 1 with scores greater than 50 percent for given study quality categories were as follows: 18 for representativeness of the study population, none for description of therapy and management, 20 for description of the assessment protocol, nine for reporting of outcomes and follow-up, and four for statistical analyses. Only 13 studies reported information about potential conflicts of interest. As indicated in Appendix G Table 2.3, the number of eligible studies on question 2 with scores greater than 50 percent for the following study quality categories were 18 for representativeness of the study population, only one for description of therapy and management, 14 for description of the assessment protocol, 12 for reporting of outcomes and follow-up, and four for statistical analyses. Only nine of these studies reported information about potential conflicts of interest.

### Results of Studies

1. In patients diagnosed with and hospitalized for acute MI, what is the prevalence of depression during initial hospitalization for MI? (Table 1)
  Table 1.1 (Appendix G) describes the patient populations and prevalence of depression during the initial MI hospitalization. Table 1.2 (Appendix G) describes the patient populations and prevalence of depression 1 month or longer after hospital discharge.
  Of the 25 articles for question 1, seven included fewer than 100 subjects, ^63^ , ^64^ , ^68^ , ^73^ , ^75^ , ^76^ , ^80^ and 17 studied more than 100 individuals. ^25^ , ^58^ , ^65^ – ^67^ , ^69^ – ^72^ ^77^ – ^79^ , ^81^ – ^84^ , ^97^ The range of subjects studied was 37 to 2,481 patients. Thirteen studies were from the United States and/or Canada, ^25^ , ^58^ , ^68^ – ^72^ , ^74^ – ^76^ , ^78^ , ^80^ , ^82^ and 12 studies were from Europe. ^63^ – ^67^ , ^73^ , ^77^ , ^79^ , ^80^ , ^83^ , ^84^ , ^97^ The mean age of study subjects ranged from 52 to 67 years. Sex was reported in all but two studies; men alone were studied in three reports and the remainder reported depression prevalence from a population mix of men and women. Only three of 25 studies reported race; ^58^ , ^70^ , ^78^ in these three, non-whites made up 33 to 38 percent of the sample. Nine studies reported the prevalence of individual cardiac risk factors ^25^ , ^58^ , ^67^ , ^68^ , ^71^ , ^74^ , ^77^ , ^80^ , ^84^ ; whereas one study reported the aggregate number of cardiac risk factors in the population. ^76^ Killip class and/or LVEF was reported in seven studies. ^25^ , ^69^ – ^71^ , ^73^ , ^74^ , ^81^ All studies reported depression prevalence data from MI survivors alone or from a study sample in which prevalence data from MI survivors were reported separately.
  Although in question 1a the prevalence of depression in patients with a history of depression (as reported by study investigators) was to be addressed, only two studies reported history of depression, ^71^ , ^78^ and none provided separate prevalence data for this segment of the sample. Therefore, there is insufficient evidence to answer this question.
  The prevalence of depression ranged from 17 to 27 percent in the seven studies that used a Structured Clinical Interview for DSM IV (SCID) to establish the diagnosis. The largest of these studies, the ENRICHD study, ^58^ which examined 2,481 patients, reported a prevalence of 20 percent with major depression.
  In the 17 studies that used a validated questionnaire or rating scale, 10 to 47 percent of patients had symptoms of depression considered above a clinical threshold criterion. Of the nine studies that used the original version of the BDI, five used a cutoff score of 10 or higher. ^25^ , ^74^ , ^77^ , ^78^ , ^80^ , ^81^ The prevalence of at least mild to moderate symptoms of depression using a cutoff of 10 or higher on the BDI was 21 to 37 percent. In the four studies that used a HADS cutoff score of 8 or higher, ^63^ , ^65^ – ^67^ the prevalence of possible clinical depression was 11 to 18 percent. In the four studies that used a HADS cutoff score of 11 or higher, ^64^ – ^67^ the prevalence of probable clinical depression was 6 to 13 percent.
  In summary, the prevalence of major depression during the initial MI hospitalization is fairly consistent across studies. Based on these studies, about one of every five patients has major depression during the initial MI hospitalization. By contrast, the prevalence of different levels of depressive symptoms varies more widely across studies assessed by questionnaire or rating scale. Variation in screening instruments used, as well as variation in cutoff criteria within instruments, may account for the difference. It is impossible given current research on the assessment of depression in MI patients to compare “possible clinical depression” based on a HADS depression subscale with “at least mild-to-moderate symptoms of depression” based on a BDI. In general, the prevalence of symptoms of depression that meet standard threshold criteria on the BDI (10 or higher) is greater than that using the HADS (either 8 or higher or 11 or higher) in patients during the initial MI hospitalization. For example, the two studies in this report that included the most patients used the BDI for 870 patients, reporting a prevalence of 32 percent ^25^ and the HADS for 688 patients, reporting prevalences of 18 percent and 10 percent depending on the cutoff. ^64^ This is consistent with the prevalence ranges for all studies using these two instruments as noted above. This discrepancy is not surprising in that the BDI includes somatic symptoms that may overlap with MI symptoms in hospitalized patients, whereas the HADS is designed for use in hospitalized patients and does not include somatic symptoms.
  As summarized in Evidence Grade Table 1, we concluded that the overall body of evidence on question 1 merited a medium quantity of evidence and reasonable quality of evidence despite the presence of some inconsistencies in the evidence.
2. What percentage of patients with post-MI depression continue to have depression (or depressive symptoms) 1 month or longer after initial hospital discharge? (Table 2)
  The three studies that specifically addressed question 2 were from North America and reported data on 52 patients (mean age 51 years; 90 percent male), ^75^ 335 patients (mean age 64 years; 64 percent male), ^69^ and 550 patients (mean age 60 years; 79 percent male). ^81^ None of these studies reported race, only one reported on cardiac risk factors, ^81^ and two reported Killip class and/or LVEF. ^69^ , ^81^
  Nineteen of the studies reported the prevalence of depression at least 1 month after hospital discharge, but they did not address question 2 specifically. Of these studies, eight included fewer than 100 subjects, ^64^ , ^76^ , ^80^ , ^84^ – ^86^ , ^93^ , ^94^ and 11 studied more than 100 individuals. ^10^ , ^66^ , ^87^ – ^92^ , ^95^ , ^96^ , ^98^ The range of study subjects was from 32 to 1,042 patients. Six studies were from the United States and/or Canada, ^76^ , ^87^ , ^88^ , ^91^ , ^93^ , ^96^ 12 studies were from Europe, ^10^ , ^64^ , ^66^ , ^80^ , ^84^ – ^86^ , ^89^ , ^90^ , ^92^ , ^94^ , ^98^ and one was from Asia. ^95^ The mean age of study subjects ranged from 50 to 67 years. Men alone were studied in four reports, ^84^ – ^86^ , ^94^ and the remainder reported depression prevalence from a gender-mixed population. Only three of 19 studies reported race. ^90^ , ^92^ , ^93^ Three studies reported information on only one cardiac risk factor, ^85^ , ^87^ , ^96^ six studies reported information on multiple cardiac risk factors, ^84^ , ^89^ , ^91^ , ^92^ , ^95^ , ^98^ and one study reported the average number of risk factors per study subject. ^76^ Killip class and/or LVEF was reported in five studies. ^87^ , ^88^ , ^91^ , ^92^ , ^95^ Two studies included patients without MI, ^85^ , ^91^ but in both of these studies, more than 80 percent of the patients were MI survivors. The other 17 studies reported depression prevalence data from MI survivors alone or from a study sample in which prevalence data from MI survivors were reported separately.
  Three studies reported prevalence data at follow-up for those depressed during the initial MI hospitalization and therefore specifically addressed question 2. These studies reported follow-up data at 30 days after MI, ^81^ 6 to 8 weeks after MI, ^75^ and 3 to 4 months after MI. ^69^ A study by Davis and Jensen ^75^ used the BDI to assess 52 patients during the initial hospitalization and again at follow-up. Of the five patients who were assessed as “clinically depressed” during the hospitalization (BDI of 13 or higher), three (60 percent) were still depressed 6 to 8 weeks later when the same BDI cutoff was used. Schleifer et al. ^68^ studied 335 patients during the initial MI hospitalization and reported both in-hospital and follow-up data in 190 patients. Of these 190 patients, 30 had major depression (15.8 percent) and 51 had minor depression (26.8 percent) according to a SCID performed during the initial hospitalization. Of the 30 patients with major depression at baseline, 11 (36.7 percent) still had major depression 3 to 4 months later and another 11 (36.7 percent) had minor depression. The total number of patients with either major or minor depression at follow-up was therefore 73.3 percent of those with major depression at baseline. Of the 51 patients with minor depression during the initial MI hospitalization, eight (15.7 percent) had major depression at follow-up and another 11 (21.6 percent) had minor depression. The total number of patients with either major or minor depression at follow-up was 37.3 percent of those with minor depression at baseline. Lauzon et al. ^81^ used the BDI to evaluate 550 patients during the initial MI hospitalization. They reported a prevalence of clinically significant depressive symptoms (BDI of 10 or higher) as 34.7 percent at baseline. Of these 550 patients, 466 were re-evaluated using a BDI 30 days later. These authors reported that of patients depressed at baseline, 70 percent continued to be depressed at 30 days; the breakdown of patients with and without depression in those lost to follow-up was not reported. In these three studies, the majority of patients with clinically significant depression during the initial MI hospitalization remained depressed when assessed 1 to 4 months later.
  As summarized in Evidence Grade Table 1, we concluded that the overall body of evidence on question 2 merited a medium quantity of evidence and reasonable quality of evidence despite the presence of some inconsistencies in the evidence (see Appendix F).

## Key Question 3

Question 3. What is the association of various measures of depression with outcomes in patients with acute MI, independent of other known predictors of post-MI outcomes?

Question 3a. What is the association of various measures of depression with surrogate markers of cardiac risk in patients with acute MI, independent of known predictors of post-MI outcomes?

### Introduction

A number of studies have reported that depression after an MI is associated with increased mortality and poorer outcomes on a variety of psychosocial and health-related variables. However, not all of these studies accounted for the potential role of confounding factors that might have influenced these observations, including cardiovascular disease severity, socioeconomic factors, psychological variables, and psychiatric conditions apart from depression. To better understand the role of depression per se in predicting negative outcomes after an acute MI, we reviewed the English language literature for articles that evaluated the relationship between depression in days to weeks following an acute MI and a variety of health and psychosocial outcome measures.

We also reviewed the literature for articles that examined the relation between post-MI depression and surrogate markers of cardiac risk that might be associated with adverse outcomes—e.g., increased ventricular arrhythmias, reduced HRV, higher levels of inflammatory markers, and abnormal platelet function.

### Results of Literature Search

After final article review, there were 33 articles that reported on 27 different patient cohorts addressing question 3 or 3a. Thirty articles were eligible for question 3. Of these, 16 articles reported data on survival. ^6^ , ^22^ – ^25^ , ^40^ , ^58^ , ^74^ , ^77^ , ^99^ – ^105^ Four of these articles were by Frasure-Smith and colleagues reported on the same cohort of patients or a subset at different times or with somewhat different analyses. ^25^ , ^101^ , ^102^ , ^105^ Similarly, Lane et al. reported on a single patient cohort at three different times. ^23^ , ^40^ , ^77^ Also, one included article was from the ENRICHD study ^58^ and reported cardiac events in depressed patients who received and did not receive a psychosocial intervention. Another study compared a subsample of patients from ENRICHD with depression to a population of patients who had neither depression nor low perceived social support. ^74^ This study ^74^ and the ENRICHD study ^58^ were considered separate studies and reported as such in this review. Thus, we found 11 independent studies with data on survival. Six studies reported data on cardiac events. ^24^ , ^52^ , ^84^ , ^89^ , ^95^ , ^106^ Data on sudden cardiac death from one study ^24^ were included in both the survival and cardiac events categories. Twelve articles from 11 independent studies reported data on QOL. ^6^ , ^23^ , ^40^ , ^63^ , ^65^ , ^67^ , ^93^ , ^107^ – ^111^ Two of these articles reported data from the same study on different outcomes related to QOL. ^107^ , ^109^ Three of the studies that reported data on QOL also reported data on survival. ^6^ , ^23^ , ^40^ Three studies, published between 2001 and 2004, reported data for question 3a. ^91^ , ^112^ , ^113^ Articles meeting criteria for inclusion in the review of this key question are shown in Tables 3, 4, 5, 6 and Appendix G (Evidence Tables 3.1, 3.2, 3.3 and 3.4).

### Characteristics of Studies

Tables are presented separately for each type of outcome addressed in question 3 and for question 3a (see Tables 3, 4, 5, 6 and Appendix G). In the first Evidence Table (Appendix G) for each type of outcome, we have summarized the study aims, design, setting, geographical area, and time period of data collection for the studies. The articles related to question 3 were published between 1990 and 2004, which included studies published from 1990 to 2003 for survival, from 1999 to 2004 for cardiac events, and from 1994 to 2003 for QOL. The studies with data relevant to question 3a were published between 2001 and 2004.

Tables 3 and Appendix G (Evidence Tables 3.1A, 3.2A, 3.3A and 3.4A) describe subject populations included in the 17 studies that assessed the relation of post-MI depression to survival. All studies were prospective, and evaluated the potential relation of depression (or depressed mood), assessed at a single point in time shortly after MI, to survival at various time points thereafter (4 months, ^40^ , ^74^ 6 months, ^100^ , ^101^ 1 year, 1½ years, 2 years, 3 years, 5 years, and 10 years). Some studies only reported data on cardiac mortality ^6^ , ^40^ , ^100^ , ^102^ , ^105^ or sudden cardiac death, whereas others reported death from all causes. ^23^ , ^25^ , ^40^ , ^58^ , ^74^ , ^77^ , ^101^ , ^103^ – ^105^ Some of the studies ^114^ did not distinguish between depressed and nondepressed groups, but instead reported the association between depressed mood, as a continuous variable, and death. One study ^58^ evaluated the influence of psychosocial treatment for depression on cardiac death in patients with post-MI depression.

Among the six studies that reported data on cardiac events (Table 4), there were three prospective cohort studies, two retrospective cohort studies, and one randomized clinical trial. All 11 independent studies with QOL outcome data were prospective cohort studies (Table 5). All three studies related to surrogate markers of cardiac risk were prospective cohort studies (Table 6).

Of the 12 articles that addressed QOL, the number of subjects ranged from 62 ^110^ to 347. ^65^ One study was from the United States, ^93^ seven from Europe, ^23^ , ^6^ , ^40^ , ^63^ , ^65^ , ^67^ , ^111^ three from the Middle East, ^107^ , ^109^ , ^110^ and one from Asia. ^108^ The patient's sex was reported in all studies; men alone were studied in three reports, women alone in one report, and the remaining studies reported on QOL outcome in a gender-mixed population.

As shown in Table 3a-1, the three studies that evaluated a surrogate marker of cardiac risk in patients with or without post-MI depression each evaluated a different marker. One study evaluated HRV, ^112^ another assessed levels of platelet-derived substances as a surrogate maker for platelet activity, ^113^ and another evaluated inflammatory markers. ^91^

### Quality of Studies on Depression and Survival

As summarized in Evidence Table 3.3A in Appendix G, the numbers of studies that had scores greater than 50 percent in the study quality categories were as follows: 12 for representativeness of the study population, zero for description of therapy and management, nine for description of the assessment protocol, 12 for reporting of outcomes and follow-up, and 13 for statistical analyses. Only eight studies reported information on potential conflicts of interest.

### Quality of Studies on Depression and Cardiac Events

As summarized in Evidence Table 3.3B in Appendix G, the numbers of studies on cardiac events that had scores greater than 50 percent in the study quality categories were as follows: four for representativeness of the study population, one for description of therapy and management, one for description of the assessment protocol, three for reporting of outcomes and follow-up, and four for statistical analyses. Only three studies reported information on potential conflicts of interest.

### Quality of Studies on Depression and Quality of Life

As summarized in Evidence Table 3.3C in Appendix G, the numbers of studies on QOL that had scores greater than 50 percent in the study quality categories were as follows: eight for representativeness of the study population, zero for description of therapy and management, six for description of the assessment protocol, nine for reporting of outcomes and follow-up, and nine for statistical analyses. Only six studies reported information on potential conflicts of interest.

### Quality of Studies on Depression and Surrogate Markers of Cardiac Risk

As shown in Evidence Table 3a.3 in Appendix G of the three studies meeting eligibility criteria for question 3a, the following numbers of studies had scores of at least 50 percent for the given criteria: one for representativeness of the study population, one for description of therapy, two for reporting outcomes and follow-up, three for description of assessment protocol and statistical analysis, and one for conflict of interest disclosure.

### Results of Studies on Depression and Survival

Two studies assessed the relation between post-MI depression and mortality 4 months after MI ^40^ , ^101^ and differed in their conclusions (See Table 3 and Evidence Table 3.4A in Appendix G). In particular, one article reported that baseline depression, as measured using the BDI, was unrelated to 4-month survival. ^40^ In contrast, the other study ^101^ found depression (BDI score greater than or equal to 10) to be an independent predictor of mortality 4 months later. Further, this study found that higher levels of depression were associated with an increased risk for death, and that even subthreshold levels of depression (BDI scores of 4 to 9) were associated with an increased risk for death in these patients.

Two studies evaluated the relationship between post-MI depression and death 6 months after an MI. One study ^101^ found depression, as measured using the National Institute of Mental Health Diagnostic Interview Schedule (DIS), to be an independent predictor for mortality, while adjusting for a variety of relevant covariates (see Evidence Table 3-4). All deaths in this population were secondary to cardiac events. The second study ^100^ used non-English-language standard diagnostic instruments for measuring depression, and divided patients into low, medium, and high levels of major depression symptoms. These authors found that high levels of post-MI depression were predictive of cardiac mortality, even when accounting for other potential covariates (see Evidence Table 3.4A in Appendix G).

Four studies assessed mortality rates in post-MI depressed patients 1 year after the index event. One of these studies ^102^ involved patients that were included in two other studies covered in this evidence report. ^25^ , ^115^ In addition to assessing the potential relation of depression to mortality, this study evaluated the potential influence of the person's sex on mortality in these patients. The study's major conclusion was that depression, which was a predictor of death at 3 months, remained a significant risk factor for death 1 year after MI. Gender did not appear to influence this risk, which was largely independent of other post-MI risks for death. A second study ^114^ assessed depression on a continuous scale using the BDI and found that increased depression scores predicted mortality, after statistical adjustment for known cardiac risk factors. Another study, ^23^ which appears at odds with this conclusion, found that depression, measured using the BDI, did not predict either cardiac or all-cause mortality after MI.

Four studies evaluated patients approximately 1½–3 years after an MI. ^12^ , ^24^ , ^58^ , ^77^ Two studies involved a subgroup of patients in the ENRICHD trial who have been described elsewhere in this evidence report. The ENRICHD study ^58^ evaluated the influence of treatment with cognitive behavioral therapy (and, when indicated, an SSRI) on post-MI patients with depression or low perceived social support. Depression was assessed using the DIS. At 29 months of follow-up, there were no differences in survival in the treated versus the untreated patients, nor were there differences in survival between patients in the depressed and low perceived social support groups. A substudy of ENRICHD ^74^ compared depressed and nondepressed patients and found that depression was an independent risk factor for death after an acute MI, but the effect did not appear until nearly a year after the index event.

Two other studies reported on the 3- to 4-year survival of post-MI patients who had been evaluated for depression at the time of their index event. One study ^24^ evaluated the risk of sudden cardiac death 4 years after an MI and found that increased depressive symptoms (BDI score greater than or equal to 10) during the initial MI hospitalization were associated with a more than two-fold increase in mortality 4 years later. In contrast to these findings, another study ^77^ found that a BDI score of at least 10 after an MI did not predict survival 3 years after. Although the patients in these two trials were similar in age (63 years) and gender (75–82 percent) male the patient populations of the two studies differed significantly. The study of Irvine et al ^24^ was performed in post-MI patients with frequent PVCs. Depression was assessed 2 to 4 weeks after the index MI. In this study the overall two-year mortality was 9.4 percent (63/671) with a cardiac mortality of 7.5 percent 50/671 and among those with cardiac deaths 68 percent (34/50) were sudden. In contrast, in the study of Lane et al ^77^ depression was assessed during the index hospitalization. The overall mortality was 13 (38/288) with a cardiac mortality of 11 percent (33/288). However, of the cardiac deaths only 9 percent were sudden (3/33) and accordingly many more deaths were due to recurrent ischemic events 60 percent (20/33) or heart failure 30 percent (10/33). Authors of both of these studies ^24^ , ^77^ hypothesized that somatic symptoms of depression and/or disease severity may be more predictive of death than is depression per se.

Three studies, ^6^ , ^25^ , ^105^ compared mortality rates in depressed patients versus non depressed patients 5 years after an acute MI. In one study, ^6^ patients were considered depressed when they scored in the upper tertile on a measure of depression. Symptoms of depression were not associated with an increased mortality risk, 5 years later. A second study, ^25^ conducted in a cohort of patients that had been previously evaluated 1 year post-MI, ^102^ found that post-MI depression was more closely linked to mortality 5 years after MI than 1 year after MI. Another study by the same group of researchers ^105^ assessed the relation of depression, anxiety, and general health in post-MI patients to mortality 5 years after the index event. They concluded that an unidentified, but unique, aspect of depression predicts long-term cardiac mortality post-MI.

A single study ^102^ reported on mortality in depressed post-MI patients 10 years after the index event. As with most of the studies that assessed the relationship between depression and mortality at earlier time points, this study found that death following MI was positively and independently associated with depressed mood, as measured by the ZDS.

As summarized in Evidence Grade Table 2, we concluded that the overall body of evidence on question 3, looking at survival as an outcome, merited a medium quantity of evidence and high quality of evidence (see Appendix F).

### Results of Studies on Depression and Cardiac Events

Six studies reported data on cardiac events, as shown in Evidence Table 3.4B in Appendix G. Irvine and colleagues ^24^ evaluated 671 patients within 6 to 45 days of acute MI who participated in the Canadian Amiodarone Myocardial Infarction Arrhythmia Trial. Subjects eligible for this trial had frequent ventricular ectopy (at least 10 PVCs per hour) and were administered multiple screening questionnaires, including the BDI and the SCL-90, as well as measures of hostility, social support, and social participation. The average age of study subjects was 63.8 years and most were married men. About one quarter of the sample had a history of heart failure and about one third had a history of prior MI. There were 34 sudden cardiac deaths after 2 years of follow-up. In the Cox proportional hazards model, biological predictors of sudden cardiac deaths were prior MI (relative risk, 2.86; 95 percent CI, 1.37 to 5.99) and prior congestive heart failure (relative risk, 3.86; 95 percent CI, 1.89 to 7.89). Scores of 10 or higher on the BDI were also associated with a significantly increased risk for sudden cardiac death, SCD (relative risk, 2.45; 95 percent CI, 1.14 to 5.35). When symptoms of fatigue were considered in the multivariate model, the contribution of depression was no longer significant (relative risk, 1.73; 95 percent CI, .076 to 3.98). When cognitive affective symptoms were considered separately, the relationship between mood and SCD was of borderline significance (relative risk, 1.09; 95 percent CI, 0.99 to 1.19). Thus, depressive symptoms were associated with an increased risk of sudden cardiac death, but this relation was no longer present when symptoms of fatigue were controlled for.

Shiotani et al. ^95^ evaluated 1,042 consecutive patients for symptoms of depression with the ZDS within 3 months of acute MI. Patients with depression over age 65 had significantly higher cardiac event rates during the first year after MI than did patients over age 65 without depression. There was a trend toward an association of depression and cardiac events in younger patients, but this did not reach statistical significance (p = 0.11).

Druss et al. ^52^ evaluated a group of over 100,000 Medicare patients who sustained an MI, approximately 5 percent of whom had mental illness. Of the group of patients with mental illness, some had an affective disorder (major depression, dysthymia, or bipolar disorder). The group of patients with a mental illness, as well as the subgroup of patients with an affective disorder, had a lower likelihood of receiving cardiac revascularization procedures (percutaneous transluminal coronary angioplasty, PTCA or coronary artery bypass graft surgery, CABG) during the initial MI hospitalization than did the group of patients without mental illness. In a study such as this one, cardiac revascularization procedures may be treated either as an MI treatment or as an outcome variable (i.e., a cardiac event), and therefore this study was included in this question.

Frasure-Smith et al. ^106^ studied 848 MI survivors and reported cardiac readmissions and procedures during the first year of follow-up. These authors found that depression (BDI score of 10 or higher) during the initial MI hospitalization was associated with a significantly increased number of cardiac readmissions and days of hospitalization. There was no relationship of depression during the initial MI hospitalization and cardiac procedures (cardiac catheterization, angioplasty, or coronary bypass surgery) in the first year post-MI.

Strik et al. ^84^ studied 315 men who completed measures of emotional distress, including depression, within the first month after the initial MI hospitalization. These authors then measured major adverse cardiac events, defined as cardiac death or recurrent MI, over an average follow-up period of 3.4 years. Although depression alone was a significant predictor of cardiac events (including cardiac death), this relation disappeared when a measure of anxiety was included in the multivariate model.

In a subsequent study with similar methodology, Strik et al. ^89^ found similar results with a sample of 206 men and women followed for 3 years after their first MI.

As summarized in Evidence Grade Table 2, we concluded that the overall body of evidence on question 3, looking at cardiac events as an outcome, merited a medium quantity of evidence and reasonable quality of evidence despite the presence of some inconsistencies in the evidence (see Appendix F).

### Results of Studies on Depression and Quality of Life

Studies that addressed QOL measures reported the relation of depression during the initial MI hospitalization to physical-behavioral function, ^6^ , ^23^ , ^40^ , ^65^ , ^67^ , ^93^ , ^111^ psychological well-being, ^6^ , ^63^ , ^65^ , ^67^ , ^109^ – ^111^ social and work role performance, ^6^ , ^23^ , ^65^ , ^93^ , ^107^ , ^108^ , ^111^ and personal perception of health ^6^ , ^23^ , ^65^ (See Table and Evidence Table 3-4 in Appendix G). Several studies reported on multiple aspects of health-related QOL. Some studies reported the relation of depression at the time of the initial MI hospitalization to QOL measures within the first 12 months post-MI, ^63^ , ^67^ , ^107^ , ^108^ , ^111^ whereas others reported on the relation to QOL at least 12 months post-MI. ^6^ , ^110^ Two articles reported on the same sample at 4-month follow-up ^40^ and at 12-month follow-up. ^23^ Three studies reported on both near- and long- term outcome. ^65^ , ^93^ , ^109^

One study reported that depression as assessed by the HADS during the initial MI hospitalization was prospectively associated with a reduced score on the mental component of the short-form health survey (SF-36 Mental Component Score) but not with the SF-36 Physical Component Score at 5 months post-MI. ^67^ Another study found that in-hospital depression for females and 1-month post-MI depression for males were prospectively related to the physical domain of QOL at 6 months as assessed by the Quality of Life After MI measure. ^111^ This study also reported that social aspects of QOL at 6 months were predicted by in-hospital and 1-month depression for women but not for men and that 6-month psychological QOL was not related to depression at either earlier time for either sex. ^111^ In-hospital depression measured with the BDI was prospectively related to sexual activity and sexual satisfaction of men 3 to 6 months post-MI in a multivariate analysis controlling for demographic (e.g., age, education) and medical (e.g., Killip class, diabetes mellitus) variables. ^107^ One study among Japanese men documented that in-hospital symptoms of depression after an MI were prospectively related to dichotomously measured return to work in multivariate analysis, but not to time until work resumption or returning to work at a reduced capacity. ^108^ Thus, during the 1-year rehabilitation period, post-MI depression has been found to be related to physical QOL, social QOL of women, sexual activity and satisfaction among men, return to work of employed men, and health care utilization.

Another study found that QOL 4 months after MI measured with Dartmouth Primary Care Cooperative Information Project (COOP) charts (combining physical, social, role functioning, general health, pain, change in health, social support, and perceived health) was related to in-hospital depression (BDI), having a partner, MI severity and state anxiety, even after controlling for sociodemographic, activity, and illness variables. ^40^ In a follow-up of this sample, ^23^ depression, living alone, MI severity (Peel Index score), and state anxiety were found to be independent predictors of 12-month QOL, even when controlling for sociodemographic, activity, and illness variables.

The three repeated-measures studies in this section had remarkable consistency across short-term and long-term follow-ups. Individuals with high in-hospital distress (i.e., above established cutoffs for either HADS-depression or HADS-anxiety scales) scored significantly lower on all eight subscales of the SF-36 (four physical and four psychosocial) at 3-month follow-up. ^65^ The mean HADS-depression score for the distressed group was significantly higher than for the nondistressed group. Consistent with the 3-month follow-up data, individuals with high in-hospital distress scored significantly lower on all eight subscales of the SF-36 at the 12-month follow-up. ^65^ DSM-III depressive disorder diagnosed in-hospital with use of the Present State Exam was associated with poorer physical functioning and greater depression severity only at discharge, and with less social connectedness only at the 6-month follow-up, whereas social functioning was significantly worse at the 3-, 6-, 9- and 12-month follow-ups. ^93^ The third repeated-measures study found that in-hospital depression measured with the BDI was significantly related to psychological distress among male survivors of MI as measured by using the Mental Health Inventory at the 3- to 6-month post-MI follow-up, with controlling for sociodemographic and medical variables. ^109^ Furthermore, psychological distress at 3 to 6 months moderated the effect of in-hospital depression on psychological distress at the 5-year follow-up among male survivors of MI, also with controlling for sociodemographic and medical variables. ^109^ Thus, at both early and late follow-up times, in-hospital depression has been shown to be related to physical, psychological, and social health and function.

The 5-year QOL outcomes of patients with acute MI were examined in two studies. In-hospital depression measured with the BDI was significantly related to psychological well-being of women at the 5-year post-MI follow-up, as measured using the Mental Health Inventory and controlling for sociodemographic and medical variables. ^110^ Similarly, among female survivors of MI, in-hospital depression and self-reported concomitant medical problems were related to psychological distress 5 years later. ^110^ One 5-year outcome study used cutoffs on the Health Complaint Scale's somatic complaints and disability subscales to define poor QOL. Multivariate analysis found a significant relation between symptoms of depression (ZDS) and poor QOL. ^6^ Thus, even 5 years after MI, psychological distress and physical health and functioning were related to in-hospital depression independent of other important QOL determinants.

As summarized in Evidence Grade Table 2, we concluded that the overall body of evidence on question 3, looking at quality of life outcomes, merited a medium quantity of evidence and low quality of evidence despite the presence of some inconsistencies in the evidence (see Appendix F).

### Results of Studies on Depression and Surrogate Markers of Cardiac Risk

Three studies reported data on surrogate markers of cardiac risk. (See Table Evidence Table 3-1, 3-2, 3-3, and 3-4 in Appendix G.) Carney et al. evaluated HRV in 673 patients with acute MI between October 1997 and January 2000 who were screened for participation in the ENRICHD trial. ^112^ The depressed subjects were eligible if they had a DSM-IV diagnosis of major or minor depression and a BDI score of 10 or higher within 28 days of admission for acute MI. The control group consisted of patients who were otherwise eligible for ENRICHD but did not meet the depression or social isolation criteria. Major exclusions included atrial fibrillation or flutter, the presence of an implanted electronic cardiac pacemaker, severe medical or severe psychiatric comorbidity, cognitive impairment, or substance abuse. Spectral HRV analysis was performed from ambulatory electrocardiographic monitors for the following bands: ultra low frequency (ULF, 1.15 × 10-5 Hz), very low frequency (VLF, 0.033 to 0.04 Hz), low frequency (LF, 0.04 to 0.15 Hz), and high frequency (HF, 0.15–0.40 Hz).

All log-transformed indices of HRV were significantly lower in the 307 patients with depression than in the 365 without depression. The depressed patients were significantly younger (mean of 57.1 years versus 60.9 years), more likely to be female (49.5 percent versus 32 percent), more likely to have diabetes mellitus (34.5 percent versus 22.1 percent), and more likely to smoke cigarettes (40.7 percent versus 23.5 percent). After adjustment for the baseline demographic differences, depression remained significantly associated with lower indices of all parameters of HRV except HF power. This study is consistent with greater autonomic dysregulation among post-MI patients with depression as compared with post-MI patients without depression.

Kuijpers et al. studied platelet function after a first MI in 24 patients, 12 of whom met DSM-IV criteria for major depression and 12 of whom did not. ^113^ There were 10 men and two women in each group; the mean age was 48.0 years in the depressed group and 49.8 years in the group without depression (see Evidence Table 3a-2 in Appendix G). In the depressed group, five patients smoked and one was hypertensive; in the non-depressed group, three smoked and six were hypertensive. At the time of the study all patients in the depressed group were taking aspirin. In the group without depression, 11 were using aspirin and one was using warfarin. Nondepressed patients were more likely than depressed patients to use ACE inhibitors (nine nondepressed patients versus four depressed patients) and nitrates (four nondepressed patients versus one depressed patient). Platelet factor 4 was significantly higher in patients with depression than in those without depression (mean 17.75 IU/mL versus 9.25 IU/mL, p = 0.02). Depressed patients tended to have higher levels of platelet beta-thromboglobulin (mean rank 15.04 IU/mL vs. 9.96 IU/mL, p = 0.08). Although the sample size of this study was small, the results suggest that despite the use of aspirin, patients with post-MI depression have higher levels of platelet activity.

Lesperance and colleagues reported on the relationship between inflammatory markers and depression in patients with ACS. ^91^ These authors studied patients 23 to 120 days after discharge from the hospital with a diagnosis of ACS between August 1999 and August 2002 (see Evidence Table 3a-2 in Appendix G). Altogether, 481 patients participated in this study, of whom 35 met DSM-IV criteria for the diagnosis of major depression according to the SCID. Of the 446 patients without depression, 367 (82 percent) had an MI and 74 percent of the depressed patients had an MI. The investigators measured levels of IL-6, soluble intercellular adhesion molecule-1 (sICAM-1), and CRP. Of these inflammatory markers only sICAM-1 was found to differ between depressed and nondepressed patients (mean 5.34 mg/mL versus 5.20 mg/mL). A number of characteristics were associated with higher levels of sICAM-1: older age, female sex, smoking, prior MI or coronary revascularization, metabolic syndrome, body mass index, use of antidepressants or adenosine diphosphate inhibitors, and not taking statins. After adjustment for sex, current smoking, and the presence of metabolic syndrome, depression remained a significant factor associated with higher sICAM-1 levels (p = 0.04). When the current use of antidepressants was included in the model, the effect of major depression was somewhat attenuated (p = 0.06). A significant interaction between depression and the use of statins was found with respect to CRP levels. Among those patients not taking a statin, those with current depression had significantly higher levels of CRP than those without depression. The results of this study demonstrate that patients with depression after ACS have higher levels of some inflammatory mediators that previously have been associated with an increased of coronary disease. However, this particular study, because of its cross-sectional design, could not establish whether these inflammatory markers were increased before the index event.

As summarized in Evidence Grade Table 3, we concluded that the overall body of evidence on question 3, looking at surrogate markers of disease severity as an outcome, merited a low quantity of evidence and high quality of evidence for some surrogate markers and low quality of evidence for others (see Appendix F).

## Key Question 4

Question 4. Do post-MI patients with depression who received depression treatment have better outcomes than post-MI depression patients who did not receive such treatment?

### Introduction

The preceding sections of this evidence review have focused on the risks associated with having depression after an MI. Most of this evidence is based on observational studies and statistical approaches to determine whether any association between depression and these outcomes is independent of other factors. Studies of treatment for depression can provide important information on causal inferences for depression and poor outcomes. Treatment studies also address the issue of greatest concern to patients and clinicians: Can treatment reduce any of the increased risks that may be associated with having depression? Question 4 addresses whether post-MI patients with depression have better outcomes with depression treatment than do those without such treatment. An important aspect of this question relates to determining whether it is the resolution of the depression, or the treatment itself, that reduces the risk. For example, if SSRIs improve outcomes, is it because the SSRIs have beneficial platelet effects, or is it because the SSRIs increase the rate of depression resolution? These issues are the motivation for question 4.

### Results of Literature Search

Our comprehensive literature search identified 12 articles addressing this question. Eleven studies were randomized clinical trials, and one used a less rigorous method for developing comparison groups. A common reason for eliminating studies was that patients entered into the studies did not all have clinical depression, and the results for the depression subgroup were not presented separately. Such studies do not provide direct evidence regarding question 4. One meta-analysis ^116^ addressed the question of whether the addition of psychosocial interventions improves the outcome of a standard rehabilitation regimen for patients with CAD. The authors used a broad definition of psychosocial interventions and identified 23 randomized clinical trials. They concluded that the addition of psychosocial treatments to standardized cardiac rehabilitation regimens reduces mortality and morbidity, psychological distress, and some biological risk factors.

### Characteristics and Results of Studies

Table and Evidence Table 4.1, 4.2, 4.3, and 4.4 in Appendix G, highlight characteristics and results of the studies eligible for our question 4. All were based in North America or England, although one study recruited some patients from Australia and Europe. ^59^ The dates of publication for these studies ranged from 1991 to 2003. There was an excellent balance in the studies with seven addressing psychosocial interventions and five focusing primarily on antidepressant medications. The majority of the subjects had had a recent MI, but some studies included patients with CAD and no MI in the previous 6 months. All of the studies included women and men, but men accounted for about 75 percent of the total participants. Some studies excluded individuals over age 70. Apart from the ENRICHD trial, the ethnic diversity of the study samples was limited.

The largest studies with the highest quality data that most directly address the question are the SADHART or SADHART ^59^ and the ENRICHD study. ^58^ SADHART was conducted in 40 outpatient cardiology centers in seven countries. Participants were randomized to 24 weeks of double-blind treatment with either sertraline or placebo. Participants were recruited in the hospital by either chart review or physician referral. Inclusion criteria included being hospitalized for either an MI or unstable angina in the past 30 days. Diagnosis of MI was made according to standard criteria. Unstable angina was defined as having (1) typical ischemic symptoms lasting longer than 10 minutes, (2) being hospitalized, and (3) having changes on an electrocardiogram (ECG) within the previous 12 hours. Alternatively, one could meet criteria for unstable angina by being hospitalized with unstable angina and having known CAD. Depression was identified with the DIS completed by a trained interviewer and with the self-rated BDI. The DIS was completed within 30 days of the hospitalization. For the DIS the 2-week duration criteria and impairment criteria were eliminated for the diagnosis of major depression because of the complicating cardiac event. Exclusions included (1) uncontrolled hypertension, (2) cardiac surgery anticipated in the next 6 months, (3) MI or cardiac surgery in the previous 3 months, (4) congestive heart failure, (5) bradycardia, and (6) MI or unstable angina of a nonatherosclerotic etiology. Psychiatric exclusions included alcohol or substance abuse, psychotic illness, cognitive impairment, current use of an antidepressant, or initiation of psychotherapy in the past 3 months.

After meeting the initial eligibility criteria for the study, all participants received placebo for 14 days. During this time they completed their cardiovascular tests and a psychiatrist confirmed that their depressive symptoms were present for 2 weeks. Because many of the participants had mild depression, they were stratified by severity of depression, and it was hypothesized that those with more severe depression would have a greater benefit from treatment with sertraline. Participants were started on sertraline 50 mg daily and could be systematically increased to 200 mg daily. The only other psychotropic medications allowed were chloral hydrate and zopiclone. The primary goal for the study was to evaluate the cardiac safety of sertraline. Therefore, the primary outcome was cardiac function, specifically LVEF. Depression outcomes included the BDI and 17-item HAMD (assessed up to 16 weeks) and Clinical Global Severity (assessed up to 24 weeks). Cardiac events were adjudicated by a committee. Revascularization was not considered an endpoint for this study.

Of the 556 individuals who were initially eligible, 369 individuals remained eligible after the 2-week run-in phase and were randomized. Because of the run-in phase, the mean time to start the intervention was 24 days after MI. There were no significant baseline differences between the groups. Most patients were aged between 50 and 70 years and had least two cardiac risk factors. While most had mild to moderate levels of depression, 25 percent met criteria for more severe depression. Most participants completed treatment (mean of 149 days) and achieved a low dose of sertraline at the end (mean of 68 mg daily). Those on sertraline did report more nausea and diarrhea, common side effects of sertraline.

The investigators presented data on 260 participants with baseline and final data (70 percent completion rate). As shown in Table 4.2, there were no differences in cardiac function at follow-up between those on sertraline and those receiving placebo. For important cardiac event outcomes, there was a trend toward lower numbers of events for those on sertraline. For the composite end point of death or cardiovascular events, the relative risk was 0.77 for those on sertraline compared with those on placebo, but the 95 percent confidence interval was moderately wide (0.51 to 1.16).

For depression outcomes, the results generally indicated that the sertraline group had better outcomes. The study groups did not differ on the HAMD ratings but these ratings stopped at 16 weeks. Clinical Global Inventory outcomes were assessed through 24 weeks and did differ between the study groups. For those with a history of recurrent depression, outcomes for those randomized to sertraline were better than for those receiving placebo for both the Clinical Global Severity and HAMD ratings.

About 20 percent of the participants in the study had not experienced a recent MI. Results were not presented separately for those with an MI. No Kaplan-Meier data were presented to determine when the sertraline began to affect cardiac outcomes. It also was not clear how drop outs were handled in the analysis.

A second paper from the SADHART study was also included in our review. This study focused on QOL outcomes. ^117^ For this analysis more than 90 percent of all randomized patients provided data. Overall, both the sertraline and placebo groups showed improvement in QOL. According to results from the Medical Outcomes Study Short Form 36 (SF-36), the study groups did not differ in Physical Component or Mental Component change scores. However, for the recurrent depression group, there was a significantly positive change on the Mental Component score for those on sertraline compared with those receiving placebo, and there was a trend toward more improvement on the Physical Component score as well. Similar results were found using the Quality of Life Enjoyment and Satisfaction scale (Q-LES-Q).

A second major study addressed the efficacy of treatment for depression in individuals who have depression after an MI—the ENRICHD study. ^118^ This multicenter trial was designed to measure the effect of a psychosocial and cognitive behavior therapy intervention. A total of 2,481 patients were recruited from eight clinical centers for the study. Eligibility requirements included meeting criteria for either depression (39 percent) or social isolation (26 percent), or both (34 percent). The depression measure was based on the Depression Interview and Structured Hamilton (DISH) instrument. The major modification with this instrument is that patients were eligible if they had depressive symptoms for 1 week, provided they had previously had an episode of major depression. DISH and BDI scores indicated most patients had moderate to minor levels of depression. The participants all had to be enrolled within 28 days of their MI. Initially the participants could not be taking antidepressants, but halfway through the study patients who remained depressed even after taking antidepressants for at least 14 days were included in the study. The criteria used to establish an MI were standard.

Patients were assigned randomly either to the intervention or routine care. Patients in both groups received written materials about cardiac risk factors based on the American Heart Association Active Partnership Program, and those in usual care had physician notification of their depression. The intervention included cognitive behavioral therapy provided first with three individual sessions and then within a group setting. Therapy could last up to 6 months. Intervention patients were referred to study psychiatrists for initiation of pharmacotherapy if they had scores higher than 24 on the HAMD or if they had less than 50 percent reduction in BDI scores after 5 weeks. Pharmacotherapy was usually sertraline and could be continued for up to 12 months.

As shown in Evidence Table 2, study participants had a mean age of 61 years, 44 percent were female, 33 percent were nonwhite, and 47 percent had a high school education or higher. Cardiovascular risk factors were as expected, with 64 percent having a smoking history and 33 percent having diabetes mellitus. Seven percent had a Killip class of III or IV; 83 percent had a cardiac catheterization; and 17 percent had a subsequent CABG surgery. Use of cardiac medications was common.

Between 1996 and 1999, 2,481 patients were randomized. Vital status was ascertained for 93 percent of patients at 6 months and all patients were followed for at least 18 months. Ninety-two percent of those randomized to the intervention received the intervention as assigned. Median time to enrollment was 6 days post-MI, and the intervention started a median of 17 days after MI. Patients attended a median of 14 sessions. At baseline the intervention group was more likely to be on an antidepressant (9.1 percent versus 4.8 percent), and these differences were still apparent at the end of data collection (21 percent versus 14.6 percent).

Depression scores improved for both groups, but the intervention produced significant but modest differences in depression at 6 months as measured by the BDI and HAMD. At 30 months there were no differences between the intervention and usual care groups in terms of all-cause mortality, cardiovascular mortality, or nonfatal cardiac events. There was a statistically significant interaction between gender, intervention, and risk of death or recurrent nonfatal MI. Men in the intervention group had better outcomes than men in the usual care group, and women in the intervention group had worse outcomes than women in the usual care group.

Although not part of the randomized component of the study, the investigators presented an analysis of whether those on antidepressants had better cardiac outcomes. In both crude analyses and analyses adjusting for baseline variables including age, BDI score, Killip class, ejection fraction, serum creatinine, previous MI and prior diagnosis of congestive heart failure, stroke or transient ischemic attack, pulmonary disease or diabetes, the hazard rate for death or nonfatal MI was 0.63 (95 percent CI, 0.46 to 0.87) for those taking antidepressants compared with those not taking antidepressants. Antidepressant use was modeled as a time-dependent variable.

Overall, this study provided a high-quality counseling intervention that was initiated soon after an MI. It had a modest effect on depression but did not have any effect on cardiac outcomes early or up to 42 months of follow-up. Despite including individuals with only low social support, it did not seem to complicate conclusions related to depression care and outcomes. Any conclusions concerning the effects of antidepressants on cardiac outcomes are less certain. In light of the study protocol, which was to refer those only among the experimental group with high or persistent depression scores to be evaluated for antidepressants, it seems likely that those on antidepressants would have higher depression scores. This non-randomized component of the study could potentially produce selection bias, as antidepressants are related to both the exposure (psychosocial intervention) and the outcomes; thus it makes the experimental group look better than the control group, even if no true association exists. In their analysis the investigators adjusted for baseline BDI scores but not for subsequent BDI scores. It would appear that the analysis presented in the manuscript might underestimate the effect of antidepressants because it did not fully adjust for depression severity. It also would be reassuring to report if the effect of antidepressant therapy was detectable for both those in the usual care group and those in the intervention group. The analysis regarding antidepressants excluded all those who had entered the trial only for low social support. However, it was not clear who the comparison group was in this antidepressant analysis. Also, the study did not adjust for willingness to accept a recommendation to start an antidepressant, which may be a marker for overall adherence to multiple care recommendations.

Other psychosocial intervention studies. With numerous studies demonstrating that depression is a risk for poor outcomes after an MI, several investigations were conducted to determine whether psychosocial interventions might reduce the elevated risk. The minimal risks associated with psychosocial interventions make such interventions attractive for patients who usually require multiple medical interventions for their cardiac care.

Frasure-Smith and colleagues ^48^ completed a randomized clinical trial involving 1,376 post-MI patients in which they compared a supportive and educational home nursing intervention and usual care. Most of the participants did not have significant problems with anxiety and depression. The mean BDI score was only 8.3 at baseline with 33 percent above the usual cutoff for clinical depression. The intervention was designed to address psychological distress, not specifically depression. The investigators met their target for intervention frequency in 87 to 94 percent of the participants. Contact for most patients receiving the intervention was spread out over 6 to 7 months. Despite meeting their intervention target goals, the investigators found that mean BDI scores at 1 year had no greater reduction for those in the intervention group than for those in the usual care group. It is unlikely there would be large intervention effects for the subgroup with high levels of depression at baseline if there were no differences in mean change in BDI scores, but data on the subgroup of participants having a score above 10 on the baseline BDI would have been informative. The authors did not provide information on the percentage of patients receiving antidepressant medication or formal psychotherapy. In terms of cardiac death, noncardiac death, nonfatal reinfarctions, or hospital readmission, there were no statistical differences by intervention status. Women in the intervention group tended to do worse than those in the usual care group. For men, there were no significant differences between the intervention and usual care groups. The authors speculated that the intervention nurses did not receive specific training in psychiatric-disorder screening and psychotherapeutic techniques, and this deficiency might account for the lack of effect of the intervention. In addition, the low need for depression treatment at baseline effectively limited power to detect differences in outcome.

Taylor and colleagues ^119^ tested the effect of a home-based, case-managed, multifactorial risk reduction program with 585 men and women aged 70 years or younger who were hospitalized for an acute MI in one of five San Francisco Bay Area hospitals. The intervention began in the hospital and included screening for psychological distress, monitoring with follow-up phone calls, and referring for mental health treatment when necessary. Patients were assessed at 6 months and 12 months. Of note is the unusual manner in which depressive symptoms were assessed. Depression was assessed with a single question about mood. With depression assessed by a single question, it is nearly impossible to detect any change. During follow-up, depression scores dropped significantly for both groups. There were no differences between the intervention and usual care groups. The intervention was not effective even for those with moderate-to-severe depression scores at baseline.

Johnston et al. ^49^ randomized by ward and recruited 100 patients from a Scottish hospital within 72 hours of admission for acute MI. Despite randomization at a group level, the study groups were balanced on important baseline characteristics. Randomization was to usual care, inpatient cardiac rehabilitation, or extended rehabilitation. The extended rehabilitation group was followed for up to 6 weeks after discharge and received a mean total of 9.5 sessions with 8.4 hours of contact. Patients and their spouses picked topics and received “nonjudgmental” counseling with a focus on helping patients achieve their objectives. Possible topics included explanation of heart attacks, risk factor modification, or emotional effects after a heart attack. Depression scores, which were measured at baseline, discharge, 2 months, 6 months, and 12 months after discharge with use of the HADS, indicated significantly lower levels of depression for both intervention groups. Unlike most studies the depression scores worsened for the usual care group after leaving the hospital. The authors suggested that their intervention had better results than others because the approach was one-to-one and not group, nurses worked from a treatment manual, and partners were included.

The study by Dracup et al. ^47^ compared 41 patients who participated in a structured outpatient cardiac rehabilitation program to 100 patients who did not complete cardiac rehabilitation. There was no randomization. All patients were living with a partner. Patient characteristics at baseline were similar for the two groups. Depression was measured with the Multiple Affect Adjective Checklist. Between baseline and 6 months, the cardiac rehabilitation patients had a reduction in their depression score, whereas the group without cardiac rehabilitation had no reduction. These differences were statistically significant, but the statistical adjustment for covariates was not clear.

Brown and colleagues ^45^ recruited patients from the cardiac rehabilitation centers of five major medical centers. All participants were required to have (1) MI or CABG within the past 4 and 4 to 24 months, (2) prognosis no worse than 3.3 (New York Heart Association Criteria), which indicates a moderately compromised cardiac status, (3) stable cardiac disease and no contraindications to physical activity, (4) onset of depression/anxiety associated with MI/CABG as assessed by the Schedule of Affective Disorders and Schizophrenia, (5) scores greater than 13 on the BDI or above 70 on the SCL-90 - Revised, and (6) spouses, friends, or relatives willing to participate in the treatment intervention. As compared with other study samples, this sample included individuals having higher levels of depression. Participants were randomized to either active treatment or attention control. Active treatment focused on principles of behavior therapy with relaxation training and some cognitive restructuring self-instruction. Treatment, which included 12 weekly sessions, was provided by three different therapists. Clinician ratings were completed by raters blinded to the intervention status of the participants. Both groups improved on depression ratings (self-report and clinician ratings), but at 12 and 15 months the behavior therapy group continued to improve whereas the attention control group began to relapse. No information on cardiovascular outcomes was collected.

The manuscript by Crowe and colleagues ^46^ describes an observational study with a randomized component in which patients did or did not receive cardiac rehabilitation intervention. It is very difficult to determine the actual study design from the article. Evidence Table 4.4 suggests that both the rehabilitation and usual care group demonstrated major improvement in depression during the follow-up, but there were no differences between the groups.

Other antidepressant intervention studies. Most of the pharmacological studies have used SSRI antidepressant medications. A 1998 study compared nortriptyline (tricyclic antidepressant) with paroxetine (SSRI). ^120^ As part of this study, 81 individuals younger than 65 years who had ischemic heart disease and moderately severe major depression (16 or higher on the 17-item HAMD) were randomized to either paroxetine or nortriptyline. Each patient completed a 2-week placebo lead-in phase to establish the stability of the depression diagnosis and to complete their cardiovascular tests. About two thirds of the patients had a history of MI, but the MI was not recent. The primary aim of the study was to determine the effect of the two types of antidepressant medication on cardiovascular outcomes. Patients received the study medication in a double-blind fashion for 6 weeks. Both medications were equally effective in reducing depression (60 percent achieved a 50 percent reduction in depressive symptoms). However, more participants withdrew from the nortriptyline than the paroxetine group (10 versus 2). Paroxetine did not have a significant effect on heart rate, blood pressure, conduction intervals, or ventricular arrhythmias. Nortriptyline was associated with an 11 percent increase in heart rate, a significant decline in standing systolic blood pressure, and a decrease in HRV. There was no effect on cardiac conduction. For equally effective treatments, the SSRI had less cardiovascular effects than did the tricyclic antidepressant. This study was funded by Smith-Kline Beecham, the manufacturer of paroxetine.

Another small study looked at the safety and efficacy of fluoxetine in the treatment of patients with major depression after a MI. ^50^ For this study, depression was confirmed by a clinician-administered HAMD between month 3 and month 12 after an MI, and patients younger than 75 years were eligible. In this double-blind study, 54 patients were randomized to either fluoxetine or placebo for 9 weeks. Despite the small sample size there was nearly a statistically significant greater reduction in depression for the fluoxetine group than for the placebo group. For the majority of cardiovascular measures there were no differences between those randomized to fluoxetine or placebo. The investigators measured cardiac output using the aortic time velocity integral and found it increased in the placebo group and decreased in the fluoxetine group. The QRS interval was lower in those on fluoxetine than in the placebo group (p=.03). This study was funded by Eli Lilly, manufacturer of fluoxetine.

In 2000 McFarlane and colleagues ^121^ reported the results of a double-blind, randomized, placebo-controlled study of sertraline in 38 post-MI patients. The total sample was small with 12 randomized to sertraline, 15 to placebo, and 11 non-depressed age-matched controls. Depression was diagnosed with a validated self-report instrument called the Inventory to Diagnose Depression (IDD). The IDD was administered before hospital discharge and again within 2 weeks of the acute infarct. Ejection fractions averaged over 50 percent in each group. Depression scores tended to decrease faster in the sertraline group than the placebo group. Standard deviation of normal R-R interval (SDNN), a measure of HRV, increased by 5 percent in the sertraline group and decreased 9 percent in the placebo group. Lower levels of SDNN have been reported to be a marker for increased cardiac mortality. Differences by study group were not evident in several other markers of HRV. This study was not supported by a pharmaceutical company but by the Heart and Stroke Foundation of Ontario, Canada.

As summarized in Evidence Grade Table 4, we concluded that the overall body of evidence on question 4 merited a medium quantity of evidence and medium to low quality of evidence (see Appendix F).

### Quality of Studies

There was a wide variation in the quality of the eligible studies with the larger and more recent studies generally having higher levels of quality. Median quality scores across the various domains of study quality ranged from a low of 50 percent on statistical analysis and measurement of depression to 100 percent on reporting potential conflicts of interest. (See Evidence Table 4.3 in Appendix G)

## Key Question 5

Q5. What are the performance characteristics (e.g., sensitivity, specificity, reliability, and predictive value) of instruments that are used to screen for depression (or depressive symptoms) after an acute MI?

Q5a. What are the performance characteristics of instruments that are used to screen for depression (or depressive symptoms) after an acute MI, during hospitalization?

Q5b. What are the performance characteristics of instruments that are used to screen for depression (or depressive symptoms) after an acute MI, within 3 months after hospitalization?

### Introduction

Clinicians and investigators need accurate and reliable methods to screen for depression in post-MI patients. The screening assessment methods should have adequate validity, reliability, and diagnostic utility within post-MI populations. Population-specific evaluation of the performance characteristics of assessment tools is particularly important with MI survivors because somatic symptoms of depression are easily mistaken for, and often overlap with, the physical sequelae of MI. Moreover, the timing of the depression assessment may influence its reliability and accuracy given that the hospitalization itself (question 5a) may adversely affect sleep habits, appetite, and other aspects of the usual depression assessment. Adequate validity of an assessment instrument is achieved if the instrument can successfully measure depression and differentiate it from similar, but distinct constructs. Reliability refers to the degree of consistency of a measure. Diagnostic utility refers to the extent to which a measure correctly identifies individuals who meet or do not meet certain diagnostic criteria as determined by a “gold standard,” which for depression would typically be a structured interview process. Validity, reliability, and diagnostic utility are multidimensional concepts that gain strength with convergence of evidence. They cannot be established globally for a particular instrument, but rather defined in terms of specific groups or populations and the purpose for which they are used (i.e., screening versus research diagnosis).

As reviewed in the section of the report on questions 1 and 2, numerous measurement instruments have been used to assess depression in post-MI patient populations. Perhaps the two most frequently used instruments are the BDI and the HADS. Evidence was presented in the section of the report on questions 1 and 2 indicating that the BDI tends to produce higher prevalence estimates across studies than the HADS. This finding raises questions about the performance characteristics of these and other measures used with post-MI patients. This section will review evidence related to the validity, reliability, and diagnostic utility of assessment techniques that have been used to evaluate depression in survivors of MI.

### Results of Literature Search

After article review, seven articles were eligible for review on question 5. One study was excluded at this point because it did not report specific cutoff criteria used for diagnosing depression. Of the six remaining studies, two also were deemed eligible for question 5a. ^119^ , ^122^ In one of these two studies, the majority of participants (78 percent) were interviewed during hospitalization and the balance post-discharge, but within 28 days of the index MI. ^122^ Three studies were eligible for question 5b as well as for question 5. ^75^ , ^90^ , ^123^ One study reported data relevant to both questions 5a and 5b. ^66^

### Characteristics of Studies

A summary of key aspects of the six eligible studies is presented in Appendix G Tables 5. Included studies were published between 1988 and 2003. All of the studies were composed entirely of post-MI patients. Two studies reported data on diagnostic utility, ^75^ , ^90^ two on factor/construct validity, ^66^ , ^119^ one on convergent validity, ^122^ one on discriminant validity, ^123^ and two on internal consistency reliability. ^66^ , ^119^ Four studies were conducted in Europe, ^66^ , ^90^ , ^119^ , ^123^ one in Canada, ^75^ and one in the United States. ^122^ Only one - which included over 2,000 participants, but provided limited data for this question - was a multicenter study. ^122^ The other studies included between 52 and 335 participants. The mean age of participants ranged from 51 to 67 years. The ENRICHD study, ^122^ which was designed to maximize diversity of participants, enrolled 44 percent women and 34 percent non-white participants. The other studies enrolled between 73 and 90 percent men. Only one other study provided data on race; it enrolled only white participants. ^90^ The ENRICHD study ^122^ was the only eligible study to report cardiac risk factors, and none of the studies reported MI characteristics such as Killip class or LVEF.

### Quality of Studies

As shown in Table 5.2, the number of studies that had a study quality score higher than 50 percent were as follows: five for representativeness of the study population, three for potential bias and confounding, two for description of therapy and management, four for description of assessment protocol, two for test interpretation, two for reporting of outcomes and follow-up, and five for statistical analyses. Only two studies reported information on potential conflicts of interest.

### Results of Studies

Table 5.1 presents evidence on performance characteristics of measures of depression with post-MI samples, as reported by the six reviewed articles. The three studies that reported performance data from hospitalized post-MI populations included data on the BDI, the HADS, and the HAMD. The BDI is a 21-item self-report rating scale measuring characteristic attitudes and symptoms of depression. The HAMD is a 17-item observer rated scale to assess the presence and severity of depressive symptoms. The HADS is a 14-item (seven depression items) self-report questionnaire designed to detect symptoms of anxiety and depression in a non-psychiatric hospitalized population.

Internal consistency reliability for the HADS and the HADS Depression subscale (HADS-D) as measured by Cronbach's alpha was found to be 0.82 and 0.72, respectively, in a sample of 194 male and female patients. ^119^ Another study by the same authors, which included 335 male and female patients, reported internal consistency reliability for the HADS as 0.87, 0.88, and 0.90 at 1 week in-hospital, 6 weeks, and 6 months post-MI and for the HADS-D as 0.76, 0.80, and 0.81 for the same follow-up times. ^66^ Nunnally has suggested a widely referenced guideline of 0.70 as a lower bound for acceptability of internal consistency reliability. These two studies also reported data from an exploratory factor analysis ^119^ and confirmatory factor analyses across time ^66^ that supported the construct validity of the HADS-D as measuring depression distinct from anxiety.

The ENRICHD investigators ^122^ reported evidence on the convergent validity of the self-report BDI and the HAMD, the items of which were embedded in an SCID. A Pearson correlation coefficient between the BDI and the HAMD was 0.64, close to the low end of the range of similar correlations that have been reported in other clinical settings (0.61 to 0.87). ^124^ The ENRICHD sample, however, included only individuals with symptoms of depression. This stipulation would be expected to restrict the range of scores on the BDI and HAMD and to lower the correlation coefficient compared to what might be found in a screening sample of both depressed and nondepressed individuals.

Three additional studies reported psychometric data within 3 months after hospitalization for the BDI, the HADS, the HAMD, the Symptom Checklist-90 Depression subscale (SCL-90-Dep), and the ZDS. The SCL-90 is a brief, multidimensional self-report inventory designed to screen for a wide range of symptoms of psychopathology that includes an index of depression. ^125^ The ZDS is a 20-item self-rating scale to screen for symptoms of depression. ^126^

Two studies assessed the diagnostic utility of measurement instruments as compared with a SCID for DSM diagnosis. ^75^ , ^90^ One of these studies ^75^ counted any subject with a total BDI score of 1 to 12 as symptomatic, resulting in difficult to interpret concordance data. This study was also limited by its very small sample size. In the other study, ^90^ data on diagnostic utility (sensitivity, specificity, positive predictive value (PPV), and negative predictive value (NPV) were reported on both major depression and combined major and minor depression for the BDI, HADS and HADS-D, HAMD, and SCL-90-Dep as compared with a physician-administered SCID-IV. SCID-IV prevalence for major depression was 11.2 percent and 7.8 percent for minor depression with a combined prevalence of 18.9 percent. Cutoff points were derived by using receiver operating characteristic (ROC) analysis, which attempts to determine optimal sensitivity and specificity. The number of patients included in each comparison ranged from 179 to 206, depending on the measure. For combined major and minor depression, sensitivities ranged from 0.75 for the HADS-D to 0.84 for the BDI. Specificities ranged from 0.72 for the BDI to 0.86 for the HAMD. PPVs ranged from 0.25 for the BDI to 0.41 for the HAMD. NPVs ranged from 0.93 for the SCL-90-Dep to 0.99 for the HAMD. For major depression alone, sensitivities ranged from 0.82 for the BDI to 0.96 for the SCL-90-Dep. Specificities ranged from 0.74 for the SCL-90-Dep to 0.92 for the HAMD. PPVs ranged from 0.32 for the HADS-D to 0.59 for the HAMD. NPVs ranged from 0.96 for the SCL-90-Dep to 0.98 for the HAMD, HADS-D, and BDI. Figures 3 and 4, show sensitivity and specificity data for all measures for major/minor and major depression.

Figure 3. Sensitivity and Specificity of Instruments used to Screen for Major and Minor Depression Following an Acute Myocardial Infarction

Figure 4. Sensitivity and Specificity of Instruments used to Screen for Major Depression Following an Acute Myocardial Infarction

One study ^123^ reported evidence on the convergent validity of the SCL-90-Dep and the ZDS for 143 patients with a Pearson correlation coefficient ranging from 0.70 to 0.77 across four time periods (1, 3, 6, and 12 months). Evidence related to discriminant validity was also reported for both the SCL-90-Dep and the ZDS as compared with a measure of “vital exhaustion” developed in the Netherlands. That these correlations ranged from 0.75 to 0.83 for the two measures across the four time periods suggests these measures do not discriminate well between depression and post-MI symptoms of fatigue. The construct validity of vital exhaustion, however, is unclear and the measurement instrument used included numerous symptoms of depression. Additionally, in this study patients with a diagnosis of clinical depression, as determined by the HAMD, at baseline were offered antidepressants and withdrawn from the study. The lack of patients with significant symptoms of depression in the study population may have contributed to the lack of differentiation reported between symptoms of depression and vital exhaustion.

As summarized in Evidence Grade Table 5, we concluded that the overall body of evidence on question 5 merited a low quantity of evidence and low quality of evidence (see Appendix F).

### Summary of Studies

The measures reviewed here seem to be measuring depression based on adequate sensitivities and specificities across studies as compared with the SCID-IV ^90^ and evidence from confirmatory and exploratory factor analyses. ^66^ , ^119^ Evidence also exists for convergent validity ^122^ , ^123^ and adequate internal consistency ^127^ of the measures.

Given the limited number of studies and analyses performed, it is difficult to draw conclusions about performance characteristics at each time period. This is particularly true during the initial MI hospitalization. Overall, however, evidence is relatively scant regarding the adequacy of the assessment of depression in post-MI populations. None of the measures reviewed here has been normalized explicitly on post-MI populations. In this context, two interrelated concerns predominate. The first relates to construct validity and how well these measures accurately distinguish between symptoms of depression and somatic symptoms related to poor physical health. The study samples covered in this review tended to be small for these purposes. Furthermore, the psychometric methods that were used are relatively weak ones and provide limited information. Existing psychometric methods that are able to establish the equivalence of key measurement characteristics across post-MI and nonhospitalized depressed subjects would be useful in refining assessment practices for depression in MI survivors.

A second concern relates to the intended use of the instruments reviewed and the very low PPVs reported. ^90^ If these instruments are to be used for general screening that will be followed by a more thorough assessment of those who screen positive, then low PPVs and high NPVs are acceptable, and cutoff points to achieve this objective have been reported. ^90^ A research setting, however, in which relatively few of those diagnosed with major depression are actually depressed (as compared with diagnosis by SCID-IV) is problematic and reduces the power to detect relationships between depression and outcome variables. Strik and colleagues ^90^ reported utility statistics for prominent measures of depression that were based on cutoff scores generated by an ROC paradigm intended to maximize combined sensitivity and specificity. This resulted in cutoff points well below those used in normal settings where cutoff points are set pragmatically according to specific clinical or research objectives. A stronger analysis might have included data for commonly used cutoff points. Despite this flaw, the study pointed out a potential problem in research on the relationship between depression and post-MI outcomes. The slightly higher cutoffs normally employed would be expected to lessen but not completely alleviate this problem.

Furthermore, Strik's study provides data relevant to the discrepancy in prevalence rates generated by studies using the BDI as compared with studies using the HADS. For combined major and minor depression, the BDI tends to be highly sensitive relative to the other measures, but with lower specificity. When only major depression is considered, the BDI is the least sensitive measure and is in the middle to lower range of specificities. This suggests that compared with the HADS, SCL-90-Dep, and HAMD, the BDI tends to diagnose patients with less significant depressive symptoms at much higher rates than do the other measures, but it may be less effective in accurately diagnosing major depression. Given the expected distribution of symptoms of depression, the BDI would be expected to identify more patients as having significant symptoms of depression, but it would do a poorer job of consistently identifying those who are most depressed.

In summary, the quality of evidence varies for performance characteristics of instruments that measure symptoms of depression in post-MI populations, both in terms of numbers of patients studied and in terms of types of evidence that have been reported.

## Key Question 6

Question 6. Does use of cardiac treatment for patients with acute myocardial infarction differ for those with and those without depression?

### Introduction

Patients who are depressed after MI may receive different treatment than patients without depressive symptoms. Several factors could explain this difference in practice. Patients with depression may have a diminished capacity to make important decisions about their health. As a result, depressed patients may be less willing to undergo cardiovascular procedures such as catheterization, percutaneous coronary intervention (PCI), or CABG. Depression may also result in decreased adherence with prescribed medications, refusal to participate in cardiac rehabilitation, and reluctance to make lifestyle changes such as smoking cessation. In addition, physicians and other health care providers may not refer patients with depression for cardiovascular procedures or other therapies like cardiac rehabilitation even when medically appropriate. This practice, in turn, might reflect a bias against depressed patients on the part of health care providers. Alternatively, the depressed patient's perception and communication of cardiovascular symptoms may differ from those of a patient without depression in a manner that makes it less likely for certain treatments to be considered necessary. To evaluate this question we reviewed the English language literature that addressed the relation of depressed mood to use of cardiac treatment after an acute MI.

### Results of Literature Search

Our search found nine studies, published between 1982 and 2004, that met criteria for inclusion in this review (see Table 6).

### Characteristics of Studies

As shown in Table 9, seven of the nine eligible studies on key question 6 used prospective cohort designs with the other using a retrospective cohort design. ^52^ Four studies reported whether patients with and without depression differed with regard to prescribed cardiac medications after MI. ^79^ , ^81^ , ^89^ , ^128^ Three studies evaluated adherence to secondary prevention medications and lifestyle recommendations in depressed and nondepressed patients. ^128^ – ^130^ Two studies evaluated whether patients with post-MI depression received invasive cardiac procedures at a different frequency compared to MI patients without depression. Two studies ^131^ , ^132^ examined factors associated with noncompletion of cardiac exercise rehabilitation.

### Quality of Studies

As shown in Table 6.3, the number of eligible studies with scores greater than 50 percent for the following criteria, were as follows: six for representativeness of the study population, one for description of therapy and management, eight for description of the assessment protocol, seven for reporting of outcomes and follow-up, and seven for the statistical analyses. Only three studies provided information about potential conflicts of interest.

### Results of Studies

Four studies have evaluated whether depressed and nondepressed post-MI patients are just as likely to be prescribed medications recommended to reduce post-MI risk (see Table 6.4). Ziegelstein et al. ^128^ in a U.S.-based study found that on hospital discharge depressed post-MI patients were less likely than patients without depression to be prescribed beta-blockers. They found no difference in discharge prescriptions for aspirin, lipid-lowering therapy and ACE inhibitors between depressed and nondepressed patients. Steeds et al. ^79^ in a United Kingdom - based study also found that MI patients with depression when compared with those without depression had lower rates of use of beta-blockers (32 percent versus 55 percent, p = 0.02) and higher rates of use of calcium channel blockers (37 percent versus 12 percent, p = 0.02). Strik et al. ^89^ monitored 206 Dutch patients with a first MI for up to 3 years. Patients with major or minor depression were prescribed platelet inhibitors at significantly lower rates than those without depression (81 percent versus 95 percent, p = 0.001). However, no significant differences were observed between depressed and nondepressed patients in the use of beta-blockers or in the rates of use of PTCA. Lauzon and colleagues ^81^ studied 550 Canadian post-MI patients and found no difference between depressed and nondepressed patients in prescribed levels of use of aspirin, beta-blockers, lipid-lowering drugs, ACE inhibitors, nitrates, or calcium-channel blockers. They did find that depressed patients had a significantly higher rate of rehospitalization for cardiac complications than nondepressed patients. Overall, these studies were not consistent with each other. The U.S. - and U.K.-based studies both found that depression was associated with decreased use of beta-blockers in post-MI patients, whereas the Dutch and Canadian studies both found that depression was not associated with decreased use of beta-blockers in post-MI patients.

Three studies examined the effect of depression on adherence behaviors after MI (see Table 6-4). In the study performed by Ziegelstein et al. ^128^ 276 patients were followed for 4 months after an acute MI, and those with major depression and/or dysthymia were less likely to follow dietary, exercise, and stress-reduction recommendations or to take prescribed medications than were patients without depression. Conn et al. ^129^ assessed multiple self-care behaviors in 94 post-MI patients aged 65 years or older who were deemed capable of self-care. Depression, but not anxiety, was significantly associated with decreased adherence at 1 to 2 years of follow-up for all self-care behaviors assessed: exercise, diet, medications, smoking cessation, and stress management. ^128^ More recently, Romanelli et al.also studied adherence behaviors in post-MI patients aged 65 years or older. ^130^ They found that post-MI patients had significantly lower rates of adherence than nondepressed MI patients for use of prescribed medications as well as recommendations for following a low fat diet, increasing exercise, and reducing stress. ^52^ , ^81^ These three studies thus were consistent in showing that depression was associated with decreased adherence to prescribed medications and other risk reduction behaviors in post-MI patients.

Two studies examined the use of invasive procedures after MI (see Table 6-4). Druss et al. ^52^ reviewed Medicare claims in a national cohort of 113,653 patients coded as having MI and compared the 5,365 coded with a secondary diagnosis of mental disorder to the other 108,288. The patients with the following mental disorders were considered: schizophrenia, affective disorders, substance abuse, and others (excluding dementia and delirium). Those with mental disorders were significantly less likely than those without mental disorders to undergo cardiac catheterization, PTCA, and CABG. This decreased tendency for undergoing invasive cardiovascular procedures among post-MI patients, extended to the subgroup of 315 patients with a mental disorder characterized as an affective disorder, among whom the rates of catheterization, PTCA, and CABG were 33.4 percent, 9.2 percent, and 7.9 percent, respectively. Those rates were significantly lower than the rates observed in the patients without mental illness, which were 43.7 percent, 16.8 percent, and 12.6 percent, respectively. In contrast, Lauzon et al ^73^ studied 550 post-MI patients in Quebec hospitalized between 1996 and 1998 and found that 23 the rates of undergoing cardiac catheterization, PTCA, and CABG were not lower among those with BDI scores of 10 or higher than among those with BDI scores lower than 10. Thus, these two studies reported conflicting results about the relation of depression to undergoing invasive procedures in post-MI patients.

One study by Blumenthal et al. ^132^ evaluated 35 post-MI patients referred for cardiac rehabilitation for factors associated with completion of the prescribed program (see Table 6.2). They found that patients with higher depression scores on the Minnesota Multiphase Personality Inventory (MMPI) were more likely to drop out of the program (p < 0.03). However, in multivariate analysis, only ejection fraction, ego strength, and social introversion were associated with continued adherence to the cardiac rehabilitation program. Another study, ^133^ performed in the United Kingdom examined psychological determinants of attendance in cardiac rehabilitation among 93 patients after an acute MI (see Table 6.2). These investigators found that the best predictors of poor or no attendance were lower perceptions of symptoms and controllability or curability of illness, and less frequent use of problem-focused coping strategies and more frequent use of maladaptive coping strategies. Although depression scores on the HADS were lower among those with poor or no attendance, depression score was not an independent determinant of attendance in cardiac rehabilitation. The higher depression score among attendees suggests that those who are experiencing a greater degree of distress after MI are more likely to attend, but this explanation is not conclusive. Because neither of these studies enrolled a sufficient number of patients with a clinical diagnosis of depression, a definitive conclusion about an independent relationship between depression and completion of recommended cardiac rehabilitation is not possible.

As summarized in Evidence Grade Table 6, we concluded that the overall body of evidence on question 6 merited a low quantity of evidence and medium to low quality of evidence (see Appendix F).