# Methods

The American Academy of Family Physicians (AAFP) requested an evidence report to synthesize the available evidence on depression and post-MI depression, with an overall goal of using the report in supporting the development of evidence based clinical practice guidelines. The Johns Hopkins University Evidence-based Practice Center (EPC) was awarded this contract in December 2003. The EPC established a team and work plan to develop the evidence report. The project consisted of recruiting technical experts, formulating and refining the specific questions, performing a comprehensive literature search, summarizing the state of the literature, constructing evidence tables, and submitting the report for peer review.

## Recruitment of Experts and Peer Reviewers

At the beginning of the project, we recruited a panel of eight external technical experts (see Appendix A^*^ ) from national and international communities to give us input on key steps including the selection and refinement of questions to be examined. This panel of experts included a representative from our partner organization (the AAFP), as well as other respected experts from the fields of psychiatry, psychology, rehabilitation, and cardiology. This panel of experts provided feedback on the key questions and was asked to review the draft report.

Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/mideprtp.htm.

## Target Population

Our review focused on studies of adults (male and female), including members of any racial/ethnic population, who had suffered an acute MI. The main targeted users of the review are clinical leaders of health care quality improvement efforts and clinicians, including family physicians, internists, cardiologists, psychiatrists, and psychologists.

## Identifying the Key Questions

The AAFP provided the EPC its original list of questions. We revised the questions on the basis of preliminary literature searches. The panel of technical experts reviewed the draft questions and ranked each question according to importance, amount of available evidence, and clarity. We collected the responses from the experts and revised the questions as suggested.

## Key Questions

The EPC team sought evidence to address the following key questions:

1. In patients diagnosed with and hospitalized for acute MI, what is the prevalence of depression during initial hospitalization for MI?

- We defined depression as symptoms meeting established clinical threshold criteria for depression as measured by validated questionnaires or standardized psychiatric interviews.

1a. What is the prevalence of depression during initial hospitalization for an acute MI, with or without a history of previous depression, as reported by study investigators?

2. What percentage of patients with post-MI depression continues to have depression (or depressive symptoms) 1 month or longer after initial hospital discharge?

3. What is the association of post-MI depression with outcomes independent of other predictors of post-MI outcomes?

- Post-MI outcomes include (1) clinical outcomes—total mortality, cardiac mortality, MI, resuscitated arrest, stroke, arrhythmias, and revascularization, (2) QOL, and (3) utilization of health care services—readmission, total hospital days, and cost of care.
- Potential predictors include demographic and clinical characteristics of patients that have been reported to be associated with the risk of post-MI outcomes.

3a. What is the association of post-MI depression with surrogate markers of cardiac risk independent of other predictors of post-MI outcomes?

- Surrogate markers of disease severity include HRV, platelet reactivity, and markers of inflammation such as CRP.

4. Do post-MI patients with depression have better outcomes with depression treatment than do those without such treatment?

- We defined depression treatment as including all interventions intended to have specific impact on depression, such as antidepressants, cognitive behavioral therapy, interpersonal therapy, psychosocial support, and cardiac rehabilitation.

4a. Do outcomes differ with or without improvement in depression for post-MI patients with depression who do receive depression treatment?

4b. Do outcomes differ with or without improvement in depression for post-MI patients with depression who do not receive depression treatment?

5. What are the performance characteristics (e.g., sensitivity, specificity, reliability, and predictive value) of instruments or methods that are used to screen for depression (or depressive symptoms) after an acute MI?

5a. What are the performance characteristics of instruments or methods that are used to screen for depression (or depressive symptoms) after an acute MI, during hospitalization?

5b. What are the performance characteristics of instruments or methods that are used to screen for depression (or depressive symptoms) after an acute MI, within 3 months after hospitalization?

6. Does the use of cardiac treatment for patients with acute MI differ for those with and those without depression?

- Cardiac treatment includes revascularization (angioplasty or bypass surgery), angiotensin converting enzyme (ACE) inhibitors, beta blockers, statins, antiplatelet agents, or other treatments recommended by the American Heart Association or the American College of Cardiology.

## Analytic Framework

We used our conceptual framework (see Figure 1) to guide the analysis of our questions, based on the relationships between MI, depression, various risk factors, pertinent treatment options, and subsequent clinical events.

## Literature Search Methods

Searching the literature included the steps of identifying reference sources, formulating a search strategy for each source, and executing and documenting each search.

## Sources

Our comprehensive search plan included electronic and hand searching. In March 2004, we searched the following electronic databases: MEDLINE®, the Cochrane CENTRAL Register of Controlled Trials (Issue 1, 2003), the Cochrane Database of Methodology Reviews (CDMR), the Cumulative Index of Nursing and Allied Health Literature (CINAHL®), the Psychological Abstracts (PsycINFO®), and EMBASE®.

Hand searching for possibly relevant citations took several forms. First, the EPC team identified 16 journals that we thought were most likely to contain relevant studies (see Appendix B). We scanned the tables of contents of these journals for relevant citations from October 2003 to April 2004.

For the second form of hand searching, we used ProCite®, a reference management software, to create a database of reference material identified through an electronic search for relevant guidelines and reviews, through discussions with experts, and through the article review process. We also reviewed the references in pertinent recent review articles that were identified during the abstract review process.

Finally, we examined the reference lists of eligible articles to identify any other potentially relevant articles. This task was performed by the second reviewer as part of the article review process (see description of article review process below).

## Search Terms and Strategies

Search strategies, specific to each database, were designed to maximize sensitivity. Initially, we developed a core strategy for MEDLINE, accessed via PubMed®, based on an analysis of the Medical Subject Headings (MeSH) and text words of key articles identified a priori. The PubMed strategy formed the basis for the strategies developed for the other electronic databases (see Appendix C).

## Organization and Tracking of the Literature

We downloaded electronic search results into the citation management database ProCite. (ProCite, ISI Research Soft, Berkeley, CA) The software's duplication check was used to eliminate citations already retrieved. We used the ProCite software to store and track the searching strategies and sources used to retrieve each citation. This software was also useful during the abstract review process to track the reviewed abstracts.

## Title Review

After the search strategies were completed and the citations downloaded into ProCite, two reviewers independently scanned the titles. During this scan, reviewers looked for article titles that clearly were irrelevant to the study questions. If both reviewers agreed, on the basis of the title, that an article was irrelevant, it was excluded from further consideration. Once a citation was selected for deletion, a note was made in the ProCite database deleting the citation from further review.

## Abstract Review

Specific inclusion and exclusion criteria were applied at each of the levels of review, with criteria becoming more stringent as the process moved from database searches, to the review of titles, to the review of abstracts, and to the review of articles. After identifying a title as potentially relevant, two team members independently reviewed the abstract of the citation, and articles were included or excluded from the article review on this basis. Also at this step, abstracts were flagged according to their relevance to a key question. To be excluded at this stage, both reviewers had to agree that an abstract was ineligible. Discrepancies were discussed during weekly face-to-face meetings.

## Inclusion and Exclusion Criteria

During the abstract review process, emphasis was placed on identifying all articles that could have original data pertinent to the questions. As previously described, a representative of the AAFP was consulted during the development of inclusion and exclusion criteria. In evaluating titles and abstracts, the following criteria were used to exclude articles from further consideration: (1) not in English, (2) no human data, (3) no original data, and (4) meeting abstract (no full article for review).

We also had two question-specific exclusion criteria. For key question 4, we excluded studies that did not have a concurrent comparison group. For key question 5, we excluded studies that did not have a validated reference standard for diagnosing depression.

## Abstract Review Process

The EPC team used an abstract review form for this stage of the process that was similar to abstract forms used in other EPC projects. The form was designed to address our specific questions and the eligibility criteria appropriate for this project (see Appendix D). Each abstract was circulated to two members of the EPC team who independently reviewed the abstract both for eligibility and applicability to specific key questions. For those articles deemed ineligible, the reviewers selected a reason for exclusion. When a citation contained no abstract, or when the reviewers could not determine from the abstract if the citation met eligibility criteria, a full copy of the article was obtained for review. Investigators met face-to-face to adjudicate disagreements about the eligibility of abstracts.

## Article Review

The purpose of the article review was to confirm the relevance of each article to the research questions, to determine methodological characteristics pertaining to study quality, and to collect evidence that addressed the research questions. The study team reviewed each article identified as being eligible during the abstract review process. The abstraction forms for the article review process were filled out in a serial manner. Two study team members worked on each article. The first reviewer had the task of filling out the quality and content abstraction forms. The secondary reviewer performed an independent assessment of the quality of each study, and then checked the information recorded by the primary reviewer on the content abstraction form. We used face-to-face meetings to adjudicate differences between the reviewers on the quality and content forms. We did not mask author and journal names because previous work has shown that masking does not make a significant difference during the data abstraction. ^61^

## Qualitative and Quantitative Data Abstraction

The study team developed content review forms and a quality review form for use in this project. The forms were pilot tested and revised before use. Because of the different types of questions, the team had a general content review form (See Appendix E), and five separate question-specific content review forms (see Appendix E): one addressing key questions 1 and 2, and one each for key questions 3, 4, 5, and 6. To make sure that all articles met eligibility criteria, the general content review form began with a check of the eligibility criteria (see Abstract Review, above). For key question 4, the team limited the review to studies with a comparison group, and for key question 5, the studies were limited to studies using a validated reference standard.

The quality assessment form included items about study quality in the following categories: representativeness of study population, bias and confounding, description of therapy and management, description of assessment protocols, test or instrument interpretation, outcome and follow-up, statistical analysis, and conflict of interest (see Appendix E).

## Evidence Tables

For each key question, the EPC team created a set of evidence tables. Each set of tables contained basic information about study aims and eligibility criteria, selected characteristics of study participants, assessments of study quality, and results most pertinent to the key question.

## Grading of the Evidence

After all articles were reviewed, we graded the evidence supporting each question on the basis of its quantity, quality, and consistency. Our evidence-grading scheme followed the approach recommended by the International GRADE Working Group. ^62^ In terms of quantity of evidence for each question, we determined the number of studies and the total number of patients studied. We assessed the quality and consistency of evidence on each key question based on the criteria recommended by the Grade Working Group that applies to the questions (see Appendix F for details).

## Peer Review

Throughout the project, feedback was sought from the technical experts through formal and ad hoc requests for guidance. A draft of the completed report was sent to the technical experts, as well as to the partner (AAFP), Agency for Healthcare Research and Quality (AHRQ) and other peer reviewers. Substantive comments were catalogued and entered into a database. Revisions were made to the evidence report as warranted, and a summary of the comments and their disposition was submitted to AHRQ with the final report.