# Introduction

## Overview of Post-Myocardial Infarction Depression

Myocardial infarction (MI) is the leading cause of death in this country. ^1^ The prognosis of patients with MI depends on the extent, location, and type of infarct. ^2^

In an effort to improve outcomes of patients with MI, a number of treatments are typically recommended, including medications, revascularization procedures, behavior and lifestyle changes, and cardiac rehabilitation. Co-existent depression may influence the recovery of patients with MI in a number of important ways reviewed in this report.

Depression is manifested by a number of symptoms including depressed mood, diminished interest or pleasure in all or almost all, activities, low self-esteem, sleep disturbance, changes in appetite, loss of energy, difficulty concentrating, psychomotor retardation or agitation, and suicidal ideation. Depression is common among patients recovering from am MI. Approximately one in six patients with an MI experience major depression and at least twice as many as that have significant symptoms of depression soon after the event. ^3^ , ^4^ Although minor mood disturbance is likely to resolve spontaneously after an MI, major depression is more persistent. ^5^ Many studies have found that depression is an independent risk factor for increased mortality among patients recovering from an MI. This increased risk appears to be present even by 4 months or earlier after hospital discharge, ^6^ and the relation between depression and risk has been reported to be graded and “dose-dependent”, with more severe depression associated with greater mortality risk. ^6^ Despite these findings, depression in patients recovering from an MI is often unrecognized, as it is in other medical populations. ^7^ Of note, only recently have MI treatment guidelines begun to call for the screening for post-MI depression. ^8^ This practice is in sharp contrast to the manner in which many other risk factors for increased morbidity and mortality are handled; for example, screening for diabetes mellitus or for reduced left ventricular ejection fraction (LVEF) are routinely performed as part of the standard care of patients hospitalized for an MI.

## Conceptual Framework

No mechanism has yet been defined that links depression after MI with the observed higher morbidity and mortality. However, a number of plausible mechanisms have been proposed. These putative mechanisms fall into two broad categories, “behavioral” (either patient or provider/health system) or “biological”. “Behavioral” mechanisms include: (1) a greater prevalence of noncompliance on the part of the patient, and (2) a failure of providers to offer important cardiac treatments as often as those patients without depression. “Biological” mechanisms include: (1) an increased risk of sudden cardiac death, possibly indicated by decreased heart rate variability (HRV) (2) increased platelet activation and thrombosis, and (3) increased activation of the systemic inflammatory response. These mechanisms are likely to act in some combination as indicated in the conceptual framework shown in Figure 1.

Figure 1. Conceptual Model

## Prevalence of Post-MI Depression

Depression has been reported to occur in a significant percentage of patients suffering from acute MI. ^3^ , ^6^ , ^9^ , ^10^ However, the prevalence of post-MI depression may vary considerably by patient population and the instruments used to make the assessment. This evidence report reviews in detail the studies reporting the prevalence of depression among patients who had an acute MI.

## Depression and Risk of Coronary Heart Disease

The development of coronary artery disease (CAD) involves the interplay of many factors. Some of these risk factors are well established: hypercholesterolemia, hypertension, diabetes, smoking, age, and genetic factors including sex. Management of these classic risk factors now forms the basis of current management recommendations for individuals at risk for coronary heart disease (CHD) events. ^11^ Epidemiologic studies also have found an association between clinical depression or depressive symptoms and increased risk of developing future symptomatic CAD, MI, and cardiac mortality. ^12^ – ^19^ Recent prospective studies have confirmed this association. In a study of 1,190 male medical students followed for up to 40 years, there was a 12 percent cumulative incidence of depression. ^20^ A history of depression carried a two-fold greater risk of developing symptomatic CAD or MI. In the Cardiovascular Health Study 4,493 Americans without evident coronary disease at baseline were followed for 6 years. ^21^ Depressive symptoms had a significant association with mortality, and an independent association with developing CAD and mortality, even after adjustment for other established coronary risk factors.

## Possible Mechanisms Linking Post-MI Depression and Adverse Outcomes

Many potential mechanisms have been proposed as plausible links between depression and higher rates of mortality after MI. Increased mortality has been detected as early as 4 months and as late as 10 years after MI among patients with depression at the time of hospitalization for MI. ^6^ , ^9^ – ^22^ Although no mechanism for the observed higher mortality has been established, suicide does not appear to play a role. Thus, there has been a search for other mechanisms by which post-MI depression could have a large adverse impact on survival within the first few months and extending for at least a decade. It is notable that not all studies of depressed post-MI patients have found an increase in mortality. ^23^

Figure 1 illustrates pathways by which depression could produce an early and sustained increase in post-MI mortality. In particular, increased thrombosis or arrhythmogenesis could directly cause higher mortality. Although numerous studies have reported an increased risk of sudden death with post-MI depression, ^24^ one study failed to find an increased rate of non-fatal MI over 5 years of follow-up. ^25^ Increased rates of non-fatal as well as fatal MI might be expected if a thrombotic mechanism were the prime mediator of increased risk. Taken together, these observations tend to favor an arrhythmic mechanism.

## Arrhythmias

In support of an arrhythmic mechanism are the observations that patients with coronary disease and depression have lower HRV than age- and sex-matched patients with coronary disease who are not depressed. ^26^ The finding of low HRV indicates abnormally high sympathetic tone with or without abnormally low parasympathetic neurological input to the heart, and it may be the link between post-MI depression and an apparently increased risk of sudden death. Individuals with post-MI depression have higher rates of ventricular ectopy than do those without depression. ^27^ An interaction between depressive symptoms and ventricular ectopy has also been reported, with an odds ratio of 29 for 18-month cardiac mortality in comparisons between post-MI patients with depression and premature ventricular contractions (PVCs) of at least 10 per hour and post-MI patients without either of these characteristics. ^9^

## Hemostasis

Alterations in hemostasis are also plausible links between depression and post-MI adverse events. Individuals with depression have evidence of increased platelet activation. The neurobiology of depression involves alteration in serotonin receptors and transport pathways. ^28^ , ^29^ The platelets of individuals with depression have alterations in receptors, including the serotonin 5 hydroxy-tryptamine (serotonin 5-HT2) receptor, that result in increased levels of activation. ^30^ , ^31^ , ^32^

## Inflammation

The onset and progression of atherosclerosis is strongly associated with vascular inflammation characterized by increased levels of inflammatory mediators such as interleukin 1(IL-1) and interleukin 6 (IL-6), tumor necrosis factor, and C-reactive protein (CRP). ^33^ In particular, the acute phase reactant CRP has emerged as a significant predictor of increased risk. ^34^ In populations without evident coronary disease, elevated CRP levels predict higher risk for developing an acute coronary syndrome (ACS). In those who have experienced an acute MI, higher levels of CRP are associated with poorer prognosis. ^35^ , ^36^ Major depression also has been associated with elevated CRP levels particularly in men. ^37^ Thus, adverse cardiac outcomes and depression could be linked through pathways with CRP or other markers.

## Quality of Life

Depression in medical illness is associated with a marked decrease in quality of life (QOL) and an increase in utilization of health care resources. ^38^ , ^39^ Among post-MI patients the presence of depression may be a powerful predictor of QOL. ^40^

## Other Possible Mechanisms

There are certainly other mechanisms not already mentioned that may link depression with increased morbidity and mortality post-MI. Depression has been associated with increased activity of the sympathetic nervous system. ^41^ In addition to its relationship to increased myocardial ischemia and arrhythmia, sympathetic nervous system activity may also result in higher blood pressure, insulin resistance, and an increased susceptibility to infection. ^42^ Depression has also been associated with deficiencies of omega-3 fatty acids and with elevated homocysteine levels which may increase the burden or cardiovascular disease, ^43^ and thereby adversely affect post-MI outcome.

## Response to Treatment for Depression

Several trials have now evaluated pharmacologic and non-pharmacologic treatment of depressive symptoms in post-MI patients. ^44^ – ^50^ However, these trials have had inconsistent results or insufficient power to detect significant differences. Consequently, no consensus exists regarding the efficacy of various treatment options for patients with post-MI depression.

## Patient Adherence and Provider Bias

Depression is a risk factor for non-adherence to treatment in many medical conditions. ^51^ Thus, it is important to determine the extent to which depression is associated with non adherence to recommended cardiac treatment in patients who have had an acute MI. As indicated in Figure 1, depression may well contribute to post-MI patients' difficulty in adhering to prescribed medications, accepting recommended procedures, and completing cardiac rehabilitation. Figure 1 also indicates that provider bias may play a role in keeping patients from receiving treatments that otherwise might be recommended after an MI. It is possible that health care providers are less likely to recommend some types of treatment for post-MI patients with depression than for those without depression. Indeed, some studies have found that patients with depression received a different level of medical treatment than those without depression. ^52^

## Screening and Diagnostic Approaches

In their recently released recommendation for depression screening, ^53^ , ^54^ the U.S. Preventive Services Task Force (USPSTF) points out that depressive disorders are common, chronic, and costly. The prevalence of depression is high, with community-based surveys indicating prevalence rates of 1.8 to 3.3 percent for depression within the last month and lifetime prevalence rates of 4.9 to 17.1 percent. ^55^ Depressive illness is projected to be the second leading cause of disability worldwide in 2020. ^56^ More than a decade ago, the economic burden of depression in the United States was estimated at approximately $44 billion, with $24 billion of that attributable to excess absenteeism of depressed workers and reductions in their productive capacity while at work during episodes of illness. ^57^ The USPSTF supports screening adults for depression in clinical practices that have systems in place to assure accurate diagnosis, effective treatment, and follow-up. ^53^ Although several reports address the ideal screening and diagnostic instruments for the detection of depression in general medical patients, little is known about the ideal method for diagnosing depression in patients in the post-MI period. What are the sensitivity and specificity of methods that could be used to screen for depression in post-MI patients? Do the accuracy and reliability of screening methods depend on the time of the evaluation relative to the diagnosis of an acute MI? Since post-MI depression has been associated with adverse outcomes, it is particularly important to have answers to these types of questions.

## Therapeutic Approaches

A number of therapeutic approaches have been advocated for patients with post-MI depression, including cardiac rehabilitation, social support, cognitive behavior therapy, and antidepressants. Two recent large studies examined the safety and efficacy of treating depression in patients recovering from an MI. In the Enhancing Recovery in Coronary Heart Disease Patients (ENRICHD) study, the effects of a psychosocial intervention on cardiac outcomes was examined in post-MI patients who were either depressed or had low perceived social support, or both. ^58^ The Sertraline Antidepressant Heart Attack Randomized Trial (SADHART) examined the safety and efficacy of antidepressant therapy with a selective serotonin reuptake inhibitor (SSRI) in patients who recently experienced an acute MI. ^59^ Although several types of antidepressant drugs might be considered in patients recovering from an MI, the tricyclic antidepressants usually are avoided because of their tendency to increase resting heart rate, produce orthostatic hypotension, and alter intracardiac conduction and the susceptibility to ventricular arrhythmias. ^60^ The SSRI antidepressants do not appear to have important cardiac side effects when administered to patients soon after an acute MI. ^59^