# Appendix H. List of Excluded Studies

Ades PA, Savage PD, Tischler MD, et al. Determinants of disability in older coronary patients. Am Heart J. 2002;143(1):151-6. No data on when MI occurred relative to when depression assessed. [pmid: 11773926].
Ades PA, Waldmann ML, McCann WJ, et al. Predictors of cardiac rehabilitation participation in older coronary patients. Arch Intern Med. 1992;152(5):1033-5. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 1580707].
Ahto M, Isoaho R, Puolijoki H, et al. Coronary heart disease and depression in the elderly--a population-based study. Fam Pract. 1997;14(6):436-45. No data on when MI occurred relative to when depression assessed. [pmid: 9476073].
Al-Ruzzeh S, Mazrani W, Wray J, et al. The Clinical Outcome and Quality of Life Following Minimally Invasive Direct Coronary Artery Bypass Surgery. J Card Surg. 2004;19(1):12-16. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 15108783].
Appels A, Hoppener P, Mulder P. A questionnaire to assess premonitory symptoms of myocardial infarction. Int J Cardiol. 1987;17(1):15-24. Does not apply. [pmid: 3666994].
Baer PE, Cleveland SE, Montero AC. Improving post-myocardial infarction recovery status by stress management training during hospitalization. J Card Rehab. 1985;5(4):191-197. Does not apply.
Baker RA, Andrew MJ, Schrader G, et al. Preoperative depression and mortality in coronary artery bypass surgery: preliminary findings. Anz J Surg. 2001;71(3):139-42. No data on when MI occurred relative to when depression assessed. [pmid: 11277141].
Beck CA, Joseph L, Belisle P, et al. Predictors of quality of life 6 months and 1 year after acute myocardial infarction. Am Heart J. 2001;142(2):271-9. Does not apply. [pmid: 11479466].
Bennett P, Brooke S. Intrusive memories, post-traumatic stress disorder and myocardial infarction. Br J Clin Psychol. 1999;38(Pt 4):411-6. Does not apply. [pmid: 10590829].
Bennett P, Lowe R, Mayfield T, et al. Coping, mood and behaviour following myocardial infarction: results of a pilot study. Cor Health Care. 1999;3(4):192-8. Does not apply.
Bennett P, Mayfield T, Norman P, et al. Affective and social-cognitive predictors of behavioural change following first myocardial infarction. Br J Health Psychol. 1999;4(3):247-256. Does not apply.
Bennett P, Owen RL, Koutsakis S, et al. Personality, social context and cognitive predictors of post-traumatic stress disorder in myocardial infarction patients. Psychol Health. 2002;17(4):489-500. Does not apply.
Berkman L, Jaffe A, Carney R, et al. Enhancing recovery in coronary heart disease (ENRICHD) study intervention: Rationale and design. Psychosom Med. 2001;63(5):747-755. No original data. [pmid: 11573023].
Berkman LF, Leo-Summers L, Horwitz RI. Emotional support and survival after myocardial infarction. A prospective, population-based study of the elderly. Ann Intern Med. 1992;117(12):1003-9. Does not apply.
Bhatia MS, Tiwari A, Balkrishna, et al. Type A behaviour, life events & myocardial infarction. Indian J Med Res. 1990;92:95-100. Does not apply. [pmid: 2370097].
Bianchi G, Fergusson D, Walshe J. Psychiatric antecedents of myocardial infarction. Med J Aust. 1978;1(6):297-301. Published before 1980. [pmid: 661688].
Billing E, Lindell B, Sederholm M, et al. Denial, anxiety, and depression following myocardial infarction. Psychosom 1980; 21(8): 639–41, 644–5. Does not apply
Black JL, Allison TG, Williams DE, et al. Effect of intervention for psychological distress on rehospitalization rates in cardiac rehabilitation patients. Psychosom. 1998;39(2):134-43. Patients with MI not reported separately and MI patients represent less 50% of sample.
Blair AJ, Leakey PN, Rust SR, et al. Locus of control and mood following myocardial infarction. Cor Health Care. 1999;3(3):140-4. Does not apply.
Boone T. Patient reactions to the exercise staff, program and prescription following myocardial infarction. Am Corr Ther J. 1986;40(3):62-67. Does not apply.
Bremer Schulte M, Pluym B, Van Schendel G. Reintegration with Duos: A self-care program following myocardial infarction. Patient Educ Counsel. 1986;8(3):233-244. Does not apply.
Brezinka V, Dusseldorp E, Maes S. Gender differences in psychosocial profile at entry into cardiac rehabilitation. J Cardiopulm Rehabil. 1998;18(6):445-9. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 9857277].
Brown JH. Depression after myocardial infarction. Can Med Assoc J. 1976;114(3):187. Published before 1980. [pmid: 1032347].
Brown MA, Munford A. Rehabilitation of post MI depression and psychological invalidism: a pilot study. Int J Psych Med. 1983-1984;13(4):291-8. Case report or case series.
Brown N, Melville M, Gray D, et al. Quality of life four years after acute myocardial infarction: short form 36 scores compared with a normal population. Heart. 1999;81(4):352-8. Does not apply. [pmid: 10092560]. [pmcid: 1728997].
Bruhn JG, Chandler B, Wolf S. A psychological study of survivors and nonsurvivors of myocardial infarction. Psychosom Med. 1969;31(1):8-19. Published before 1980. [pmid: 4388320].
Bruhn JG, Paredes A, Adsett CA, et al. Psychological predictors of sudden death in myocardial infarction. J Psychosom Res. 1974;18(3):187-91. Published before 1980. [pmid: 4156369].
Buchanan LM, Cowan M, Burr R, et al. Measurement of recovery from myocardial infarction using heart rate variability and psychological outcomes. Nurs Res. 1993;42(2):74-8. Does not apply. [pmid: 8455991].
Burrel G, Sundin O, Stroem G, et al. Heart and lifestyle: A Type A treatment program for myocardial infarction patients. Scand Behav Ther. 1986;15(3):87-93. Does not apply.
Byrne DG. Illness behaviour and psychosocial outcome after a heart attack. Br J Clin Psychol. 1982;21(Pt 2):145-6. No original data. [pmid: 7126953].
Carinci F, Nicolucci A, Ciampi A, et al. Role of interactions between psychological and clinical factors in determining 6-month mortality among patients with acute myocardial infarction. Application of recursive partitioning techniques to the GISSI-2 database. Gruppo Italiano per lo Studio della Sopravvivenza nell' Infarto Miocardico. Eur Heart J. 1997;18(5):835-45. Does not apply. [pmid: 9152654].
Carney RM, Freedland KE, Clark KA, et al. Psychosocial adjustment of patients arriving early at the emergency department after acute myocardial infarction. Am J Cardiol. 1992;69(3):160-2. Does not apply. [pmid: 1731451].
Carney RM, Freedland KE, Eisen SA, et al. Major depression and medication adherence in elderly patients with coronary artery disease. Health Psychol. 1995;14(1):88-90. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 7737079].
Carney RM, Freedland KE, Smith L, et al. Relation of depression and mortality after myocardial infarction in women. Circ. 1991;84(4):1876-7. Letter.
Carney RM, Freedland KE, Stein PK, et al. Change in heart rate and heart rate variability during treatment for depression in patients with coronary heart disease. Psychosom Med. 2000;62(5):639-47. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 11020093].
Carney RM, Rich MW, Tevelde A, et al. Major depressive disorder in coronary artery disease. Am J Cardiol. 1987;60(16):1273-1275. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 3687779].
Carney RM, Freedland KE, Stein PK, et al. Effects of depression on QT interval variability after myocardial infarction. Psychosom Med. 2003;65(2):177-180. Does not apply. [pmid: 12651984].
Carney RM, Rich MW, Freedland KE, et al. Major depressive disorder predicts cardiac events in patients with coronary artery disease. Psychosom Med. 1988;50(6):627-33. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 2976950].
Cassem NH, Hackett TP. Psychiatric consultation in a coronary care unit. Ann Intern Med. 1971;75(1):9-14. Published before 1980. [pmid: 5091570].
Catipovic-Veselica K, Marosevic L, Ilakovac V, et al. Bortner type A scores and eight basic emotions for survivors of ventricular fibrillation and left ventricular failure during acute myocardial infarction. Psychol Rep. 1996;79(3 Pt 2):1195-202. Does not apply. [pmid: 9009766].
Cay EL, Philip AE, Stuckey NA. Ten years in cardiac rehabilitation. Psych Fennica. 1981;Suppl:19-31. Does not apply.
Cay EL, Vetter N, Philip AE, et al. Psychological reactions to a coronary care unit. J Psychosom Res. 1972;16(6):437-47. Published before 1980. [pmid: 4666661].
Cay EL, Vetter N, Philip AE, et al. Psychological status during recovery from an acute heart attack. J Psychosom Res. 1972;16(6):425-35. Published before 1980. [pmid: 4666660].
Chalfont L, Bennett P. Personality and coping: their influence on affect and behaviour following myocardial infarction. Coronary Health Care. 1999;3(3):110-6. Does not apply.
Chiou A, Potempa K, Buschmann MB. Anxiety, depression and coping methods of hospitalized patients with myocardial infarction in Taiwan. Int J Nurs Stud. 1997;34(4):305-11. Unable to review. [pmid: 9306165].
Cleophas TJ, de Jong SJ, Niemeyer MG, et al. Changes in life-style in men under sixty years of age before and after acute myocardial infarction: a case-control study. Angiol. 1993;44(10):761-8. Does not apply.
Coelho R, Ramos E, Prata J, et al. Acute myocardial infarction: psychosocial and cardiovascular risk factors in men. J Cardiovasc Risk. 1999;6(3):157-62. Does not apply. [pmid: 10463142].
Cohen L, Stokhof LH, van der Ploeg HM, et al. Identifying patients recovering from a recent myocardial infarction who require and accept psychological care. Psychol Rep. 1996;79(3 Pt 2):1371-7. Does not apply. [pmid: 9009795].
Collins JA, Rice VH. Effects of relaxation intervention in phase II cardiac rehabilitation: replication and extension. Heart Lung. 1997;26(1):31-44. Does not apply. [pmid: 9013219].
Conn VS, Taylor SG, Abele PB. Myocardial infarction survivors: age and gender differences in physical health, psychosocial state and regimen adherence. J Adv Nurs. 1991;16(9):1026-34. Does not apply. [pmid: 1939915].
Conn VS, Taylor SG, Casey B. Cardiac rehabilitation program participation and outcomes after myocardial infarction. Rehabil Nurs. 1992;17(2):58-62. Does not apply. [pmid: 1553417].
Conroy RM, McGowan E, Mulcahy R. Improved subjective health in patients in a post coronary rehabilitation programme. Ir J Psychol Med. 1989;6(1):30-34. Does not apply.
Cossette S, Frasure-Smith N, LespĂ©rance F. Nursing approaches to reducing psychological distress in men and women recovering from myocardial infarction. Intl J Nurs Stud. 2002;39(5):479-94. Does not apply.
Cossette S, Frasure-Smith N, Lesperance F. Clinical implications of a reduction in psychological distress on cardiac prognosis in patients participating in a psychosocial intervention program. Psychosom Med. 2001;63(2):257-266. Unable to review. [pmid: 11292273].
Coyne KS, Lundergan CF, Boyle D, et al. Relationship of infarct artery patency and left ventricular ejection fraction to health-related quality of life after myocardial infarction: the GUSTO-I Angiographic Study experience. Circ. 2000;102(11):1245-51. Does not apply.
Crane PB, McSweeney JC. Exploring older women's lifestyle changes after myocardial infarction. Medsurg Nursing. 2003;12(3):170-6. Does not apply. [pmid: 12861754].
Czajkowski SM. Effects of Treating Depression and Low Perceived Social Support on Clinical Events after Myocardial Infarction: The Enhancing Recovery in Coronary Heart Disease Patients (ENRICHD) Randomized Trial. J Am Med Assoc. 2003;289(23):3106-3116. Duplicate citation.
Daly J, Elliott D, Cameron-Traub E, et al. Health status, perceptions of coping, social support immediately after discharge of survivors of acute myocardial infarction. Am J Crit Care. 2000;9(1):62-9. No usable data. [pmid: 10631392].
Deems P, Duyvis DJ, Beunderman R, et al. Myocardial infarction: One year later. Gedrag: Tijdschrift voor Psychologie. 1984;12(5):46-54. Does not apply.
Denollet J. Emotional distress and fatigue in coronary heart disease: the Global Mood Scale (GMS). Psychol Med. 1993;23(1):111-21. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 8475198].
Denollet J, Brutsaert DL. Personality, disease severity, the risk of long-term cardiac events in patients with a decreased ejection fraction after myocardial infarction. Circ. 1998;97(2):167-73. Does not apply.
Denollet J, Brutsaert DL. Reducing emotional distress improves prognosis in coronary heart disease-Year mortality in a clinical trial of rehabilitation. Circ. 2001;104(17):2018-2023. Does not apply.
Denollet J, Sys SU, Brutsaert DL. Personality and mortality after myocardial infarction. Psychosom Med. 1995;57(6):582-91. Does not apply. [pmid: 8600485].
Denollet J, Sys SU, Stroobant N, et al. Personality as independent predictor of long-term mortality in patients with coronary heart disease. Lancet. 1996;347(8999):417-21. Does not apply. [pmid: 8618481].
Desai MM, Rosenheck RA, Druss BG, et al. Mental disorders and quality of care among postacute myocardial infarction outpatients. J Nerv Ment Dis. 2002;190(1):51-3. Does not apply. [pmid: 11838034].
Dimsdale JE, Hackett TP, Hutter AM, et al. The association of clinical, psychosocial, angiographic variables with work status in patients with coronary artery disease. J Psychosom Res. 1982;26(2):215-221. Does not apply. [pmid: 7077552].
Doerfler LA, Pbert L, DeCosimo D. Symptoms of posttraumatic stress disorder following myocardial infarction and coronary artery bypass surgery. Gen Hosp Psychiatry. 1994;16(3):193-9. Does not apply. [pmid: 8063086].
Dorn J, Naughton J, Imamura D, et al. Correlates of compliance in a randomized exercise trial in myocardial infarction patients. Med Sci Sports Exerc. 2001;33(7):1081-9. Does not apply. [pmid: 11445753].
Drory Y, Kravetz S, Florian V. Psychosocial adjustment in patients after a first acute myocardial infarction: the contribution of salutogenic and pathogenic variables. Israel Study Group on First Acute Myocardial Infarction. Arch Phys Med Rehabil. 1999;80(7):811-8. Does not apply. [pmid: 10414767].
Elias MF, et al. A behavioral study of middle-aged chest pain patients: Physical symptom reporting, anxiety, depression. Exper Aging Research. 1982;8(1, Pt 2):45-51. Patients with MI not reported separately and MI patients represent less 50% of sample.
Esteve LG, Valdes M, Riesco N, et al. Denial mechanisms in myocardial infarction: their relations with psychological variables and short-term outcome. J Psychosom Res. 1992;36(5):491-6. Does not apply. [pmid: 1619589].
Fedoroff JP, Lipsey JR, Starkstein SE, et al. Phenomenological comparisons of major depression following stroke, myocardial infarction or spinal cord lesions. J Affect Disord. 1991;22(12):83-9. Does not apply. [pmid: 1880312].
Fielding R. Depression and acute myocardial infarction: a review and reinterpretation. Soc Sci Med. 1991;32(9):1017-28. No original data. [pmid: 2047894].
Fogel J, Fauerbach JA, Ziegelstein RC, et al. Quality of life in physical health domains predicts adherence among myocardial infarction patients even after adjusting for depressive symptoms. J Psychosom Res. 2004;56(1):75-82. Does not apply. [pmid: 14987967].
Follick MJ, Ahern DK, Gorkin L, et al. Relation of psychosocial and stress reactivity variables to ventricular arrhythmias in the Cardiac Arrhythmia Pilot Study (CAPS). Am J Cardiol. 1990;66(1):63-7. Does not apply. [pmid: 1694388].
Frasure-Smith N, Lesperance F, Gravel G, et al. Social support, depression, mortality during the first year after myocardial infarction. Circ. 2000;101(16):1919-24. Does not apply.
Frasure-Smith N, Lesperance F, Julien P. Major depression is associated with lower omega-3 fatty acid levels in patients with recent acute coronary syndromes. Biol Psychiatry. 2004;55(9):891-6. Does not apply. [pmid: 15110732].
Frasure-Smith N, Lesperance F, Talajic M. Depression and 18-month prognosis after myocardial infarction. Circ. 1995;91(4):999-1005. Does not apply.
Frasure-Smith N, Lesperance F, Talajic M. The impact of negative emotions on prognosis following myocardial infarction: is it more than depression?. Health Psychol. 1995;14(5):388-98. Does not apply. [pmid: 7498109].
Frasure-Smith N, Lesperance F, and Talajic M. The prognostic importance of depression, anxiety, anger, and social support following myocardial infarction: Opportunities for improving survival. 2000; 203–228. Book chapter
Friedmann E, Thomas SA. Pet ownership, social support, one-year survival after acute myocardial infarction in the Cardiac Arrhythmia Suppression Trial (CAST). Am J Cardiol. 1995;76(17):1213-7. No data on when MI occurred relative to when depression assessed. [pmid: 7502998].
Friedmann E, Thomas SA. Pet ownership, social support, and one-year survival after acute myocardial infarction in the Cardiac Arrhythmia Suppression Trial (CAST). Am J Cardiol 1995; 76(17): 1213–7. No data on when MI occurred relative to when depression assessed
Froese A, Hackett TP, Cassem NH, et al. Trajectories of anxiety and depression in denying and nondenying acute myocardial infarction patients during hospitalization. J Psychosom Res. 1974;18(6):413-20. Published before 1980. [pmid: 4443957].
Fukunishi I, Hattori M. Mood states and Type A behavior in Japanese male patients with myocardial infarction. Psychother Psychosom. 1997;66(6):314-8. Does not apply. [pmid: 9403921].
Gallagher R, McKinley S, Dracup K. Effects of a telephone counseling intervention on psychosocial adjustment in women following a cardiac event. Heart Lung. 2003;32(2):79-87. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 12734530].
Glassman AH, Roose SP, Bigger JT Jr. The safety of tricyclic antidepressants in cardiac patients: Risk-benefit reconsidered. J Am Med Assoc. 1993;269(20):2673-2675. No original data.
Gonzalez-Jaimes EI, Turnbull-Plaza B. Selection of psychotherapeutic treatment for adjustment disorder with depressive mood due to acute myocardial infarction. Arch Med Res. 2003;34(4):298-304. Does not apply. [pmid: 12957527].
Gonzalez MB, Snyderman TB, Colket JT, et al. Depression in patients with coronary artery disease. Dep. 1996;4(2):57-62. Patients with MI not reported separately and MI patients represent less 50% of sample.
Griego LC. Physiologic and psychologic factors related to depression in patients after myocardial infarction: a pilot study. Heart Lung. 1993;22(5):392-400. Case report or case series. [pmid: 8226002].
Gross R, Kindler S. Occurrence of high levels of posttraumatic stress disorder symptoms in patients who had survived a myocardial infarction or coronary artery bypass graft surgery. Gen Hosp Psychiatry. 1995;17(1):56-7. Letter. [pmid: 7737498].
Grossarth-Maticek R, Kanazir DT, Vetter H, et al. Smoking as a risk factor for lung cancer and cardiac infarct as mediated by psychosocial variables. A prospective investigation. Psychother Psychosom. 1983;39(2):94-105. Does not apply.
Guinjoan SM, De Guevara MS, Correa C, et al. Cardiac parasympathetic dysfunction related to depression in older adults with acute coronary syndromes. J Psychosom Res. 2004;56(1):83-8. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 14987968].
Guiry E, Conroy RM, Hickey N, et al. Psychological response to an acute coronary event and its effect on subsequent rehabilitation and lifestyle change. Clin Cardiol. 1987;10(4):256-60. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 3581537].
Hallas CN, Thornton EW. Effects of SSRI antidepressant treatment upon mood status and blood pressure reactivity to demand in coronary patients. Coronary Health Care. 2000;4(1):2-9. Does not apply.
Hallstrom T, Lapidus L, Bengtsson C, et al. Psychosocial factors and risk of ischaemic heart disease and death in women: a twelve-year follow-up of participants in the population study of women in Gothenburg, Sweden. J Psychosom Res. 1986;30(4):451-9. Does not apply. [pmid: 3761229].
Hamalainen H, Smith R, Puukka P, et al. Social support and physical and psychological recovery one year after myocardial infarction or coronary artery bypass surgery. Scand J Public Health. 2000;28(1):62-70. Does not apply. [pmid: 10817316].
Havik OE, Maeland JG. Changes in smoking behavior after a myocardial infarction. Health Psychol. 1988;7(5):403-20. Does not apply. [pmid: 3215153].
Herrmann C, Brand-Driehorst S, Kaminsky B, et al. Diagnostic groups and depressed mood as predictors of 22-month mortality in medical inpatients. Psychosom Med. 1998;60(5):570-7. Study population mixed and MI patients not reported separately. [pmid: 9773760].
Hevey D, Brown A, Cahill A, et al. Four-week multidisciplinary cardiac rehabilitation produces similar improvements in exercise capacity and quality of life to a 10-week program. J Cardiopulm Rehabil. 2003;23(1):17-21. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 12576907].
Hlatky MA, Haney T, Barefoot JC, et al. Medical, psychological and social correlates of work disability among men with coronary artery disease. Am J Cardiol. 1986;58(10):911-5. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 3776848].
Honig A. Depression after first myocardial infarction. 8th Congress of the Association of European Psychiatrists. London, UK. 7–12th July, 1996. Does not apply
Horlick L, Cameron R, Firor W, et al. The effects of education and group discussion in the post myocardial infarction patient. J Psychosom Res. 1984;28(6):485-92. Does not apply. [pmid: 6520804].
Horsten M, Mittleman MA, Wamala SP, et al. Depressive symptoms and lack of social integration in relation to prognosis of CHD in middle-aged women. The Stockholm Female Coronary Risk Study. Eur Heart J. 2000;21(13):1072-80. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 10843825].
Huijbrechts IP, Duivenvoorden HJ, Deckers JW, et al. Modification of smoking habits five months after myocardial infarction: relationship with personality characteristics. J Psychosom Res. 1996;40(4):369-78. Does not apply. [pmid: 8736417].
Ickovics JR, Viscoli CM, Horwitz RI. Functional recovery after myocardial infarction in men: the independent effects of social class. Ann Intern Med. 1997;127(7):518-25. Does not apply. [pmid: 9313019].
Johnston M, Pollard B, Hennessey P. Construct validation of the hospital anxiety and depression scale with clinical populations. J Psychosom Res. 2000;48(6):579-84. Reports depression as a continuous variable. [pmid: 11033377].
Jones DA, West RR. Psychological rehabilitation after myocardial infarction: multicentre randomised controlled trial. BMJ. 1996;313(7071):1517-21. Does not apply. [pmid: 8978226]. [pmcid: 2353074].
Julkunen J, Idaenpaeaen-Heikkilae U, and Saarinen T. Type A behaviour, anxiety, and the first-year prognosis of a myocardial infarction. 1990; 331–337. Does not apply
Julkunen J, Saarinen T. Psychosocial predictors of recovery after a myocardial infarction: Development of a comprehensive assessment method. Ir J Psychol. 1994;15(1):67-83. Does not apply.
Kavanagh T, Shephard RJ, Tuck JA. Depression after myocardial infarction. Can Med Assoc J. 1975;113(1):23-7. Published before 1980. [pmid: 1148970]. [pmcid: 1956314].
Kisely S, Guthrie E, Creed F, et al. Predictors of mortality and morbidity following admission with chest pain. J R Coll Physicians Lond. 1997;31(2):177-83. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 9131519].
Kishi Y, Robinson RG, Kosier JT. Suicidal ideation among patients during the rehabilitation period after life-threatening physical illness. J Nerv Ment Dis. 2001;189(9):623-8. Does not apply. [pmid: 11580007].
Kishi Y, Robinson RG, Kosier JT. Suicidal ideation among patients with acute life-threatening physical illness: patients with stroke, traumatic brain injury, myocardial infarction, spinal cord injury. Psychosom. 2001;42(5):382-90. Study population mixed and MI patients not reported separately.
Kishida H, Saito T, Fukuma N, et al. Combination of ambulatory electrocardiographic monitoring and psychological testing in coronary artery disease patients. Jpn J Med. 1990;29(4):384-90. Does not apply. [pmid: 2273622].
Koenig HG, Meador KG, Cohen HJ, et al. Depression in elderly hospitalized patients with medical illness. Arch Intern Med. 1988;148(9):1929-36. Study population mixed and MI patients not reported separately. [pmid: 3415405].
Kohn LM, Sleet DA, Carson JC, et al. Life changes and urinary norepinephrine in myocardial infarction. J Human Stress. 1983;9(2):38-45. Does not apply.
Kozmar D, Catipovic-Veselica K, Galic A, et al. Depression in acute coronary syndrome. Psychol Rep. 2003;93(3 Pt 2):1105-8. Reports depression as a continuous variable. [pmid: 14765578].
Kugler J, Dimsdale JE, Hartley LH, et al. Hospital supervised vs home exercise in cardiac rehabilitation: effects on aerobic fitness, anxiety, depression. Arch Phys Med Rehabil. 1990;71(5):322-5. Depression status at baseline not available. [pmid: 2327885].
Kuijpers PMJC, Hamulyak K, Strik JJMH, et al. Beta-thromboglobulin and platelet factor 4 levels in post-myocardial infarction patients with major depression. Psych Res. 2002;109(2):207-210. Duplicate citation.
Kurosawa H, Shimizu Y, Nishimatsu Y, et al. The relationship between mental disorders and physical severities in patients with acute myocardial infarction. Jpn Circ J. 1983;47(6):723-8. No validated depression measure used. [pmid: 6854926].
Ladwig KH, Lehmacher W, Roth R, et al. Factors which provoke post-infarction depression: results from the post-infarction late potential study (PILP). J Psychosom Res. 1992;36(8):723-9. Does not apply. [pmid: 1432862].
Ladwig KH, Roll G, Breithardt G, et al. Post-infarction depression and incomplete recovery 6 months after acute myocardial infarction. Lancet. 1994;343(8888):20-3. Does not apply. [pmid: 7905043].
Laghrissi-Thode F, Wagner WR, Pollock BG, et al. Elevated platelet factor 4 and beta-thromboglobulin plasma levels in depressed patients with ischemic heart disease. Biol Psych. 1997;42(4):290-5. Patients with MI not reported separately and MI patients represent less 50% of sample.
Lane D, Carroll D, Ring C, et al. Do depression and anxiety predict recurrent coronary events 12 months after myocardial infarction?. Q J Med. 2000;93(11):739-44. Does not apply.
Lane D, Carroll D, Ring C, et al. Predictors of attendance at cardiac rehabilitation after myocardial infarction. J Psychosom Res. 2001;51(3):497-501. Does not apply. [pmid: 11602219].
Lee H, Kohlman GC, Lee K, et al. Fatigue, mood, hemodynamic patterns after myocardial infarction. Appl Nurs Res. 2000;13(2):60-9. Does not apply. [pmid: 10842901].
Leineweber C, Kecklund G, Janszky I, et al. Poor sleep increases the prospective risk for recurrent events in middle-aged women with coronary disease: The Stockholm Female Coronary Risk Study. J Psychosom Res. 2003;54(2):121-127. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 12573733].
Leon AC, Portera L, Walkup JT. The development and evaluation of the brief depression screen in medically ill disability claimants. Int J Psychiatry Med. 2001;31(4):389-400. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 11949737].
Levine JB, Covino NA, Slack WV, et al. Psychological predictors of subsequent medical care among patients hospitalized with cardiac disease. J Cardiopulm Rehabil. 1996;16(2):109-16. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 8681155].
Lewin B, Robertson IH, Cay EL, et al. Effects of self-help post-myocardial-infarction rehabilitation on psychological adjustment and use of health services. Lancet. 1992;339(8800):1036-40. Does not apply. [pmid: 1349062].
Linden B. Evaluation of a home-based rehabilitation programme for patients recovering from acute myocardial infarction. Intensive Crit Care Nurs. 1995;11(1):10-9. Does not apply. [pmid: 7711393].
Liu-JD, Zheng-H. Efficacy of fluoxetine in the treatment of depression in patients with acute myocardial infarction. J Clin Psycholl Med. 1999;9(4):210-211. Incorrect citation.
Lloyd GG, Cawley RH. Distress or illness? A study of psychological symptoms after myocardial infarction. Br J Psychiatry. 1983;142:120-5. Does not apply. [pmid: 6839066].
Lloyd GG, Cawley RH. Psychiatric morbidity after myocardial infarction. Q J Med. 1982;51(201):33-42. Does not apply. [pmid: 7111673].
Lloyd GG, Cawley RH. Psychiatric morbidity in men one week after first acute myocardial infarction. Br Med J. 1978;2(6150):1453-4. Published before 1980. [pmid: 719460]. [pmcid: 1608691].
MacKenzie G. Role patterns and emotional responses of women with ischemic heart disease 4 to 6 weeks after discharge from hospital. Can J Cardiovasc Nurs. 1993;4(2):9-15. No usable data. [pmid: 8148069].
Maeland JG, Havik OE. Psychological predictors for return to work after a myocardial infarction. J Psychosom Res. 1987;31(4):471-81. Depression not reported separately. [pmid: 3668885].
Maeland JG, Havik OE. Use of health services after a myocardial infarction. Scand J Soc Med. 1989;17(1):93-102. Does not apply. [pmid: 2711151].
Marchionni N, Fattirolli F, Fumagalli S, et al. Determinants of exercise tolerance after acute myocardial infarction in older persons. J Am Geriatr Soc. 2000;48(2):146-53. Does not apply. [pmid: 10682943].
Mayou R, Foster A, Williamson B. Psychosocial adjustment in patients one year after myocardial infarction. J Psychosom Res. 1978;22(5):447-53. Published before 1980. [pmid: 745164].
Mayou RA, Thompson DR, Clements A, et al. Guideline-based early rehabilitation after myocardial infarction: A pragmatic randomised controlled trial. J Psychosom Res. 2002;52(2):89-95. Does not apply. [pmid: 11832254].
McGee HM, Johnston M, Pollard B, et al. Does myocardial infarction have a greater impact on women than on men? Testing hypotheses about the effects of gender role models and responsibilities. Eur Rev of Appl Psychol. 2000;50(3):333-340. No data on when MI occurred relative to when depression assessed.
Mendes de Leon CF, DiLillo V, Czajkowski S, et al. Psychosocial characteristics after acute myocardial infarction: The ENRICHD pilot study. J Cardiopulm Rehabil. 2001;21(6):353-362. Does not apply. [pmid: 11767809].
Milani RV, Lavie CJ. Behavioral differences and effects of cardiac rehabilitation in diabetic patients following cardiac events. Am J Med. 1996;100(5):517-23. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 8644763].
Milani RV, Lavie CJ. Prevalence and effects of cardiac rehabilitation on depression in the elderly with coronary heart disease. Am J Cardiol. 1998;81(10):1233-6. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 9604957].
Milani RV, Lavie CJ, Cassidy MM. Effects of cardiac rehabilitation and exercise training programs on depression in patients after major coronary events. Am Heart J. 1996;132(4):726-732. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 8831359].
Moser DK, Dracup K. Psychosocial recovery from a cardiac event: the influence of perceived control. Heart Lung. 1995;24(4):273-80. Reports depression as a continuous variable. [pmid: 7591794].
Naismith LD, Robinson JF, Shaw GB, et al. Psychological rehabilitation after myocardial infarction. Br Med J. 1979;1(6161):439-42. Published before 1980. [pmid: 427400]. [pmcid: 1597752].
Nir Z, Neumann L. Motivation patterns, self-esteem, depression of patients after first myocardial infarction. Behav Med. 1990;16(2):62-6. Reports depression as a continuous variable. [pmid: 2364178].
O'Carroll RE, Smith KB, Grubb NR, et al. Psychological factors associated with delay in attending hospital following a myocardial infarction. J Psychosom Res. 2001;51(4):611-614. Reports depression as a continuous variable. [pmid: 11595250].
Obier K, Haywood LJ. Psycho-social problems of coronary care unit patients. J Natl Med Assoc. 1971;63(6):425-8. Published before 1980. [pmid: 5130042]. [pmcid: 2608885].
Oldridge N, Furlong W, Feeny D, et al. Economic evaluation of cardiac rehabilitation soon after acute myocardial infarction. Am J Cardiol. 1993;72(2):154-61. Does not apply. [pmid: 8328376].
Oldridge N, Guyatt G, Jones N, et al. Effects on quality of life with comprehensive rehabilitation after acute myocardial infarction. Am J Cardiol. 1991;67(13):1084-9. Does not apply. [pmid: 2024598].
Oldridge N, Perkins A, Hodes Z. Comparison of three heart disease specific health-related quality of life instruments. Monaldi Arch Chest Dis. 2002;58(1):10-8. Does not apply. [pmid: 12693064].
Oldridge N, Streiner D, Hoffmann R, et al. Profile of mood states and cardiac rehabilitation after acute myocardial infarction. Med Sci Sports Exerc. 1995;27(6):900-5. Does not apply. [pmid: 7658953].
Paeivaerinta A, Verkkoniemi A, Niinistoe L, et al. The prevalence and associates of depressive disorders in the oldest-old Finns. Soc Psychiatry Psychiatr Epidemiol. 1999;34(7):352-359. No data on when MI occurred relative to when depression assessed. [pmid: 10477955].
Palinkas LA. Psychosocial therapy reduced the risk of cardiovascular death at 2 years after “out of hospital” sudden cardiac arrest. Evidence-Based Mental Health. 2001;4(4):108. Brief of article.
Pathy MS, Peach H. Disability among the elderly after myocardial infarction: a 3-year follow-up. J R Coll Physicians Lond. 1980;14(4):221-3. No validated depression measure used. [pmid: 6256543].
Peach H, Pathy J. Disability in the elderly after myocardial infarction. J R Coll Physicians Lond. 1979;13(3):154-7. Published before 1980. [pmid: 157393].
Pedersen SS, Middel B, Larsen ML. Posttraumatic stress disorder in first-time myocardial infarction patients. Heart Lung. 2003;32(5):300-7. Does not apply. [pmid: 14528187].
Pedersen SS, Middel B, Larsen ML. The role of personality variables and social support in distress and perceived health in patients following myocardial infarction. J Psychosom Res. 2002;53(6):1171-5. Does not apply. [pmid: 12480001].
Petersen LA, Normand SL, Druss BG, et al. Process of care and outcome after acute myocardial infarction for patients with mental illness in the VA health care system: are there disparities?. Health Serv Res. 2003;38(1 Pt 1):41-63. Does not apply. [pmid: 12650380]. [pmcid: 1360873].
Pitzalis MV, Iacoviello M, Todarello O, et al. Depression but not anxiety influences the autonomic control of heart rate after myocardial infarction. Am Heart J. 2001;141(5):765-71. Does not apply. [pmid: 11320364].
Plevier CM, Mooy JM, Marang-Van de Mheen PJ, et al. Persistent impaired emotional functioning in survivors of a myocardial infarction?. Qual Life Res. 2001;10(2):123-32. Does not apply. [pmid: 11642682].
Pratt LA, Ford DE, Crum RM, et al. Depression, psychotropic medication, risk of myocardial infarction. Prospective data from the Baltimore ECA follow-up. Circ. 1996;94(12):3123-9. Does not apply.
Pruneti CA, L'Abbate A, Steptoe A. Personality and behavioral changes in patients after myocardial infarction. Res Commun Psychol Psychiatry Behav. 1993;18(12):37-51. Does not apply.
Enhancing recovery in coronary heart disease (ENRICHD): baseline characteristics. Am J Cardiol 2001; 88(3): 316–22. Does not apply
Rabilloud M, Cao D, Riche B, et al. Impact of selected geographical and clinical conditions on thrombolysis rate in myocardial infarction in three departments of France. Eur J Epidemiol. 2001;17(7):685-91. Does not apply. [pmid: 12086084].
Rahe RH, Ward HW, Hayes V. Brief group therapy in myocardial infarction rehabilitation: three- to four-year follow-up of a controlled trial. Psychosom Med. 1979;41(3):229-42. Published before 1980. [pmid: 314119].
Raskind M, Veith R, Barnes R, et al. Cardiovascular and antidepressant effects of imipramine in the treatment of secondary depression in patients with ischemic heart disease. Am J Psychiatry. 1982;139(9):1114-7. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 6180649].
Riegel B, Gocka I. Gender differences in adjustment to acute myocardial infarction. Heart Lung. 1995;24(6):457-66. Does not apply. [pmid: 8582821].
Riegel BJ. Contributors to cardiac invalidism after acute myocardial infarction. Coron Artery Dis. 1993;4(2):215-20. Does not apply. [pmid: 8269214].
Riegel BJ, Dracup KA. Does overprotection cause cardiac invalidism after acute myocardial infarction?. Heart Lung. 1992;21(6):529-35. Does not apply. [pmid: 1446999].
Roberts SL. Cognitive model of depression and the myocardial infarction patient. Prog Cardiovasc Nurs. 1989;4(2):61-70. No original data. [pmid: 2740325].
Rosen JL, Bibring GL. Psychological reactions of hospitalized male patients to a heart attack. Age and social-class differences. Psychosom Med. 1966;28(6):808-21. Published before 1980. [pmid: 5972494].
Rumsfeld JS, Magid DJ, Plomondon ME, et al. History of depression, angina, quality of life after acute coronary syndromes. Am Heart J. 2003;145(3):493-9. Does not apply. [pmid: 12660673].
Runions J. A program for psychological and social enhancement during rehabilitation after myocardial infarction. Heart Lung. 1985;14(2):117-25. No original data. [pmid: 3844391].
Saito M, Fuseno H, Honda T, et al. Clinical problems in the management of patients with acute myocardial infarction from its onset to the patients' return to work. Jpn Circ J. 1983;47(6):686-95. Does not apply. [pmid: 6854923].
Saks K, Kolk H, Allev R, et al. Health status of the older population in Estonia. Croat Med J. 2001;42(6):663-8. Does not apply. [pmid: 11740851].
Salisbury H. Home-based myocardial infarction rehabilitation. Health Visitor. 1997;70(7):265-6. No original data.
Sarantidis D, Thomas A, Iphantis K, et al. Levels of anxiety, depression and denial in patients with myocardial infarction. Eur Psychiatry. 1997;12(3):149-151. Does not apply. [pmid: 19698522].
Sauer WH, Berlin JA, Kimmel SE. Selective serotonin reuptake inhibitors and myocardial infarction. Circ. 2001;104(16):1894-8. Does not apply.
Schleifer SJ, Macari-Hinson MM, Coyle DA, et al. The nature and course of depression following myocardial infarction. Arch Intern Med. 1989;149(8):1785-9. Does not apply. [pmid: 2788396].
Schomer HH, Noakes TD. The psychological effect of exercise training on patients after a myocardial infarction. A pilot study. S Afr Med J. 1983;64(13):473-5. Does not apply.
Schwarcz G, Lopez-Toca R. Continued lithium treatment after myocardial infarction. Am J Psychiatry. 1982;139(2):255. Letter. [pmid: 7055304].
Sengupta AN, Sengupta M. Psychological reaction after myocardial infarction. J Indian Med Assoc. 1972;58(7):241-2. Published before 1980. [pmid: 5046613].
Serebruany VL, Glassman AH, Malinin AI, et al. Enhanced platelet/endothelial activation in depressed patients with acute coronary syndromes: evidence from recent clinical trials. Blood Coagul Fibrinolysis. 2003;14(6):563-7. Does not apply. [pmid: 12960610].
Sesso HD, Kawachi I, Vokonas PS, et al. Depression and the risk of coronary heart disease in the Normative Aging Study. Am J Cardiol. 1998;82(7):851-6. Does not apply. [pmid: 9781966].
Sherrard H. Counselling after a myocardial infarction improved mood for patients and their partners and decreased patient functional limitations [commentary on Johnston M, Foulkes J, Johnston DW, et al. Impact on patients and partners of inpatient and extended cardiac counseling and rehabilitation: a controlled trial. Psychsom Med 1999 Mar/Apr;61:255–33]. Evidence-Based Nursing. 2000;3(1):21. Meeting abstract.
Sihm I, Dehlholm G, Hansen ES, et al. Psychic vulnerability and type-A behavior among young Danish male survivors of acute myocardial infarction. Nordisk Psykiatrisk Tidsskrift. 1991;45(6):451-456. Does not apply.
Silverstone PH. Depression and outcome in acute myocardial infarction. Br Med J (Clin Res Ed). 1987;294(6566):219-20. Does not apply.
Silverstone PH. Depression increases mortality and morbidity in acute life-threatening medical illness. J Psychosom Res. 1990;34(6):651-7. Study population mixed and MI patients not reported separately. [pmid: 2290137].
Singh J, Singh S, Singh A, et al. Sex life and psychiatric problems after myocardial infarction. J Assoc Physicians India. 1970;18(5):503-7. Published before 1980. [pmid: 5474272].
Sloan RP, Bigger JT Jr. Biobehavioral factors in Cardiac Arrhythmia Pilot Study (CAPS). Review and examination. Circ. 1991;83(4 Suppl):II52-7. No original data.
Soederman E, Lisspers J, Sundin O. Depression as a predictor of return to work in patients with coronary artery disease. Soc Sci Med. 2003;56(1):193-202. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 12435561].
Soloff PH. Medically and surgically treated coronary patients in cardiovascular rehabilitation: a comparative study. Int J Psychiatry Med. 1978-1979;9(1):93-106. Published before 1980. [pmid: 309869].
Spittle B, JAmes B. Psychosocial factors and myocardial infarction. Aust N Z J Psychiatry. 1977;11(1):37-43. Published before 1980. [pmid: 266928].
Stansfeld SA, Sharp DS, Gallacher JE, et al. A population survey of ischaemic heart disease and minor psychiatric disorder in men. Psychol Med. 1992;22(4):939-49. Does not apply. [pmid: 1488489].
Stein PK, Carney RM, Freedland KE, et al. Severe depression is associated with markedly reduced heart rate variability in patients with stable coronary heart disease. J Psychosom Res. 2000;48(45):493-500. Does not apply. [pmid: 10880671].
Stern MJ, Gorman PA, Kaslow L. The group counseling v exercise therapy study. A controlled intervention with subjects following myocardial infarction. Arch Intern Med. 1983;143(9):1719-25. Does not apply. [pmid: 6615094].
Stern MJ, Pascale L, Ackerman A. Life adjustment postmyocardial infarction: determining predictive variables. Arch Intern Med. 1977;137(12):1680-5. Published before 1980. [pmid: 931475].
Stern MJ, Pascale L, McLoone JB. Psychosocial adaptation following an acute myocardial infarction. J Chronic Dis. 1976;29(8):513-26. Published before 1980. [pmid: 956331].
Stewart RA, North FM, West TM, et al. Depression and cardiovascular morbidity and mortality: cause or consequence?. Eur Heart J. 2003;24(22):2027-37. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 14613739].
Sundin O, Lisspers J, Hofman-Bang C, et al. Comparing multifactorial lifestyle interventions and stress management in coronary risk reduction. Int J Behav Med. 2003;10(3):191-204. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 14525716].
Surtees PG, Wainwright NWJ, Khaw K-T, et al. Functional health status, chronic medical conditions and disorders of mood. Br J Psychiatry. 2003;183:299-303. Does not apply. [pmid: 14519607].
Sykes DH, Arveiler D, Salters CP, et al. Psychosocial risk factors for heart disease in France and North Ireland: The prospective epidemiological study of myocardial infarction (PRIME). Int J Epidemiol. 2002;31(6):1227-1234. Does not apply. [pmid: 12540727].
Sykes DH, Hanley M, Boyle DM, et al. Work strain and the post-discharge adjustment of patients following a heart attack. Psychol Health. 2000;15(5):609-23. Does not apply.
Taylor DK, Barber KR, McIntosh BA, et al. The impact of post acute myocardial infarction (AMI) depression on patient compliance and risk factor modification. Psychol Health Med. 1998;3(4):439-442. Unable to review.
Thomas SA, Friedmann E, Wimbush F, et al. Psychological factors and survival in the cardiac arrhythmia suppression trial (CAST): a reexamination. Am J Crit Care. 1997;6(2):116-26. Does not apply. [pmid: 9172848].
Thompson DR. A randomized controlled trial of in-hospital nursing support for first time myocardial infarction patients and their partners: effects on anxiety and depression. J Adv Nurs. 1989;14(4):291-7. Reports depression as a continuous variable. [pmid: 2738227].
Thompson DR, Meddis R. A prospective evaluation of in-hospital counseling for first time myocardial infarction men. J Psychosom Res. 1990;34(3):237-48. Does not apply. [pmid: 2341993].
Thornton EW, Hallas CN. Affective status following myocardial infarction can predict long-term heart rate variability and blood pressure reactivity. Br J Health Psychol. 1999;4(3):231-245. Does not apply.
Trzcieniecka-Green A, Steptoe A. The effects of stress management on the quality of life of patients following acute myocardial infarction or coronary bypass surgery. Eur Heart J. 1996;17(11):1663-70. Does not apply. [pmid: 8922914].
Trzcieniecka-Green A, Steptoe A. Stress management in cardiac patients: a preliminary study of the predictors of improvement in quality of life. J Psychosom Res. 1994;38(4):267-80. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 8064645].
Tsivil'ko MA, Korkina MV, Moiseev VS, et al. Conditions for the formation of mental disorders secondary to myocardial infarct. J Russian East Eur Psychiatry. 1993;26(1):71-79. Does not apply.
Turner SC, Evans JA, Bethell HJN, et al. Psychological assessments for cardiac rehabilitation patients. Int. J. Cardiol. 2003;92(23):201-207. No data on when MI occurred relative to when depression assessed. [pmid: 14659854].
Unden A-L, Schenck-Gustafsson K, Axelsson P-O, et al. Positive effects of increased nurse support for male patients after acute myocardial infarction. Quality of Life Research: An Intl J Quality of Life Aspects of Treatment, Care Rehabil. 1993;2(2):121-127. Does not apply.
van den Brink RH, van Melle JP, Honig A, et al. Treatment of depression after myocardial infarction and the effects on cardiac prognosis and quality of life: rationale and outline of the Myocardial Infarction and Depression-Intervention Trial (MIND-IT). Am Heart J. 2002;144(2):219-25. Does not apply. [pmid: 12177637].
van Dijl H, Nagelkerke N. Statistical discrimination of male myocardial infarction patients and healthy males by means of psychological test and a tracing of basic dimensions of the infarction personality. Psychother Psychosom. 1980;34(23):196-203. Does not apply. [pmid: 7220771].
van Dixhoorn J, Duivenvoorden HJ, Pool J. Success and failure of exercise training after myocardial infarction: is the outcome predictable?. J Am Coll Cardiol. 1990;15(5):974-82. Does not apply. [pmid: 2312985].
van Dixhoorn J DHPJ. Success and failure of exercise training after myocardial infarction: is the outcome predictable? [see comments]. J Am Coll Cardiol. 1990;15(5):974-82. Does not apply. [pmid: 2312985].
van Elderen-van Kemenade T, Maes S, van den Broek Y. Effects of a health education programme with telephone follow-up during cardiac rehabilitation. Br J Clin Psychol. 1994;33(Pt 3):367-78. Does not apply. [pmid: 7994223].
van Jaarsveld CHM, Sanderman R, Miedema I, et al. Changes in health-related quality of life in older patients with acute myocardial infarction or congestive heart failure: A prospective study. J Amer Geriatr Soc. 2001;49(8):1052-1058. Does not apply. [pmid: 11555066].
Vazquez-Barquero JL, Padierna Acero JA, Ochoteco A, et al. Mental illness and ischemic heart disease: analysis of psychiatric morbidity. Gen Hosp Psychiatry. 1985;7(1):15-20. Patients with MI not reported separately and MI patients represent less 50% of sample. [pmid: 3871415].
Visser MC, Koudstaal PJ, Erdman RA, et al. Measuring quality of life in patients with myocardial infarction or stroke: a feasibility study of four questionnaires in The Netherlands. J Epidemiol Community Health. 1995;49(5):513-7. Does not apply. [pmid: 7499995]. [pmcid: 1060156].
Waltz M, Badura B, Pfaff H, et al. Marriage and the psychological consequences of a heart attack: a longitudinal study of adaptation to chronic illness after 3 years. Soc Sci Med. 1988;27(2):149-58. Does not apply. [pmid: 3175701].
Warren JR, Whall AL. Development of an intervention to cope with depression following myocardial infarction. A nurse-facilitated cardiac support group. J Gerontol Nurs. 2001;27(5):24-5. No original data.
Webb MS, Riggin OZ. A comparison of anxiety levels of female and male patients with myocardial infarction. Crit Care Nurse. 1994;14(1):118-24. Does not apply. [pmid: 8194314].
Webster KK, Christman NJ. Perceived uncertainty and coping: post myocardial infarction. West J Nurs Res. 1988;10(4):384-96. Does not apply. [pmid: 3188499].
Wei M, Hornung CA, Thompson WG, et al. Depression and survival following myocardial infarction [5]. J Am Med Assoc. 1994;271(14):1080-1082. Correction table for another article.
Wells KB, Rogers W, Burnam MA, et al. Course of depression in patients with hypertension, myocardial infarction, or insulin-dependent diabetes. Am J Psychiatry. 1993;150(4):632-8. Does not apply. [pmid: 8465882].
West RR, Evans DA. Lifestyle changes in long term survivors of acute myocardial infarction. J Epidemiol Community Health. 1986;40(2):103-9. Does not apply. [pmid: 3746170]. [pmcid: 1052502].
West RR EDHA. Changes in life-style after early or late mobilization following acute myocardial infarction: A ten-year follow-up of a randomized controlled trial. J Cardiopulm Rehabil. 1986;6(3):113-119. Does not apply.
Westin L, Carlsson R, Erhardt L, et al. Differences in quality of life in men and women with ischemic heart disease. A prospective controlled study. Scand Cardiovasc J. 1999;33(3):160-5. Does not apply.
Westin L, Carlsson R, Israelsson B, et al. Quality of life in patients with ischaemic heart disease: a prospective controlled study. J Intern Med. 1997;242(3):239-47. Does not apply. [pmid: 9350169].
Wiklund I, Herlitz J, Hjalmarson A. Quality of life five years after myocardial infarction. Eur Heart J. 1989;10(5):464-72. Does not apply. [pmid: 2759109].
Wiklund I, Welin C. A comparison of different psychosocial questionnaires in patients with myocardial infarction. Scand J Rehabil Med. 1992;24(4):195-202. Does not apply. [pmid: 1485146].
Willmer KA, Abraheem A, Hackett K, et al. Rehabilitation following myocardial infarction: evaluation of both 'fast-track' and low level exercise on both physical and psychological parameters. Coronary Health Care. 1999;3(4):178-82. Does not apply.
Winefield HR, Martin CJ. Measurement and prediction of recovery after myocardial infarction. Int J Psychiatry Med. 1981-1982;11(2):145-54. Does not apply. [pmid: 7263131].
Wishnie HA, Hackett TP, Cssem NH. Psychological hazards of convalescence following myocardial infarction. JAMA. 1971;215(8):1292-6. Published before 1980. [pmid: 5107558].
Worcester MC, Hare DL, Oliver RG, et al. Early programmes of high and low intensity exercise and quality of life after acute myocardial infarction. BMJ. 1993;307(6914):1244-7. Does not apply. [pmid: 8281056]. [pmcid: 1679381].
Wrzesniewski K, Debska B, Tyminska-Sedek K. Type A behavior pattern and emotional dynamics after myocardial infarction. Polish Psychol Bulletin. 1994;25(1):33-41. Does not apply.
Yates BC. The relationships among social support and short- and long-term recovery outcomes in men with coronary heart disease. Res Nurs Health. 1995;18(3):193-203. Does not apply. [pmid: 7754090].
Yoshida T, Kohzuki M, Yoshida K, et al. Physical and psychological improvements after phase II cardiac rehabilitation in patients with myocardial infarction. Nurs Health Sci. 1999;1(3):163-70. Does not apply. [pmid: 10894639].
Yoshida T, Yoshida K, Yamamoto C, et al. Effects of a two-week, hospitalized phase II cardiac rehabilitation program on physical capacity, lipid profiles and psychological variables in patients with acute myocardial infarction. Jpn Circ J. 2001;65(2):87-93. Does not apply. [pmid: 11216831].
Young JK, Foster DA. Cardiovascular procedures in patients with mental disorders. JAMA. 2000;283(24):3198. Letter. [pmid: 10866854].
Zotti AM, Bettinardi O, Soffiantino F, et al. Psychophysiological stress testing in postinfarction patients. Psychological correlates of cardiovascular arousal and abnormal cardiac responses. Circ. 1991;83(4 Suppl):II25-35. Reports depression as a continuous variable.