# Appendix G. Evidence Tables

Evidence Table 1.1. Characteristics of Studies on Prevalence of Depression During Hospitalization For Acute Myocardial Infarction (Question 1)

Study Author, Year | Study Design | Target Population | Exclusion Criteria | Number of Study Sites | Study Site | Recruitment Period | Study Objective
Taylor, 1986 | RCT ^a^ | Only MI ^b^ patients | A^c^ > 70; F^d^; medically unable to undergo treadmill exercise testing 3 wk^e^ post-MI | Multicenter, 2 | USA | NR ^f^ | To document the psychosocial status of uncomplicated MI patients eligible for a 3 week treadmill exercise test, to determine the impact of home exercise training on psychosocial status compared to a group training program or no exercise training, and to determine the relationship among psychosocial factors and medical outcome in these patients.
Bennett, 1988 | Pro cohort ^g^ | Only MI patients | A > 75; anticipating cardiac surgery; previous MI; presence of other major physical conditions | Single center | Europe | NR | To investigate the magnitude of changes in coronary risk behavior and mood 3 months following first MI.
Davis, 1988 | Pro cohort | Only MI patients | A > 65; psychiatric Rx ^h^ | Single center | Canada | NR | To identify optimal methods of detecting depression in medically ill subjects.
Carney, 1990 | Case control | Only MI patients | A ≥ 70; serious co-morbid conditions; unable to complete interview and psychological testing; previous MI; h/o^i^ angioplasty/CABG^j^ surgery; CHF^k^; valvular heart disease; “severe” DM^l^; chronic medical illness; severe mental impairment | Single center | USA | NR | To determine whether a major degressive disorder in hospital predicts insomnia two weeks prior to MI.
Silverstone, 1990 | Pro cohort | Only MI patients | NR | NR | Europe | NR | To investigate the time course of depressive symptoms following severe medical illness and to assess the importance of somatic symptoms in particular.
Gilutz, 1991 | Pro cohort | Only MI patients | A < 34 or > 70; previous MI; DM; HTN ^m^; any other chronic disease | Multicenter, 2 | Europe; Middle East | Europe: 1979 - 1980; Middle East: 1983 - 1986 | To evaluate causal attribution patterns and whether these can predict patient rehabilitation outcome.
Schleifer, 1991 | Pro cohort | Only MI patients | Terminal noncardiac conditions; cognitively impaired; too ill to participate; non-English speaking; undergoing CABG; died prior to day 8 post-MI | Multicenter, 2 | USA | Aug 1983 – May 1985 | To evaluate the contribution of cardioactive medication on depression at follow-up controlling for baseline depression.
Forrester, 1992 | Cross-sectional | Only MI patients | A ≥ 80; too ill to be interviewed; delirium/dementia; h/o coarse brain injury; scheduled for CABG; angioplasty; residence outside of metro Baltimore | Multicenter, 3 | USA | NR | 1. To find prevalence of depression among post-MI patients.
| | | | | | | 2. To investigate predisposing factors (eg cardiac history, acute medical factors, cognitive + social factors) of depression.
Legault, 1992 | Pro cohort | Only MI patients | A < 18 or > 70; language/literacy problems; medical status precluding psychiatric assessment; previous admission to CCU ^n^ | Single center | Canada | Dec 1986 – Jan 1988 | To assess prevalence of psychiatric morbidity during hospitalization and follow up. To evaluate associations between psychiatric morbidity with cardiac diagnosis and morbidity.
Kaufmann, 1999 | Pro cohort | Only MI patients | Another medical condition likely to influence 1-yr ^o^ survival; insufficient English; cognitive problems interfering with interview; clinically unable to complete interview | Single center | USA | Jan 1995 – Dec 1995 | To examine the independent impact of major depression and hostility on mortality rate a 6 and 12 months after discharge from hospital in patients with a myocardial infarction.
O'Rourke, 1999 | Pro cohort | Only MI patients | A ≥ 76; non-English speaking; recurrent MI; emergency angioplasty; emergency cardiac bypass | Multicenter, 2 | Europe | NR | To examine predictive power of psychosocial variables (self-efficacy beliefs, locus of control, illness perception, social support, anxiety, depression) on health service utilization 6 months following MI.
Mayou, 2000 | Pro cohort | Only MI patients | A ≥ 80; no other criteria specified; event occurred within 28 d ^p^ of preceding event | Multicenter | Europe | Nov 1994 – Nov 1995 | To investigate the significance of emotional distress immediately after a myocardial infarction as a predictor of physical, psychological, and social outcome and resource use.
Brink, 2002 | Pro cohort | Only MI patients | Serious co-morbid conditions; dementia; non-Swedish; recurrent MI | Single center | Europe | Oct 1998 – Sep 1999 | To explore health related quality of life in first time myocardial infarction patients, five months after the heart attack.
Lane,.2002 | Pro cohort | Only MI patients | MI resulted from CABG/angioplasty; co-morbidity likely to cause death within 12 mos; non-English speaking; cognitively impaired; medically unable to complete assessment within 15 d post-MI | Multicenter, 2 | Europe | Jun 1997 – Aug 1998 | To examine the relationship between symptoms of depression following MI & 3 year survival status.
Lesperance, 2002 | Pro cohort | Only MI patients | Other life-threatening conditions; non-French/non-English speaking; cognitively impaired/physically unstable to complete interview; lived too far from hospital for f/u ^q^ | Multicenter | Canada | Jan 1991 – Nov 1994 | To evaluate a dose relationship between depression symptoms and long term cardiac mortality, confirm that any impact of depression symptoms remain significant after control for measures of cardiac disease severity, compare the impact of depression measurement during hospitalization and a 1 year and evaluate the prognostic importance of changes in depressive symptoms over the first post MI year.
Luutonen, 2002 | Pro cohort | Only MI patients | A > 75 | Multicenter, 2 | Europe | Mar 1998 – Aug 1998 | To investigate the prevalence of depressive symptoms and the self reported psychiatric treatment after MI.
Watkins, 2002 | Cross-sectional | Only MI patients | Not in sinus rhythm; cross spectral analysis of SBP^r^ power and RR ^s^interval; showed no patients of coherence of 0.5 or greater; unable to complete interview due to severe physical disability or altered mental status | Single center | USA | NR | To evaluate whether depression is associated with impaired baro reflex sensitivity in patients with AMI ^t^.
Barefoot, 2003 | Pro cohort | Only MI patients | Index ACS ^u^ developed after CABG/PTCA ^v^; cognitively impaired; likely to die in 1 yr; limited physical capacity; participation in conflicting research protocol | Multicenter, 8 | USA | Jun 1996 – Aug 1996 | To assess the relations between social support and depression in post MI patients at the time of hospitalization and 2 weeks afterwards.
Berkman, 2003 | RCT | Only MI patients | Index ACS after surgery; h/o of active substance abuse; h/o psychosis; h/o suicide risk; severe dementia; non cardiac condition likely to be fatal within 1y; too ill/ refused to participate; participating in other research protocol; inaccessible for intervention/f/u; receiving psychotherapy; before Apr 1998 patients on antidepressant after Apr 1998 patients on antidepressant but who remained depressed were included | Multicenter, 8 | USA, | Oct 1996 - Oct 1999 | To determine whether mortality and recurrent infarction are reduced by treatment of depression and LPSS ^w^ with cognitive behavior therapy supplemented with an SSRI ^x^ when indicated in patients enrolled with 28 days after MI.
Lauzon, 2003 | Pro cohort | Only MI patients | Non-English/non-French speaking; physically incapable of responding to a questionaire; unable to give informed consent | Multicenter, 10 | Canada | Dec 1996 – Nov 1998 | To measure the prevalence and prognostic impact of depressive symptoms after acute myocardial infarction.
Martin, 2003 | Pro cohort | Only MI patients | Medically unsuitable for cardiac rehab ^y^; died before/shortly after starting rehab program; refused cardiac rehab | Multicenter, 3 | Europe | NR | To determine the factor structure of the HADS ^z^ in a clinical population following MI and to establish change-sensitivity characteristics and psychometric reliability of the HADS in this patient group.
Rafanelli, 2003 | Pro cohort | Only MI patients | Not referred to cardiac rehab program | Single center | Europe | NR | To study the prevalence of psychological distress in the setting of cardiac rehabilitation.
Steeds, 2004 | Pro cohort | Only MI patients | A > 75; incapable of providing informed written consent; other ACS except MI | Single center | Europe | 1999 - 2000 | To determine the prevalence of an elevated BDI ^aa^ and to determine the relation between BDI score and prognosis in UK ^ab^ population following MI.

a Randomized controlled trial

b Myocardial infarction

c Age

d Female

e Week

f Not reported

g Prospective cohort study

h Treatment

i History of

j Coronary artery bypass graft

k Congestive heart failure

l Diabetes mellitus

m Hypertension

n Coronary care unit

o Year

p Day

q Follow-up

r Systolic blood pressure

s Respiratory rate

t Acute myocardial infarction

u Acute coronary syndrome

v Percutaneous transluminal coronary angioplasty

w Low perceived social support

x Selective serotonin reuptake inhibitor

y Rehabilitation

z Hospital Anxiety and Depression Scale

aa Beck Depression Inventory

ab United Kingdom

Evidence Table 1.2. Characteristics of Patients in the Studies on Prevalence of Depression During Hospitalization for Acute Myocardial Infarction (Question 1)

Study Author, Year | No. of Subjects | Mean Age | Male (%) | White (%) | Married(%) | HTN ^a^(%) | DM ^b^(%) | Smoking (%) | Lipid ^c^(%) | Killip Class (I–IV) (%) | Mean Ejection Fraction
Taylor, 1986 | 173 | 52 | 100 | NR | 86 | NR ^d^ | NR | NR | NR | NR | NR
Bennett, 1998 | 37 | 62 | 73 | NR | NR | NR | NR | NR | NR | NR | NR
Davis, 1988 | 52 | 51 | 90 | NR | 48 | NR | NR | NR | NR | NR | NR
Carney, 1990 | 70 | 53 | 76 | NR | NR | 43 | 16 | 48 | NR | NR | NR
Silverstone, 1990 | 100 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Gilutz; 1991 | Europe: 98; Middle East: 87 | NR ^e^ | NR | NR | Europe: 85; Middle East: 96 | NR | NR | Europe: 32; Middle East: 35 | NR | NR | NR
Schleifer, 1991 | 335 | 63 | 64 | NR | NR | NR | NR | NR | NR | NR | 42
Forrester, 1992 | 129 | 59 | 74 | 62 | 55 | NR | NR | NR | NR | NR | 40
Legault, 1992 | 52 | 55 | 78 | NR | NR | NR | NR | NR | NR | NR | NR
Kaufmann, 1999 | 331 | NR ^f^ | 66 | NR | 70 | 49 | 27 | 28 | 38 | Class I: 44; Class II: 48; Class III: 8; Class IV: 1 | 45
O'Rourke, 1999 | 70 | 58 | 74 | NR | 73 | NR | NR | NR | NR | NR | NR
Mayou, 2000 | 344 | 63 | 73 | NR | NR | NR | 34 | 58 | NR | NR | 46
Brink, 2002 | 114 | 68 | 68 | NR | 72 | 35 | 15 | 31 | NR | NR | NR
Lane, 2002 | 288 | 63 | 75 | 93 | 70 | 39 | 13 | 43 | 72 | Class II – IV: 51 | NR
Lesperance, 2002 | 896 | 59 | 68 | NR | 72 | 35 | 16 | 47 | NR | Class II – IV: 31 | EF ^g^ 35%: 19%
Luutonen, 2002 | 85 | 61 | 77 | NR | NR | NR | NR | NR | NR | NR | NR
Watkins, 2002 | 204 | 59 | 58 | 65 | NR | NR | NonDep ^h^ 31, Dep ^i^ 49 | NonDep 53, Dep 81 | NR | NR | NonDep 46, Dep 48
Barefoot, 2003 | 196 | 61 | 63 | 67 | NR | NR | NR | NR | NR | NR | NR
Berkman, 2003, | 9279 ^j^ | 63 | 62 | 26 | 52 | 60 | 33 | 64 | 57 | Class III – IV: 7 | NR
Lauzon, 2003 | 550 | 60 | 80 | 96 | 70 | 35 | 16 | 40 | 38 | Class II – IV: 18 | NR
Martin, 2003 | 335 | 67 | 67 | NR | NR | NR | NR | NR | NR | NR | NR
Rafanelli, 2003 | 61 | 61 | 85 | NR | NR | NR | NR | NR | NR | NR | NR
Steeds, 2004 | 131 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

a Hypertension

b Diabetes

c Hyperlipidemia

d Not reported

e In the European population 21% were less than 45 years old, 54% were 46 – 55 years old and 25% were 56 – 60 years old. In the Middle Eastern population 30% were less than 45 years old, 46% were 46 – 55 years old and 24% were 56 – 60 years old

f 45% were less than 65 years old and 56% were greater than 65 years old

g Ejection Fraction

h Non depressed

i Depressed

j Medically eligible and screened for depression

Evidence Table 1.3. Assessment of Study Quality in Studies on the Prevalence of Depression During Hospitalization for Acute Myocardial Infarction (Question 1)

Study Author, Year | Representativeness | Description Therapy & Management | Description Assessment Protocol | Outcomes & Follow-Up | Statistical Analyses | Conflicts
Taylor, 1986 | 50% | 0% | 100% | 100% | 50% | 50%
Bennett, 1988 | 10% | 0% | 100% | 50% | 0% | 0%
Davis, 1988 | 30% | 0% | 100% | 67% | 42% | 0%
Carney, 1990 | 45% | 0% | 88% | N/A | 33% | 75%
Silverstone, 1990 | 10% | 0% | 100% | 75% | 33% | 0%
Gilutz, 1991 | 45% | 0% | 75% | N/A | 0% | 0%
Schleifer, 1991 | 80% | 0% | 100% | 67% | 29% | 50%
Forrester, 1992 | 70% | 0% | 88% | N/A | 33% | 50%
Legault, 1992 | 80% | 0% | 100% | 50% | 75% | 75%
Kaufmann, 1999 | 90% | 0% | 100% | 75% | 38% | 0%
O'Rourke, 1999 | 50% | 0% | 100% | 50% | 19% | 0%
Mayou, 2000 | 65% | 0% | 100% | 67% | 19% | 75%
Brink, 2002 | 65% | 0% | 100% | 63% | 50% | 50%
Lane, 2002 | 50% | N/A | 100% | 0% | 50% | 0%
Lesperance, 2002 | 85% | 0% | 100% | 79% | 50% | 100%
Luutonen, 2002 | 80% | N/A | N/A | 83% | 50% | 0%
Watkins, 2002 | 30% | 0% | 50% | N/A | 42% | 75%
Barefoot, 2003 | 45% | 0% | 100% | 50% | 25% | 100%
Berkman, 2003 | 90% | 0% | 100% | 92% | 94% | 100%
Lauzon, 2003 | 65% | 0% | 100% | 71% | 25% | 50%
Martin, 2003 | 60% | 0% | 100% | 50% | 33% | 0%
Rafanelli, 2003 | 50% | 0% | 100% | 0% | 50% | 50%
Steeds, 2004 | 30% | 0% | 100% | 50% | 50% | 0%

Representativeness: Percentage score was based on a total maximum score of 10 points. This included assessment of how well the study described the study setting and population (2 points), inclusion/exclusion criteria (2 points), non-participating patients (2 points), patient characteristics at enrollment (2 patients), and whether the study used a consecutive series or randomly selected sample (2 patients).

Description of Therapy: Percentage score was based on a total maximum score of 6 points. This included assessment of how well the study described details of the cardiac therapy given (2 points), whether the study described details of the psychiatric treatment given (2 points), and whether there was adequate description of other treatments given (2 points).

Description of Assessment: Percentage score was based on a total maximum score of 4 points. This included assessment of the description of methods used for initial diagnosis of depression (2 points), and the description of the interpretation criteria for a diagnosis of depression (2 points).

Outcomes and Follow-up: Percentage score was based on a total maximum score of 6 points. This included assessment of whether the study reported numbers or reasons for withdrawals or those lost to follow-up (2 points), the percentage of patients withdrawn or lost to follow-up (2 points), and whether the same tools for diagnosing depression were used for baseline and follow-up (2 points).

Statistical Analyses: Percentage score was based on a total maximum score of 8 points. This included assessment of whether statistical tests were clearly identified (2 points), whether loss to follow-up was handled appropriately (2 points), whether adjustment was made for confounding (2 points), and whether confidence intervals were reported (2 patients).

Conflict of Interest: Percentage score was based on a total maximum score of 2 points. This involved determination of whether the study identified the sources of funding and involvement of the funding agency

Evidence Table 1.4. Results of Prevalence of Depression During Hospitalization for Acute Myocardial Infarction (Question 1)

Study Author, Year | Diagnosis of MI ^a^ | Diagnosis of Depression | Depression Assessment Method ^b^ | Criteria | Prevalence (%) | Depression Severity Measure^c^ | Comments
Taylor, 1986 | NR ^d^ | Modified baseline assessment | HAMD ^e^ | HAMD ≥ 10 | 3 wk ^f^ post-MI 13 | Dichotomous variable | NA ^g^
Bennett, 1988 | NR | Standard baseline assessment | HADS ^h^ | HADS ≥ 11 | In hospital ^i^ 13 | Dichotomous variable | NA
Davis, 1988 | NR | Standard baseline assessment | BDI ^j^ | BDI ≥ 13 | In hospital 10 | Dichotomous variable | NA
Carney, 1990 | Chest pain compatible with ischemia,ECG ^k^,Creatine kinase (MB ^l^ fraction) | Modified baseline assessment | DIS ^m^ | DSM-III ^n^ criteria for Major Depressive Episode | In hospital 23 | Dichotomous variable | DIS was administered by two trained lay interviewers. Two senior clinicans independently reviewed interview results using DSM-III-R criteria with 100% agreement between both clinicians.
Silverstone, 1990 | NR | Standard baseline assessment | Montgomery-Asberg | M-A ^o^ ≥ 21 | In hospital 19 | Dichotomous variable | Study included for acute medical illnesses. Data during hospitalization reported separately for MI.
Gilutz, 1991 | NR | Standard baseline assessment | Holland Sgroi Anxiety Depression Scale | Mild, Moderate/Severe Depression | In hospital 31, 10–15 d ^p^ post-MI 35 | Categorical variable | Specific cutoffs not provided for depression and no data on depression measure reported.
Schleifer, 1991 | Compatible history, cardiac enzyme elevation, Q waves, or 24 hrs^q^ ST-T wave abnormalities | Modified baseline assessment | Nurse Interview | RDC ^r^ criteria for major, minor depression | 8–10 d ^i^ Maj dep 17; Min dep 30 | Categorical variable | Major depression was assessed as (lowered mood AND 4 symptoms) ≥ 1 week. Minor depression was assessed as (lowered mood AND 2 symptoms) ≥ 1 week.No mention of DSM criteria.
Forrester,1992 | Creatine kinase | Modified baseline assessment: | PSE ^s^ | DSM - III criterion for Major Depression | In hospital: within 10 d post-MI 19 | Dichotomous variable | NA
Legault, 1992 | “Conventional clinical criteria” confirmed by ECG and elevation of MB-Ck ^t^ | Standard baseline assessment | BDI | BDI ≥ 16 | In hospital ^i^ 18 | Dichotomous variable | Authors reported demographics for MI unstable angina, and non cardiac chest pain. Data reported seperately for MI.
Kaufmann, 1999 | In hospital assessment: chest pain, ECG, Ck | Standard baseline assessment | DIS | DIS score ≥ 5 | In hospital: 3–15 d post-MI 27 | Dichotomous variable | NA
O'Rourke, 1999 | WHO ^u^ criteria | Standard baseline assessment | HADS | HADS ≥ 8 | 3 – 5 d post-MI 17 | Dichotomous variable | NA
Mayou, 2000 | In hospital assessment: ECG, other cardiac enzymes | Standard baseline assessment | HADS | HADS ≥ 8, HADS ≥ 11 | In hospital 18, within 3 d post-MI 8 | Categorical variable | NA
Brink, 2002 | NR | Standard baseline assessment | HADS | HADS ≥ 8, HADS ≥ 11 | In hospital 11, within 1 wk post-MI 8 | Categorical variable | NA
Lane, 2002 | In hospital assessment: chest pain, ECG, Ck | Standardbaseline assessment | BDI | BDI ≥ 10 | In hospital: within 15 d post-MI ^i^ 31 | Dichotomous variable | NA
Lesperance, 2002 | Symptom enzyme and ECG criteria | Standard baseline assessment | BDI | BDI ≥ 10 | In hospital ^i^ 32 | Dichotomous variable | NA
Luutonen, 2002 | In hospital assessment: chest pain, ECG, Ck | Standard baseline assessment | BDI | BDI ≥ 10 | In hospital ^i^ 21 | Dichotomous variable | NA
Watkins, 2002 | In hospital assessment: cardiac enzymes, ECG | Modified baseline assessment, | DIS | DSM - IV criteria for Major Depression | In hospital: 3 – 9 d post-MI 18 | Dichotomous variable | NA
Barefoot, 2003 | Characteristic enzymes, MI compatible symptoms | Standard baseline assessment | HAMD, BDI | “Signs of Depression”, BDI ≥ 10 | Within 2 wk post-MI ^i^ 28, 37 | Categorical, dichotomous variable | NA
Berkman, 2003 | Characteristic enzymes, MI compatible symptoms | Modified baseline assessment | Structured Interview for DSM-IV | DSM - IV criteria for Major Depression | 2–4 wk post-MI 27 | Dichotomous variable | The study is an RCT ^v^ with treatment given for 6 or more months - CBT ^w^ ± sertraline.
Lauzon, 2003 | In hospital assessment: ECG | Standard baseline assessment | BDI | BDI ≥ 10 | Within 2 – 3 d of hospitalization ^i^ 35 | Dichotomous variable | NA
Martin, 2003 | In hospital assessment: ECG, Troponin, ST wave elevation, patient history | Standard baseline assessment | HADS | HADS ≥ 8, HADS ≥ 11 | In hospital 15, within 1 wk post-MI ^i^ 6 | Categorical variable | NA
Rafanelli, 2003 | In hospital assessment: chest pain, shortness of breath, ECG, Ck | Modified baseline assessment | SCID ^x^ | DSM-IV criterion for Major, Minor Depression | Within 1 mo ^y^ post-MI 2, 10 | Dichotomous variable | NA
Steeds, 2004 | NR | Standard baseline assessment | BDI-II | BDI-II ≥ 12 | In hospital 47 | Dichotomous variable | NA

a Myocardial infarction

b Method of assessing of depression used for analysis

c How severity of depression was measured

d Not reported

e Hamilton Rating Scale for Depression

f Week

g Not applicable

h Hospital Anxiety and Depression Scale

i Also assessed at later point. See Table 2

j Beck Depression Inventory

k Electrocardiogram

l Muscle brain

m Diagnostic Interview Schedule

n Diagnostic & Statistical Manual of Mental Disorders

o Montgomery-Asberg

p Day

q Hours

r Research Diagnostic Criteria

s Psychological Stress Evaluator

t Creatine kinase

u World Health Organization

v Randomized controlled trial

w Cognitive behavioral therapy

x Structured Clinical Interview for Diagnostic & Statistical Manual of Mental Disorders - IV

y Month

Evidence Table 2.1. Characteristics of Studies on Prevalence of Depression After Hospitalization For Acute Myocardial Infarction (Question 2)

Study Author, Year | Study Design | Exclusion Criteria | Number of Study Sites | Study Site | Recruitment Period | Study Objective
Trelawny, 1987 | Sample of suspected MI ^a^ patients 28 of 32 confirmed | A ^b^ > 65; F ^c^; unmarried | NR ^d^ | Europe | NR | To describe responses of patients following admission for possible MI and study relationships of 4 aspects of outcome- work, exercise, leisure, and sexual activity.
Davis, 1988 | Retro cohort ^e^ | A > 65; receiving psychiatric Rx ^f^ | NR | Canada | NR | To identify optimal methods of detecting depression in medically ill subjects.
Follick, 1988 | RCT ^g^ of transtelephonic system | A > 70 | Multicenter, 2 | USA | NR | To examine the effects of an outpatient risk- management system on psychological, work and social functional status among post-MI patients.
Schleifer, 1991 | Retro cohort | Terminal noncardiac illness; undergoing CABG ^h^; died prior to day 8 post-MI; discharged; transferred to another facility; too ill to participate in interview; cognitively impaired; non-English speaking | Multicenter, 2 | USA | Aug 1983 - May 1985 | To evaluate the contribution of cardio active medications to depression in patients recovering from an MI.
Legault, 1992 | Pro cohort | A < 18 or > 70; literacy problems; medical status precluding psychiatric assessment | Single center | Canada | Dec 1986 - Jan 1988 | To assess prevalence of psychiatric morbidity during hospitalization and follow up.
| | | | | | To evaluate association between psychiatric morbidity with cardiac diagnosis and morbidity.
Garcia, 1994 | Cross-sectional | A > 65; F; illiteracy; concomitant diseases; previous MI | Single center | Europe | NR | To determine influence of coping strategies, personality variables and emotional states in early phase of MI and later psychopathology displayed by patients.
Travella, 1994 | Pro cohort | Anticipating cardiac surgery; serious comorbidity; cognitively impaired; treated depression; brain injury | Multicenter, 3 | USA | NR | To examine the course and clinical correlates of depression during the first year after MI.
Clarke, 1996 | Pro cohort | A > 70; F; CABG pending; previous MI; unmarried/not living in stable relationship | Multicenter, 4 | Canada | NR | To test the hypothesis that over-protectiveness of patients after MI by the spouse has a negative effect on recovery.
Lesperance, 1996 | Pro cohort | MI after surgery; non-English/non-French speaking; comorbidity likely to influence survival; not medically stable | Single center | Canada | Aug 1991 - July 1992 | To study how common major depression is prior to MI; are there medical and psychological correlates to history of major depression and does this influence a patient's medical and psychological evolution during the year after MI.
Bennett, 1998 | Pro cohort | A > 75; anticipating cardiac surgery; non-atherosclerotic MI; previous MI; other physical conditions | Single center | Europe | NR | To investigate the magnitude of changes in coronary risk behavior and mood 3 months following first MI.
Lehto, 2000 | Retro cohort | A > 70; DEPS ^i^ score not available; outside catchment area | Single center | Europe | NR | To study the prevalence of depression at least 6 months after various coronary heart disease events and the associations between depression and clinical variables.
Strik, 2001 | Pro cohort | Recurrent MI; unable to fill out questionnaires | NR | Europe | May 1997 - Sep 1999 | To assess sensitivity and specificity of 3 self-report questionnaires and one observer rating scale as screening instruments for depression following first MI.
Lane, 2002 | Pro cohort | Serious comorbidity; cognitively impaired; non-English speaking; MI from CABG/angiography; medically unstable within 15 d ^j^ post-MI; other conditions that would lead to death within 12 mo^k^ | Multicenter, 2 | Europe | Jan 1997 - Aug 1998 | To assess prevalence of depression and anxiety in post-MI patients during hospitalization and follow-up and to assess association of post-MI depression and anxiety with mortality and quality of life at 12 month follow-up.
Luutonen, 2002 | Pro cohort | NR | NR | Europe | Mar 1998 - Aug 1998 | To investigate the prevalence of depressive symptoms and self-reported psychiatric treatment after MI.
Shiotani, 2002 | Pro cohort | Died in hospital; unable to verbally communicate; major psychiatric disease; refused registry | Multicenter, 25 | Asia | Apr 1998 - Apr 2000 | To investigate the impact of the depressive symptoms on prognosis of elderly patients with acute MI.
Strik, 2002 | Retro cohort | Data not available for serum lipid at 1 mo; AMI ^l^ diagnosis not explicit | NR | Europe | May 1997 - Sep 1999 | To study relation of levels of serum lipoproteins to depression after acute MI.
Aben, 2003 | Pro cohort | Psychotic symptoms; cognitive impairment; depressive episode week before MI; major psychiatric disorder; intracerebral disease | Single center | Europe | NR | To compare the cumulative 1 year incidence of depression after stroke and after MI taking into consideration differences in age, sex, and the level of handicap.
Barefoot, 2003 | NR | Index ACS^m^ after surgery/PTCA^n^; cognitively impaired; h/o post-procedure MI; likely to die in 1 yr^o^; limited physical capacity; participating in conflicting research protocol | Multicenter, 8 | USA, | Jun 1996 - Aug 1996 | To assess the relations between social support and depression in post MI patients at the time of hospitalization and 2 weeks afterwards.
Lauzon, 2003 | Pro cohort | Transfer from other hospital; incapable of responding to questionnaire; unable to give consent | NR | Canada | Dec 1996 - Nov 1998 | To measure the prevalence and prognostic impact of depressive symptoms after acute MI.
Martin, 2003 | Cross-sectional | Medically unsuitable for cardiac rehab; died before/shortly after starting program | Multicenter, 3 | Europe | NR | To determine the factor structure of the HADS ^p^ in a population following MI and to establish change-sensitivity characteristics and psychometric reliability of the HADS in this patient group.
Strik, 2003 | Pro cohort | F; h/o ^q^ psychosis; cognitively impaired; non-Dutch speaking; comorbid life-threatening condition; h/o MI | Single center | Europe, | May 1994 -Sep 1999 | To examine whether depression is a better predictor of incomplete recovery after MI than anxiety, and to examine the effect of emotional distress not only on major cardiac events but also on re-hospitalization and health care consumption.
Lesperance, 2004 | Pro cohort | Life expectancy < 2 yr due to medical illness; cognitively impaired; non-English/non-French speaking; ACS due to medical illness | Multicenter, 2 | Canada | Aug 1999 - Aug 2001 | To determine whether or not depression is associated with higher levels of inflammatory markers in patients recovering from ACS.

a Myocardial infarction

b Age

c Female

d Not reported

e Retrospective cohort study

f Treatment

g Randomized controlled trial

h Coronary artery bypass graft

i Depression

j Day

k Month

l Acute myocardial infarction

m Acute coronary syndrome

n Percutaneous transluminal coronary angioplasty

o Year

p Hospital Anxiety and Depression Scale

q History of

Evidence Table 2.2. Characteristics of Patients in the Studies on Prevalence of Depression After Hospitalization for Acute Myocardial Infarction (Question 2)

Study Author, Year | No. of Subjects | Mean Age | Male (%) | White (%) | Married (%) | HTN ^a^ (%) | DM ^b^ (%) | Smoking (%) | Lipid ^c^ (%) | Killip Class (I–IV) (%) | Mean Ejection Fraction (%)
Trelawny, 1987 | 32 | NR ^d^ | 100 | NR | 100 | NR | NR | 71 | NR | NR | NR
Follick, 1988 | 238 | 55 | 72 | NR | NR | NR | NR | 53 | NR | NR | NR
Davis, 1988 | 52 | 51 | 90 | NR | 48 | NR | NR | NR | NR | NR | NR
Schleifer, 1991 | 335 | 64 | 64 | NR | NR | NR | NR | NR | NR | NR | 42
Legault, 1992 | 52 ^e^ | 55 | 78 | NR | NR | NR | NR | NR | NR | NR | NR
Garcia, 1994 | 97 ^f^ | 50 | 100 | NR | 69 | NR | NR | NR | NR | NR | NR
Travella, 1994 | 70 ^g^ | 58 | 74 | NR | NR | NR | NR | NR | NR | NR | NR
Lesperance, 1996 | 222 | 60 | 78 | NR | NR | NR | NR | NR | NR | Class I – IV: depressed: 20, non depressed: 19 | 44
Clarke, 1996 | 52 | NR | 100 | NR | NR | NR | NR | NR | NR | NR | NR
Lehto, 2000 | 101 | 62 | 69 | NR | NR | 28 | 15 | 12 | 63 | NR | NR
Luutonen, 2002 | 85 | 61 | 77 | NR | NR | NR | NR | NR | NR | NR | NR
Shiotani, 2002 | 1042 | 64 | 80 | NR | NR | 48 | 32 | 66 | 37 | Class II–IV: 12.5 | NR
Strik, 2002 | 140 | 58 | 76 | NR | NR | NR | NR | NR | NR | NR | 53
Aben, 2003 | 200 | 60 | 77 | NR | NR | NR | NR | NR | NR | NR | NR
Martin, 2003 | 335 | 67 | 67 | NR | NR | NR | NR | NR | NR | NR | NR
Barefoot, 2003 | 196 | 61 | 63 | 67 | NR | NR | NR | NR | NR | NR | NR
Strik, 2003 | 318 | 52 | 1 | NR | NR | 28 | NR | 54 | 20 | NR | NR
Strik, 2004 | 206 | 59 | 76 | NR | NR | NR | NR | 13 | 30 | NR | NR
Lane, 2002 | 288 ^h^ | 63 | 75 | 93 | NR | NR | NR | NR | NR | NR | NR
Bennett, 1998 | 37 | 62 | 73 | NR | NR | NR | NR | NR | NR | NR | NR
Strik 2001 | 206 | 60 | 76 | NR | NR | NR | NR | NR | NR | NR | NR
Luutonen, 2002 | 85 | 61 | 77 | NR | NR | NR | NR | NR | NR | NR | NR
Lauzon, 2003 | 550 | 60 | 80 | 96 | 70 | 35 | 16 | 40 | 38 | Class II – IV: 18 | NR
Lesperance, 2004 | 481 | 60 | 81 | NR | NR | 66 | NR | 15 | NR | NR | NR

a Hypertension

b Diabetes

c Hyperlipidemia

d Not reported

e Patients with myocardial infarction of 92 total

f 67 were assessed at 1 month

g With variable numbers at different time points

h 199 available at 4 months; 188 at 12 month

Evidence Table 2.3. Assessment of Study Quality in Studies on Prevalence of Depression After Hospitalization for Acute Myocardial Infarction (Question 2)

Study Author, Year | Representativeness | Description Therapy & Management | Description Assessment Protocol | Outcomes & Follow-Up | Statistical Analyses | Conflict
Trelawny, 1987 | 15% | 8% | 38% | 0% | 44% | 50%
Davis, 1988 | 35% | 0% | 100% | 0% | 42% | 0%
Follick, 1988 | 25% | 50% | 50% | 0% | 17% | 50%
Schleifer, 1991 | 90% | 17% | 100% | 17% | 0% | 50%
Legault, 1992 | 90% | 25% | 100% | 0% | 75% | 75%
Garcia, 1994 | 55% | 0% | 100% | 0% | 0% | 0%
Travella, 1994 | 70% | 38% | 88% | 17% | 33% | 50%
Clarke, 1996 | 50% | 0% | 100% | 0% | 0% | 0%
Lesperance, 1996 | 60% | 17% | 88% | 8% | 25% | 0%
Bennett, 1998 | 10% | 0% | 100% | 8% | 0% | 0%
Lehto, 2000 | 45% | 0% | 88% | N/A | 0% | 0%
Strik, 2001 | 80% | 0% | 100% | N/A | 50% | 0%
Lane, 2002 | 90% | 0% | 100% | 0% | 50% | 0%
Shiotani, 2002 | 80% | N/A | N/A | 0% | 50% | 50%
Strik, 2002 | 75% | 8% | 100% | 0% | 50% | 0%
Barefoot, 2003 | 50% | 0% | 100% | 0% | 25% | 100%
Aben, 2003 | 80% | 0% | 100% | 0% | 33% | 0%
Lauzon, 2003 | 65% | 33% | 100% | 8% | 13% | 50%
Martin, 2003 | 65% | 8% | 100% | 8% | 33% | 0%
Strik, 2003 | 65% | 25% | 100% | 0% | 50% | 0%
Lesperance, 2004 | 90% | 33% | 100% | 0% | 19% | 50%

Representativeness: Percentage score was based on a total maximum score of 10 points. This included assessment of how well the study described the study setting and population (2 points), inclusion/exclusion criteria (2 points), non?participating patients (2 points), patient characteristics at enrollment (2 patients), and whether the study used a consecutive series or randomly selected sample (2 patients).

Description of Therapy: Percentage score was based on a total maximum score of 6 points. This included assessment of how well the study described details of the cardiac therapy given (2 points), whether the study described details of the psychiatric treatment given (2 points), and whether there was adequate description of other treatments given (2 points).

Description of Assessment: Percentage score was based on a total maximum score of 4 points. This included assessment of the description of methods used for initial diagnosis of depression (2 points), and the description of the interpretation criteria for a diagnosis of depression (2 points).

Outcomes and Follow?up: Percentage score was based on a total maximum score of 6 points. This included assessment of whether the study reported numbers or reasons for withdrawals or those lost to follow?up (2 points), the percentage of patients withdrawn or lost to follow?up (2 points), and whether the same tools for diagnosing depression were used for baseline and follow?up (2 points).

Statistical Analyses: Percentage score was based on a total maximum score of 8 points. This included assessment of whether statistical tests were clearly identified (2 points), whether loss to follow?up was handled appropriately (2 points), whether adjustment was made for confounding (2 points), and whether confidence intervals were reported (2 patients).

Conflict of Interest: Percentage score was based on a total maximum score of 2 points. This involved determination of whether the study identified the sources of funding and involvement of the funding agency.

Evidence Table 2.4. Results of Studies on Prevalence of Depression After Hospitalization for Myocardial Infarction (Question 2)

Study | Diagnosis of MI | Depression Assessment Method^a^ | Criteria | Depression Severity Measure^b^ | Prevalence (%) | Commments
Trelawny, 1987 | Confirmed by cardiologist | Goldberg's clinical interview schedule | Depression not specified | NR ^c^ | 10 d ^d^ 20; 2 mos ^e^ 26; 6 mos 26 | Group consisted of married men admitted to an ER ^f^ with suspected MI ^g^ ≥ 65 years.
Davis, 1988 | MI patients admitted to CCU ^h^ | BDI ^i^ | ≥ 13 | Categorical variable | 6–8 wks ^j^ 10 | Prevalence of depression measured by 3 methods
| | | | | | 17 BDI rating 27 SCID ^k^ rating
Follick, 1988 | In?hospital assessment, chest pain, ECG ^l^, creatine kinase | SCL-90 ^m^ | No standard definition of depression | Dichotomous variable | Baseline 16; 9 mos 10 | NA ^n^
Schleifer, 1991 | In-hospital assessment, chest pain, creatine kinase, ECG | RDC ^o^ (Nurse Interview) | Major/Minor depression | Categorical variable | 8–10 d: Major ^p^ 17, Minor ^q^ 30; | Major depression assessed as (lowered mood and 4 symptoms) ≥ 1 week.
| | | | | 3–4 mos: Major 14, Minor= 19 | Minor depression assessed as (lowered mood and 2 symptoms) ≥ 1 week.
Legault, 1992 | In-hospital assessment, ECG, creatine kinase. | BDI | ≥ 16 | Dichotomous variable | 3 mos 7; 12 mos 9 | Authors reported demographics for MI, unstable angina, and non cardiac chest pain.
| | | | | | Only the data on MI patient captured. Follow up at 3 months and 12 months, with initial.
Garcia, 1994 | In-hospital assessment | RDC | Major/Minor depression | Continous variable, Categorical variable | 1 mo: Major 11, Minor 27 | All patients with first MI assessed for depression - no control.
| | | | | | Data reported at hospitalization for MI (diagnosis standard not provided) included only means & CIs ^r^ for personality type A, and mood measures(including BDI).
Travella, 1994 | ECG, CPK ^s^ | HAMD ^t^PSE ^u^ | Major/Minor dysthymia | Categorical variable | In hospital: MDD ^v^ 26, Dys ^w^ 3; | NA
| | | | | 3 mos: MDD 15, Dys 4;
| | | | | 6 mos: MDD 21, Dys 3;
| | | | | 9 mos: MDD 28, Dys 3;
| | | | | 12 mos MDD 16, Dys 13
Clarke, 1996 | In-hospital assessment | ZDS ^x^ | NR | Dichotomous variable | 3 mos 24 | NA
Lesperance, 1996 | In-hospital assessment, chest pain, creatine kinase, new Q waves | DIS ^y^ | Depression | NR | 6 mos 21; 12 mos 9 | NA
Bennett, 1998 | In-hospital assessment | HADS ^z^ | ≥11 | Dichotomous variable | 3 mos 3 | NA
Lehto, 2000 | Interviews and clinical examinations at least 6 months after the cardiac events, physician report | DEPS ^aa^ | ≥ 9 | Continuous variable, Dichotomous variable | At least 6 mos post-MI ^d^ 16 | NA
Strik, 2001 | In-hospital assessment, ECG, AST, clinical picture | SCID, HAMD, SCL-90, BDI, HADS | Major/Minor depression | Dichotomous variable | 1 mo Major 11, Minor 8 | NA
Lane, 2002 | In-hospital assessment, chest pain, ECG, creatine kinase | BDI | ≥ 10 | Continuous variable, Dichotomous variable | 4 mos 38; 12 mos 37 | NA
Luutonen, 2002 | In-hospital assessment, chest pain, ECG, creatine kinase | BDI | ≥ 10 | Continuous variable, Categorical variable | 6 mos 30; 18 mos 34 | NA
Shiotani, 2002 | In-hospital assessment, chest pain, ECG, creatine kinase, | ZDS | ≥ 40% | Dichotomous variable | Within first 3 mos 42 | Depression not assessed during hospitalization. SDS ^ab^ mailed within 3 months.
Strik, 2002 | In-hospital assessment, chest pain, ECG, AST | BDI, HADS, SCL-90 if any one positive assessment with SCID | Major or minor depression | Dichotomous variable | 3 mos: Major 11, Minor 2 | NA
Aben, 2003 | In-hospital assessment, chest pain, ECG, AST ^ac^ | BDI, HADS, SCL-90 if any one positive assessment with SCID and HAMD | Depression | Dichotomous variable | 1 mo 14 | The study reports incident cases of depression at 1, 3, 6, 9, and 12 months. Cumulative incidence of depression in table 2.
Barefoot, 2003 | In-hospital assessment, ECG, cardiac enzyme | NR | HAMD d/x ^ad^, BDI ≥10 | Continuous variable, categorical variable | 2 wks: HAMD 17, BDI 27 | NA
Lauzon, 2003 | In-hospital assessment, ECG | BDI | ≥ 10 | Dichotomous variable | 1 mo 39; 6 mos 39; 1 yr 30 | NA
Martin, 2003 | In-hospital assessment, ECG, troponin, patient history | HADS | ≥ 11 (probable depression) ≥ 8 (possible depression) | Continuous variable, Dichotomous variable | 1 wk: ≥ 8: 15, ≥ 11: 6; | NA
| | | | | 6 wk: ≥ 8: 13, ≥ 11: 5;
| | | | | 6 mos: ≥ 8: 10, ≥ 11: 5
Lesperance, 2004 | In-hospital assessment, chest pain, ECG,creatine kinase | SCID | Major depression | Dichotomous variable | Approx 2 mos: 7 | NA

a Method of assessing of depression used for analysis

b How severity of depression was measured

c Not reported

d Day

e Month

f Emergency room

g Myocardial infarction

h Coronary care unit

i Beck Depression Inventory

j Weeks

k Structural Clinical Interview for Diagnostic & Statistical Manual of Mental Disorders IV

l Electrocardiogram

m Symptoms Checklist 90

n Not applicable

o Research Diagnostic Criteria

p Major depression

q Minor depression

r Confidence intervals

s Creatine phosphokinase

t Hamilton Rating Scale for Depression

u Present State Examination

v Major Depressive Disorder

w Dysthymia

x Zung Depression Scale

y Diagnostic Interview Schedule

z Hospital Anxiety and Depression Scale

aa Depression Scale

ab Self?Rating Depression Scale

ac Aspartate amino transferase

ad Diagnosis

Evidence Table 3.1A. Characteristics of Studies on the Relation of Depression to Survival in Patients After Myocardial Infarction (Question 3)

Study Author, Year | Study Design | Target Population | Exclusion Criteria | Number of Study Sites | Study Site | Recruitment Period | Study Objective
Ahern, 1990 | Pro cohort ^a^ | Only MI ^b^ patients | Age > 70, index ACS ^c^ after symtoms, non-atherosclerotic MI, pulmonary hypertension, symptomatic urinary tract infection, chronic active hepatitis, nonischemic MI, women of child bearing age, < 10 PVCs/hr ^d^, non English speaking | Multicenter, 10 | USA, Canada | NR ^e^ | To test the predictive association between biobehavioral factors and mortality or cardiac arrest.
Ladwig, 1991 | Pro cohort | Only MI patients | Age > 66, female | Multicenter | Europe | Jan 1983 - Dec 1985 | To assess incidence of hyperactive behaviour and persistence and depression in the post-acute phase after MI.
Frasure-Smith, 1993 | Pro cohort | Only MI patients | Cognitively impaired, medical condition likely to impact 6 mos survival, non English or non French speaking, too unstable to complete interview | Single center | Canada | Jul 1991 - Jun 1992 | To determine if the diagnoses of major depression in patients hospitalized following MI would have an independent impact on cardiac mortality over the first 6 months after discharge.
Frasure-Smith, 1999 | Pro cohort | Only MI patients | Life threatening conditions, cognitively impaired, non French, lived too far to return to follow up, administrative reasons, physician refusal, participation in other research early discharge | Multicenter, 10 | Canada | Jul 1991 - 1994 | To assess gender differences in the impact of depression on 1 year cardiac mortality in patients hospitalized for an acute MI.
Irvine, 1999 | RCT ^g^ | Only MI patients | Age > 65,more than 1 MI, non Gottenberg residents | Multicenter | Canada | Jun 1996 - Nov 1995 | To examine the impact of depressive symptoms and social support on a 2-year sudden cardiac death risk, controlling for fatigue symptoms.
Denollet, 2000 | Pro cohort | Patients with ACS | Serious co-morbidity | Single center | Europe | Jan 1989 - Dec 1992 | To test the hypothesis that both cardiac disorder and emotional distress confer an increased risk of cardiac events and impaired QOL ^h^ despite appropriate cardiac treatment.
Lane, 2000 | Pro cohort | Only MI patients | Index ACS after symptoms:, another condition likely to lead to death within 12 mos, non English speaking, medically unstable, MI, CABG ^i^, PCI ^j^ | Multicenter | Europe | Jan 1997 - Aug 1988 | To determine the impact of depression and anxiety on mortality and quality of life in patients hospitalized for an acute MI.
Welin, 2000 | Pro cohort | Only MI patients | NR | Multicenter | Europe | Oct 1985 - Oct 1987 | To test whether the 10 year prognosis after MI is related to psychological stress, lack of social support, anxiety, and/or depressive tendency.
Bush, 2001 | Pro cohort | Only MI patients | Serious co-morbidity likely to die in 6 mos of medical condition, not admitted to the cardiology service, died or transferred, other facility within 48 hrs of hospitalization | Single center | USA | Jul 1995 - Dec 1996 | To determine whether minimal symptoms of depression that are less than those considered clinically significant are associated with increased mortality risk after MI.
Druss, 2001 | Pro cohort | Only MI patients | Age < 65, terminally ill, cognitively impaired, died during current admission, DNR ^k^ order, dementia | Multicenter | USA | Feb 1994 - Jul 1995 | To investigate whether difference in quality of medical care might explain a portion of the excess mortality associated with mental disorders in the year after MI.
Lane, 2001 | Pro cohort | Only MI patients | Index ACS after surgery, serious co-morbidities, cognitively impaired, non English, medically unstable | Multicenter | Europe | Jan 1997 - Aug 1998 | To determine the impact of symptoms of depression and anxiety on mortality and quality of life in patients hospitalized for AMI^l^.
Lane, 2002 | Pro cohort | Only MI patients | NR | Multicenter | Europe | Jun 1997 - Aug 1998 | To examine the relationship between symptoms of depression following MI & 3 year survival status.
Lesperance, 2002 | Pro cohort | Only MI patients | NR | Multicenter | Canada | Jan 1991 - Nov 1994 | To evaluate a close relationship between depression symptoms and long-term cardiac mortality, confirm that any impact of depression symptoms remain significant after control for measures of cardiac disease severity, compare the impact of depression measurement during hospitalization and a year later and evaluate the prognostic importance of changes in depressive symptoms over the first post-MI year.
Carney, 2003 | Pro cohort | Only MI patients | H/o ^m^ psychosis, cognitively impaired, life threatening medical illness, to ill to participate, TCA ^n^ or MAOI ^o^ or other anti-depressant that may affect heart rate variability, refused logistically, unable to participate | Multicenter | USA | Oct 1997 - Jan 2000 | To determine if depression was associated with an increased risk of mortality and nonfatal recurrent MI in a subsample of the ENRICHD ^p^ trials depressed patients compared with a group of non depressed patients recruited for an ancillary study.
Frasure-Smith, 2003 | Pro cohort | Only MI patients | Index ACS after surgry, cognitively impaired:, non English or non French, life threatening illness, physical inability to complete hospital interview, living to far to return to hospital for f/u ^q^, physician refusal, participation in other research | Multicenter | Canada | Jan 1991 - Sep 1994 | To examine the relative importance of depression, anxiety,anger, and social support in predicting 5-years cardiac related mortality following an MI and assess the role of any common underlying dimensions.

a Prospective cohort study

b Myocardial infarction

c Acute coronary syndrome

d Premature ventricular contractions per hour

f Not reported

g Randomized controlled trial

h Quality of life

i Coronary artery bypass graft

j Percutaneous coronary intervention

k Do not resuscitate

l Acute myocardial infarction

m History of

n Tetracyclic antidepressant

o Monoamine oxidase inhibitor

p Enhancing Recovery in Coronary Heart Disease

q Follow-up

Evidence Table 3.1B. Characteristics of Studies on the Relation of Depression to Cardiac Events in Patients After Myocardial Infarction (Question 3)

Study Author, Year | Study Design | Target Population | Exclusion Criteria | Number of Study Sites | Study Site | Recruitment Period | Study Objective
Irvine, 1999 | RCT ^a^ | Only MI ^b^ patients | non English or non French speaking, not well enough to complete questionaire | Multicenter | Canada | NR ^c^ | To examine the impact of depressive symptoms and social support on a 2-year sudden cardiac death risk, controlling for fatigue symptoms.
Druss, 2000 | Retro cohort^d^ | Only MI patients | Age < 65 yrs ^e^, terminally ill, transfer from another hospital, do not resuscitale order, not fee for service | Multicenter | USA | Feb 1994 - Jul 1994 | To assess whether having a comorbid mental disorder is associated with a lower likelihood of cardiac catheterization and/or vascularization after AMI ^f^.
Frasure-Smith, 2000 | Retro cohort | Only MI patients | Non-English or non-French speaking, life threating condition, cognitively impaired, physically unstable, live far from hospital, administrative reason | Multicenter | Canada | M-HART ^g^: 1991 - 1995EPPI ^h^: NR | To examine the relationship between post-MI depression and physician costs, including both out patient care and hospital readmissions.
Shiotani, 2002 | Pro cohort ^i^ | Only MI patients | Died in hospital, unable to verbally communicate, major psychological disease, refused registry | Multicenter | Asia | Apr 1998 - Apr 2000 | To investigate the impact of the depressive symptoms on prognosis of the elderly patients with AMI.
Strik, 2003 | Pro cohort | First MI | H/o ^j^ psychosis, cognitively impaired, non Dutch speaking | Single center | Europe | May 1994 - Sep 1999 | 1) To examine whether depression is a better predictor of incomplete recovery after MI than anxiety.
| | | | | | | 2) To examine the effect of emotional distress not only on major cardiac events but also on re-hospitalization and increased health care consumption.
Strik, 2004 | Pro cohort | First MI | H/o psychosis,cognitively impaired, cant express themselves, non Dutch speaking, lived more than 50 kms ^k^, co-morbid life threatening illness | Single center | Europe | NR | 1)To evaluate whether cumulative 1 year incidence of major and minor depression in a consecutive cohort is as high following MI in first MI patients.
| | | | | | | 2)To evaluate whether in the above patient population major and minor depressive symptoms, predicted cardiac mortality and morbidity upto 3 years post MI.

a Randomized controlled trial

b Myocardial infarction

c Not reported

d Retrospective cohort study

e Years

f Acute myocardial infarction

g Montreal Heart Attack Readjustment Trial

h Emotions and Prognosis Post-Infarct Study

i Prospective cohort study

j History of

k Kilometers

Evidence Table 3.1C. Characteristics of Studies on the Relation of Depression to Quality of Life in Patients After Myocardial Infarction (Question 3)

Study Author, Year | Study Design | Target Population | Exclusion Criteria | Number of Study Sites | Study Site | Recruitment Period | Study Objective
Travella, 1994 | Pro cohort^ a^ | Only MI^b^ patients | Attempted cardiac surgery,serious co-morbidities,cognitively impaired, h/o ^c^ depression | Multicenter | USA | NR ^d^ | To examine the course of clinical correlates of depression going the first year after MI.
Drory, 1998 | Pro cohort | Only MI patients | Females, previous AMI ^e^, not sexually active prior to MI | Multicenter | Asia | NR | To examine important diverse sociodemographic, medical and psychological variables as potential predicton of sexual activity, satisfaction in male patients following a first AMI.
O'Rourke, 1999 | Pro cohort | included patients with ACS ^f^ other than MI. | Age>76, non-English, recurrent MI, emergency angioplasty, emergency cardiac by pass | Multicenter | Europe | NR | To examine predictive power of psychosocial variables (self-efficacy beliefs, locus of control, illness perception, social support, anxiety, depression) on health service utilization 6 months following MI.
| | Data for MI not reported separately
Soejima, 1999 | Pro cohort | Only MI patients | NR | Multicenter | Asia | Apr 1992 - Jan 1996 | To investigate psychosocial and clinical factors related to work resumption, delay in returning to work and level of work activity after acute myocardial infarction in Japanese male patients.
Bogg, 2000 | Pro cohort | Only MI patients | CVA ^g^ | Single Center | Europe, | NR | To assess the influences of gender on quality of life among post MI patients with depression.
Denollet, 2000 | Pro cohort | 322 patients with ACS, 50.31% patients with MI | Serious co-morbidities | Single center | Europe, | Jan 1989 - Dec 1992 | To test the hypothesis that both cardiac disorder and emotional distress confer an increased risk of cardiac events and impaired QOL ^h^ despite appropriate cardiac treatment.
| | No data for MI reported separately
Lane, 2000 | Pro cohort | Only MI patients | Index ACS after surgery, serious co-morbidities, another medical condition likely to lead to death within the next 12 months, non-English, medically unstable, too unstable to complete the baseline assessment within 15 days of their infarction | Multicenter | Europe, | Jan 1997 - Aug 1998 | To determine the impact of depression and anxiety on mortality quality of life in patients hospitalized for an acute myocardial infarction.
Mayou, 2000 | Pro cohort | Only MI patients | Age > 80 years | Multicenter | Europe | Nov 1994 - Nov 1995 | To investigate the significance of emotional distress imediately after a myocardial infarction as a predictor of physical, psychological, and social outcome and resource use.
Lane, 2001 | Pro cohort | Only MI patients | Index ACS after surgery, serious co-morbidities, cognitively impaired, non-English, medically unstable | Multicenter | Europe, | Jan 1997 - Aug 1998 | To determine the impact of symptoms of depression and anxiety on mortality and quality of life in patients hospitalized for AMI
Brink, 2002 | Pro cohort | Only MI patients | Serious co-morbidities, dementia, non-Swedish | Single Center | Europe, | Oct 1998 - Sep 1999 | To explore health related quality of life in first time myocardial infarction patients, five months after the heart attack.
Drory, 2002 | Pro cohort | Only MI patients | Previous MI | Multicenter | Asia, | NR | To evaluate differential and independent impact of socio-demographic medical and psychologic variables assessed at hospital discharge on patients short and long term mental health.
Drory, 2003 | Pro cohort | Only MI patients | Men, previous MI | Multicenter | Asia, | NR | To compare the long term psychologic well being and psychologic distress, after a first acute myocardial infarction of women with those of men and those of a normative community sample of women and to examine the relation of socio-demographic, medical and psychologic variables to the long-term psychologic well-being and psychologic distress of women.

a Prospective cohort study

b Myocardial infarction

c History of

d Not reported

e Acute myocardial infarction

f Acute coronary syndrome

g Cardiovascular angioplasty

h Quality of life

Evidence Table 3.2A. Patient Characteristics of Studies on the Relation of Depression to Survival in Patients After Myocardial Infarction (Question 3)

Study Athor, Year | No. of Subjects | Mean Age | Male(%) | White (%) | Married ^a^(%) | Education ^b^(%) | Employed ^c^(%) | HTN ^d^(%) | DM ^e^(%) | Smoking (%) | Lipid ^f^(%) | Killip Class (I–IV) (%) | Mean Ejection Fraction | H/o ^g^ Dep (%)
Ahern, 1990 | 265 | NR ^h^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Ladwig, 1991 | 560 | NR | 100 | NR | NR | NR | NR | Group A: 109, Group B: 36, Group C: 33 | NR | Group A: 222, Group B: 79, Group C: 45 | NR | NR | EF ^i^ < 35%: 22 | NR
Frasure-Smith, 1993 | 222 | NR | 78 | NR | NR | > 8 yrs ^j^: 69 | NR | 30 | 12 | 40 | NR | 21 | 43, EF: 95% CI^k^(42.1% to 45.7%) | NR
Frasure-Smith, 1999 | Female: 283, Male: 613 | Female: 63, Male: 58 | 68 | NR | Female: 51, Male: 18 | < 7yrs: Female: 38 Male: 23 | NR | Female: 52, Male: 28 (n=612) | Female: 23, Male: 13 | Female: 45, Male: 49 | NR | Class I: Female: 57, Male: 75 | Female:71, Male: 47; EF < 35%, Female: 18, Male: 20; Mean: Female: 50, Male: 47 | NR
| | | | | | | | | | | | Class II: Female: 15, Male: 11;
| | | | | | | | | | | | Class III: Female: 25, Male: 12;
| | | | | | | | | | | | Class IV: Female: 3, Male: 2
Irvine, 1999 | 634 | 64 | 83 | NR | 74 | 14 | NR | NR | 15 | NR | NR | NR | NR | NR
Denollet, 2000 | Event Free: 270, CV^l^ Event: 22, Total Events: 49 | Event Free: 38,CV Event: 59, Total Events: 53 | Event Free: 92, CV Event: 95, Total Events: 94 | NR | NR | NR | NR | Event Free: 32, CV Event: 27, Total Events: 29 | NR | Total Events: 20 | Event Free: 36, CV Event: 36, Total Events: 37 | NR | Event Free: 16,CV Event: 36, Total Events: 33 | Event Free: 32, CV Event: 55, Total Events: 51
Lane, 2000 | BDI ^m^ > 10: 89, BDI < 10: 199 | BDI > 10: 63, BDI < 10: 63 | BDI > 10: 62, BDI < 10: 80 | BDI > 10: 91, BDI < 10: 94 | BDI > 10: 67, BDI < 10: 71 | BDI > 10: 10, BDI < 10: 10 | BDI > 10: 24, BDI < 10: 36 | BDI > 10: 42, BDI < 10: 37 | BDI > 10: 19, BDI < 10: 10 | BDI > 10: 44, BDI < 10: 43 | BDI > 10: 74, BDI < 10: 79 | Class II – IV: BDI > 10: 58, BDI < 10: 49 | NR | NR
Welin, 2000 | 275 | NR | 84 | NR | NR | NR | NR | 21 | 9 | 19 | NR | NR | NR | NR
Bush, 2001 | 271 | 64.8 | 58 | 86 | 79 | NR | NR | 66 | 35 | 29 | 62% | Class II – IV: 41 | EF > 35%: 71,EF < 35%: 29 | 18
Druss, 2001 | Mental ^n^: 4664,No Mental : 83577 | Mental: 76, No Mental : 76 | Mental : 53 No Mental : 47 | NR | NR | Mental: 6, No Mental: 0 | NR | Mental : 42, No Mental : 40 | Mental : 22, No Mental : 26 | Mental : 22, No Mental : 15 | NR | NR | EF: >55%, Mental: 14, No Mental : 15 | NR
Lane, 2001 | Group A: 89, Group B: 199 | Group A: 63, Group B: 63 | Group A: 62, Group B: 80 | Group A: 91, Group B: 94 | Group A: 91, Group B: 94 | Group A: 10, Group B: 10 | Group A: 24, Group B: 36 | Group A: 42, Group B: 37 | Group A: 19, Group B: 10 | Group A: 44, Group B: 43 | Group A: 74, Group B: 79 | Class II – IV: Group A: 58, Group B: 49 | NR | NR
Lane, 2002 | Dep ^o^: 89, NonDep ^p^: 199 | Dep: 63, NonDep: 63 | 75 | 93 | Dep: 71, NonDep: 67 | Dep: 10, NonDep: 10 | Dep: 24, NonDep: 36 | Dep: 42, NonDep: 37 | Dep: 19, NonDep: 10 | Dep: 44, NonDep: 43 | NR | Class II – IV: Dep: 55, NonDep: 49 | NR | NR
Lesperance, 2002 | 870 | 59 | 68 | NR | 36 | NR | NR | 35 | 16 | 47 | NR | Class I –IV: 31 | 19 (n=889) | NR
Carney, 2003 | Group A: 358, Group B: 408 | Group A: 57, Group B: 61 | Group A: 53, Group B: 62 | Group A: 28, Group B: 21 | NR | NR | NR | NR | Group A: 33, Group B: 22 | NR | NR | Class III: Group A: 6, Group B: 4 | EF < 40 %, Group A: 24, Group B: 22 | NR
Frasure-Smith, 2003 | 887 | 59 | 69 | NR | NR | NR | NR | NR | NR | 62 | NR | NR | NR | NR

a Married or partnered

b High School or higher education

c Employed full-time or part-time

d Hypertension

e Diabetes

f Hyperlipidemia

g History of

h Not reported

i Ejection fraction

j Years

k Confidence interval

l Cardiovascular

m Beck Depression Inventory

n Mental disorder/no mental disorder

o Depressed

p Non-depressed

Evidence Table 3.2B. Patient Characteristics of Studies on the Relation of Depression to Cardiac Events in Patients After Myocardial Infarction(Question 3)

Study Author, Year | No. of Subjects | Mean Age | Male (%) | HTN ^a^ (%) | DM ^b^ (%) | Smoking (%) | Lipid ^c^ (%) | Mean Ejection Fraction | History of Depression (%)
Irvine, 1999 | 634 | 64 | 83 | NR^d^ | 15 | NR | NR | NR | NR
Druss, 2000 | Mental^e^: 5365 | Mental: 50 | Mental: 52 | Mental: 42 | Mental: 22 | Mental:22 | NR | EF^g^ ≥ 55% | NR
| No Mental^f^: 108288 | No Mental: 49 | No Mental: 46 | No Mental: 40 | No Mental: 26 | No Mental: 151 | | Mental: 14
| | | | | | | | No Mental: 14
Frasure-Smith, 2000 | 848 | NR | 69 | 34 | 16 | 48 | NR | EF ≤ 35%: 17 | NR
Shiotani, 2002 | Dep^h^: 438 | Dep: 63 | Dep: 81 | Dep: 49 | Dep: 36 | Dep: 70 | Dep: 35 | NR | NR
| NonDep^i^: 604 | NonDep: 64 | NonDep: 80 | NonDep: 46 | NonDep: 29 | NonDep: 62 | NonDep: 39
Strik, 2003 | 318 | 58 | 100 | 28 | 9 | 54 | 20 | EF ≤ 50%: 45 | NR
Strik, 2004 | Dep: 63 | NR | Dep: 84 | NR | NR | Dep: 10 | Dep: 35 | EF < 50% | Dep: 32
| NonDep: 143 | | NonDep: 74 | | | NonDep: 13 | NonDep: 29 | Dep: 77, NonDep: 31; EF > 50% | NonDep: 13
| | | | | | | | Dep: 56, NonDep: 69

a Hypertension

b Diabetes

c Hyperlipidemia

d Not reported

e Any mental disorder

f No mental disorder

g Ejection fraction

h Depressed

i Non-depressed

Evidence Table 3.2C. Patient Characteristics of Studies on the Relation of Depression to Quality of Life in Patients After Myocardial Infarction (Question 3)

Study Author, Year | No. of Subjects | Mean Age | Male (%) | Non-White (%) | Married (%) | Education^a^ (%) | Employed^b^ (%) | HTN ^c^ (%) | DM ^d^ (%) | Smoking (%) | Lipid ^e^ (%) | Killip Class (I–IV) (%) | Mean Ejection Fraction | History of Depression (%)
Travella, 1994 | Dep ^f^: 18, NonDep ^g^: 52 | Dep: 63, NonDep: 57 | Dep: 54, NonDep: 82 | Dep: 44, NonDep: 36 | NR | Dep: 12, NonDep: 12 | NR | NR | NR | NR | NR | NR | NR | Dep: 28, NonDep: 10
Drory, 1998 | 276 | 51 | 100 | 33 rest of group from Europe/ American/ Israel | 99 | 13 | NR | NR | 9 | NR | NR | Class I: 83, Class II: 16, Class III: 1, Class IV: 1 | NR | NR
O'Rourke 1999 | EHM ^h^: 45, No EHM ^i^: 25 | EHM: 58, No EHM: 60 | EHM: 73, No EHM: 76 | NR | EHM: 73, No EHM: 72 | NR | EHM: 31, No EHM: 44 | NR | NR | NR | NR | NR | NR | NR
Soejima, 1999 | 134 | 54 | 100 | NR | NR | NR | 100 | 34 | 22.5 (14.8, 30.3) | 74.8 | 31.5 (22.9,40.2) | Class I: 847 (78.0–91.4), Class II:15.3 (8.6–22.6) | 56 | NR
Bogg, 2000 | 220 | NR | 77 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Denollet, 2000 | Free ^j^: 270, Cardiac ^k^: 22, Total ^l^: 49 | Free: 38, Cardiac: 59, Total: 53 | Free: 92, Cardiac: 95, Total: 94 | NR | NR | NR | NR | Free: 32 (85), Cardiac: 27 (6), Total: 29 (14) | NR | Free: 17 (45), Cardiac: 18 (4), Total: 20 (10) | Free: 36 (103), Cardiac: 36 (8), Total: 37 (18) | NR | Free: 16 (43), Cardiac: 36 (8), Total: 33 (16) | Free: 32 (85), Cardiac: 55 (12), Total: 51 (25)
Lane, 2000 | Dep: 89, NonDep: 199 | Dep: 63, NonDep: 63 | Dep: 62, NonDep: 80 | Dep: 9, NonDep: 7 | NR | Dep: 10, NonDep: 10 | Dep: 24, NonDep: 36 | Dep: 42, NonDep: 37 | Dep: 19, NonDep: 9 | Dep: 44, NonDep: 43 | Dep: 35, NonDep: 39 | Class I: Dep: 41, NonDep: 51, Class II: Dep: 56, NonDep: 49 | NR | NR
Mayou, 2000 | Total: 344, Distress ^m^: 51, NonDistress ^n^: 293 | Total: 63, Distress: 58, NonDistress: 64 | Total: 73 Distress: 69, NonDistress: 74 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Lane, 2001 | Dep: 89, LowDep^o^: 199 | Dep: 63, LowDep: 63 | Dep: 62, LowDep: 80 | Dep: 9, LowDep: 7 | NR | Dep: 10, LowDep: | Dep: 24, LowDep: 36 | NR | NR | NR | NR | NR | NR | NR
Brink, 2002 | Women: 37, Men: 77 | Women: 72, Men: 65 | 68 | NR | Women: 60, Men: 78 | Women: 78, Men: 71 | NR | Women: 51, Men: 28 | Women: 16, Men: 15 | Women: 24, Men: 34 | NR | NR | NR | NR
Drory, 2002 | 209 | 52 | 100 | NR | NR | 12 | NR | NR | NR | NR | NR | Class I: 81 Class II: 17 Class III: 1 Class IV: 1 | NR | NR
Drory, 2003 | 62 | 56 | 0 | 20 | NR | 12 | NR | NR | NR | NR | NR | Class II – IV: 16 | NR | NR

a High School or higher

b Employed full-time or part-time

c Hypertension

d Diabetes

e Hyperlipidemia

f Depressed

g Not depressed

h Received Edinburgh Heart Manual

i Did not received Edinburgh Heart Manual

j Event free

k Fatal and non fatal cardiac events at 5 years

l Cardiac events and revascularization at 5 years

m Distressed cases at baseline

n Not distressed cases at baseline

o Low levels of depression as indicated by Beck Depression Inventory score less than 10

Evidence Table 3.3A. Assessment of Study Quality in Studies on the Relation of Depression to Survival in Patients After Myocardial Infarction (Question 3)

Study Author, Year | Representativeness | Description of Therapy & Management | Description of Assessment Protocol | Outcomes and Follow-Up | Statistical Analyses | Conflicts
Ahern, 1990 | 75% | 25% | 100% | 69% | 63% | 50%
Ladwig, 1991 | 30% | 0% | 38% | 69% | 38% | 100%
Frasure-Smith, 1993 | 75% | 17% | 100% | 88% | 63% | 50%
Frasure-Smith, 1999 | 100% | 0% | 100% | 30% | 63% | 50%
Irvine, 1999 | 70% | 58% | 100% | 63% | 63% | 50%
Denollet, 2000 | 60% | 8% | 100% | 85% | 81% | 0%
Lane, 2000 | 95% | 8% | 100% | 88% | 88% | 0%
Welin, 2000 | 70% | 0% | 100% | 80% | 63% | 50%
Bush, 2001 | 75% | 0% | 100% | 78% | 56% | 0%
Druss, 2001 | 90% | 0% | 100% | 94% | 75% | 100%
Lane, 2001 | 95% | 25% | 100% | 42% | 69% | 0%
Lane, 2002 | 50% | N/A | 100% | 60% | 75% | 0%
Lesperance, 2002 | 95% | 42% | 100% | 90% | 75% | 100%
Carney, 2003 | 85% | 42% | 100% | 60% | 81% | 50%
Frasure-Smith, 2003 | 70% | 0% | 100% | 88% | 88% | 50%

Representativeness: Percentage score was based on a total maximum score of 10 points. This included assessment of how well the study described the study setting and population (2 points), inclusion/exclusion criteria (2 points), non participating patients (2 points), patient characteristics at enrollment (2 patients), and whether the study used a consecutive series or randomly selected sample (2 patients).

Description of Therapy: Percentage score was based on a total maximum score of 6 points. This included assessment of how well the study described details of the cardiac therapy given (2 points), whether the study described details of the psychiatric treatment given (2 points), and whether there was adequate description of other treatments given (2 points).

Description of Assessment: Percentage score was based on a total maximum score of 4 points. This included assessment of the description of methods used for initial diagnosis of depression (2 points), and the description of the interpretation criteria for a diagnosis of depression (2 points).

Outcomes and Follow up: Percentage score was based on a total maximum score of 12 points. This included assessment of whether the study reported numbers or reasons for withdrawals or those lost to follow up (2 points), the percentage of patients withdrawn or lost to follow up (2 points), whether the cardiac outcome measures were defined (2 points), whether the depression outcome measures were defined (2 points), whether the same tools for diagnosing depression were used for baseline and follow up (2 points) and the planned length of follow-up (2 points).

Statistical Analyses: Percentage score was based on a total maximum score of 8 points. This included assessment of whether statistical tests were clearly identified (2 points), whether loss to follow up was handled appropriately (2 points), whether the magnitude of the difference for primary endpoints or magnitude of association between outcomes and index variability is reported (2 points) and whether adjustment was made for confounding (2 points).

Conflict of Interest: Percentage score was based on a total maximum score of 2 points. This involved determination of whether the study identified the sources of funding and involvement of the funding agency.

Evidence Table 3.3B. Assessment of Study Quality in Studies on the Relation of Depression to Cardiac Events in Patients After Myocardial Infarction (Question 3)

Study Author, Year | Representativeness | Description of Therapy & Management | Description of Assessment Protocol | Outcomes and Follow-Up | Statistical Analyses | Conflicts
Irvine, 1999 | 70% | 58% | 100% | 63% | 63% | 63%
Druss, 2000 | 85% | 8% | 50% | 50% | 100% | 75%
Shiotani, 2002 | 80% | 17% | 100% | 92% | 75% | 83%
Strik, 2003 | 65% | 25% | 100% | 56% | 106% | 81%
Strik, 2004 | 75% | 8% | 100% | 83% | 75% | 79%

Representativeness: Percentage score was based on a total maximum score of 10 points. This included assessment of how well the study described the study setting and population (2 points), inclusion/exclusion criteria (2 points), non participating patients (2 points), patient characteristics at enrollment (2 patients), and whether the study used a consecutive series or randomly selected sample (2 patients).

Description of Therapy: Percentage score was based on a total maximum score of 6 points. This included assessment of how well the study described details of the cardiac therapy given (2 points), whether the study described details of the psychiatric treatment given (2 points), and whether there was adequate description of other treatments given (2 points).

Description of Assessment: Percentage score was based on a total maximum score of 4 points. This included assessment of the description of methods used for initial diagnosis of depression (2 points), and the description of the interpretation criteria for a diagnosis of depression (2 points).

Outcomes and Follow up: Percentage score was based on a total maximum score of 12 points. This included assessment of whether the study reported numbers or reasons for withdrawals or those lost to follow up (2 points), the percentage of patients withdrawn or lost to follow up (2 points), whether the cardiac outcome measures were defined (2 points), whether the depression outcome measures were defined (2 points), whether the same tools for diagnosing depression were used for baseline and follow up (2 points) and the planned length of follow-up (2 points).

Statistical Analyses: Percentage score was based on a total maximum score of 8 points. This included assessment of whether statistical tests were clearly identified (2 points), whether loss to follow up was handled appropriately (2 points), whether the magnitude of the difference for primary endpoints or magnitude of association between outcomes and index variability is reported (2 points) and whether adjustment was made for confounding (2 points).

Conflict of Interest: Percentage score was based on a total maximum score of 2 points. This involved determination of whether the study identified the sources of funding and involvement of the funding agency.

Evidence Table 3.3C. Assessment of Study Quality in Studies on the Relation of Depression to Quality of Life in Patients After Myocardial Infarction (Question 3)

Study Author, Year | Representativeness | Description of Therapy & Management | Description of Assessment Protocol | Outcomes and Follow-Up | Statistical Analyses | Conflicts
Travella, 1994 | 70% | 38% | 88% | 80% | 50% | 65%
Drory, 1998 | 60% | 0% | 100% | 58% | 50% | 54%
Irvine, 1999 | 70% | 58% | 100% | 63% | 63% | 63%
Ladwig, 1999 | 30% | 0% | 38% | 69% | 38% | 53%
O'Rourke, 1999 | 60% | 0% | 100% | 63% | 19% | 41%
Soejima, 1999 | 75% | 0% | 63% | 63% | 69% | 66%
Bogg, 2000 | 35% | 0% | 50% | 97% | 50% | 73%
Denollet, 2000 | 60% | 8% | 100% | 85% | 81% | 83%
Lane 2000 | 95% | 8% | 100% | 88% | 88% | 88%
Mayou, 2000 | 75% | 17% | 100% | 58% | 50% | 54%
Lane, 2001 | 75% | 0% | 100% | 63% | 63% | 63%
Brink, 2002 | 75% | 0% | 100% | 78% | 56% | 67%
Drory, 2002 | 45% | 0% | 100% | 58% | 44% | 51%
Drory, 2003 | 20% | 0% | 50% | 40% | 50% | 45%

Representativeness: Percentage score was based on a total maximum score of 10 points. This included assessment of how well the study described the study setting and population (2 points), inclusion/exclusion criteria (2 points), non participating patients (2 points), patient characteristics at enrollment (2 patients), and whether the study used a consecutive series or randomly selected sample (2 patients).

Description of Therapy: Percentage score was based on a total maximum score of 6 points. This included assessment of how well the study described details of the cardiac therapy given (2 points), whether the study described details of the psychiatric treatment given (2 points), and whether there was adequate description of other treatments given (2 points).

Description of Assessment: Percentage score was based on a total maximum score of 4 points. This included assessment of the description of methods used for initial diagnosis of depression (2 points), and the description of the interpretation criteria for a diagnosis of depression (2 points).

Outcomes and Follow up: Percentage score was based on a total maximum score of 12 points. This included assessment of whether the study reported numbers or reasons for withdrawals or those lost to follow up (2 points), the percentage of patients withdrawn or lost to follow up (2 points), whether the cardiac outcome measures were defined (2 points), whether the depression outcome measures were defined (2 points), whether the same tools for diagnosing depression were used for baseline and follow up (2 points) and the planned length of follow-up (2 points).

Statistical Analyses: Percentage score was based on a total maximum score of 8 points. This included assessment of whether statistical tests were clearly identified (2 points), whether loss to follow up was handled appropriately (2 points), whether the magnitude of the difference for primary endpoints or magnitude of association between outcomes and index variability is reported (2 points) and whether adjustment was made for confounding (2 points).

Conflict of Interest: Percentage score was based on a total maximum score of 2 points. This involved determination of whether the study identified the sources of funding and involvement of the funding agency.

Evidence Table 3.4A. Assessment of Depression in Studies on the Relation of Depression to Survival in Patients after Myocardial Infarction(Question 3)

Study Author, Year | No Screened | No Enrolled | Depression Instrument | Time of Baseline Assessment | Mean Follow-up | Total Number at Enrollment | | Total at Follow-Up
| | | | | | Depressed | Non-Depressed
Ahern, 1990 | 502 | 265 | BDI ^a^ profile of mood states | 6 – 60 d ^b^ | 1 yr ^c^ | NR ^d^ | NR | NR
Ladwig, 1991 | 779 | 560 | NR | 3 wks ^e^ post MI | 6 mos ^f^ | “Extreme depression”: 80 | 480 | NR
Frasure-Smith, 1993 | 332 | 222 | MIMH DIS ^g^ | 5 – 15 d | 6 mos | 35 | 187 | NR
Frasure-Smith, 1999 | 2512 | 904 | BDI | After transfer from CCU ^h^ to ward | 1 yr | 290 | 606 | 896
Irvine, 1999 | 969 | 703 | BDI | 20 – 59 d | 2 yrs | NR | NR | 634
Denollet, 2000 | 322 | 319 | ZDS ^i^ | Within 2 mos post-MI | 5 yrs | Event free: 32%; CV ^j^ Events: 50%; Total Events: 57% | Event free: 68%; CV Events: 45%; Total Events: 49% | NR
Lane, 2000 | 437 | 288 | BDI | Within 15 d post-MI | 4 mos | 89 | 199 | 263
Welin, 2000 | 333 | 275 | ZDS | 3 – 6 d post-MI | 10 yr | ZDS > 40: 37% | ZDS < 40: 63% | NR
Bush, 2001 | 696 | 285 | SCID ^k^ BDI | 2.5 d post-MI | 4 mos | 73 | 194 | 271
Druss, 2001 | NR | 88241 | NR | NR | NR | NR | NR | NR
Lane, 2001 | 437 | 288 | BDI | Within 15 d post-MI | 12 mos | 89 | 199 | 257
Lane, 2002 | 437 | 288 | BDI | Within 15 d post-MI | 3 yrs | 89 | 199 | 250
Lesperance, 2002 | NR | 896 | BDI | Transfer from CCU to ward | 5 yrs | 290 | 606 | 715
Carney, 2003 | NR | NR | Depression interview: structured HAMD ^l^ and BDI | Within 28 d post-MI | Upto 30 mos | 358 | 408 | NR
Frasure-Smith, 2003 | NR | NR | NR | NR | 12 mos | NR | NR | NR

a Beck Depression Inventory

b Day

c Year

d Not reported

e Weeks

f Months

g National Institute of Mental Health Diagnostic Interview Schedule

h Coronary care unit

i Zung Depression Scale

j Cardiovascular

k Structured Clinical Interview for DSM-IV

l Hamilton Rating Scale for Depression

Evidence Table 3.4B. Assessment of Depression in Studies on the Relation of Depression to Cardiac Events in Patients after Myocardial Infarction(Question 3)

Study Author, Year | No. Screened | No. Enrolled | Depression Instrument | Time of Baseline Assessment | Mean Follow-Up | Total Number at Enrollment | | No. at Follow-Up | Total Number at Follow-Up
| | | | | | Depressed | Non Depressed | | Depressed | Non Depressed
Irvine, 1999 | 969 | 703 | Psychological questionnaire | After 2 wks ^a^ during post randomization | 2 yrs ^b^ | 634 | NR ^c^ | NR | NR | NR
Frasure-Smith, 2000 | 337 | 222 | Structured baseline interview | 1 wk following admission | 1 yr | 260 | 588 | NR | NR | NR
Druss, 2000 | All patient discharged from acute care hospital with diagnosis of AMI ^d^ | NR | ICD-9CM ^e^ | During index admission | 30 d ^f^ | NR | NR | NR | NR | NR
Shiotani, 2002 | 1828 | 1086 | Zung ^g^ | Zung mailed within 3 mos ^h^ after the onset of AMI. | 12 mos | 438 | 604 | 1042 | NR | NR
Strik, 2003 | 407 | 318 | SCL-90 ^i^ | 1 mo post-MI ^j^ | 3–4 yrs post-MI | NR | NR | NR | NR | NR
Strik, 2004 | NR | 422 | Baseline: SCID ^k^Follow-up: 3 psychiatric self rating scales BDI^l^, SCL-90,HADS ^m^ | 1 mo post-MI | NR | 63 | 143 | NR | 59 | 131

a Weeks

b Years

c Not reported

d Acute myocardial infarction

e The International Statistical Classification of Diseases and Related Health Problems

f Day

g Montreal Heart Attack Readjustment Trial

h Zung Self-Rating Depression Scale

i Months

j Symptom Checklist - 90

k Structured Clinical Interview for Diagnostic & Statistical Manual of Mental Disorders IV

l Beck Depression Inventory

m Hamilton Anxiety and Depression Scale

Evidence Table 3.4C. Depression Assessment of Studies on the Relation of Depression to Quality of Life in Patients after Myocardial Infraction(Question 3)

Study Author, Year | No. Screened | No. Enrolled | Depression Instrument | Time of Baseline Assessment | Mean Follow-Up | Total Number at Enrollment | | No. at Follow-Up
| | | | | | Depressed | Non Depressed
Travella, 1994 | NR^a^ | 129 | Present state examination - modified, HAM-D^b^ | During hospitalization | 12 months | 18 | 52 | 70
Drory, 1998 | NR | 276 | BDI^c^ | 7 days | 3 – 6 months | NR | NR | 276
Irvine, 1999 | 969 | 703 | BDI symptom checklist | 2 weeks | 2 years | NR | NR | 634
Ladwig, 1999 | NR | 552 | Depressivitats-Skaln | 17–21 days | 6 months | 74 | 466 | 376
O'Rourke, 1999 | 85 | 70 | HADS^d^ | 3–5 days | 6 months | 12 | 58 | 55
Soejima, 1999 | 136 | 134 | Depression Index | “soon after MI^e^” | NR | NR | NR | NR
Bogg, 2000 | 231 | 220 | HADS (II) Global mood scale | 3–4 days | 6 months | NR | NR | NR
Denollet, 2000 | NR | 322 | Zung^e^ | Within 2 months | 5 years | NR | NR | 299
Lane 2000 | 437 | 288 | BDI | Within 15 days | 4 months | 89 | 199 | 263
Mayou, 2000 | 546 | 344 | HADS | 3 days | 3 months, 12 months | 51 | 293 | 224
Lane, 2001 | 437 | 288 | BDI | Within 15 days | 12 months | 89 | 199 | 263
Brink, 2002 | 144 | 134 | HADS | Within 1week | 5 months | NR | NR | 114
Drory, 2002 | NR | NR | BDI | 1 week | 3 months, 6 months & 5 years | NR | NR | 209
Drory, 2003 | NR | NR | BDI | 1 week | 5 years | NR | NR | 62

a Not reported

b Hamilton Rating Scale for Depression

c Beck Depression Inventory

d Hospital Anxiety and Depression Scale

e Zung Self-Rating Depression Scale

Evidence Table 3.5A. Results of Studies on the Relation of Depression to Survival in Patients after Myocardial Infarction (Question 3)

Study Author, Year | Outcome Reported | | | Stat^a^ | Depressed vs.^b^Non Depressed | Multivariate Comparison | Independent Variables Adjusted for in Multivariate Analyses
| Cardiac Mortality | Total Mortality | Other
Ahern, 1990 | NA^c^ | NA | TM^d^ or cardiac arrest at baseline | RR^e^ | NR^f^ | 1.38 (CI^g^ 0.99 – 1.93) p < 0.05 | Previous MI^h^, LVEF^h^, 3–9 PVCs/min^i^ at baseline ECG^h^, Use of digitalis^h^, Use of B-blocker^h^, MI^j^ transmural
Ladwig, 1991 | Low: 0.9; Medium: 2.4; High: 7.5 | NA | Sustained VT^k^ admission | OR^l^ | Mantel-Haenszel p<0.001 | 2.8 low/med depression, 4.9 low/high depression p=0.07
Frasure-Smith, 1993 | | At 6 mos^m^ | NA | HR^n^ | 5.74 (CI 4.61 – 6.87) p = 0.0006 | 4.29 (CI 3.14 – 5.44)p = 0.013 | Previous MI^h^, Killip Class
Frasure-Smith, 1999 | NA | NA | Arrhythmia; MI recurrence; Revascularization; Any hard event | OR | CV death: 3.23 (CI 1.65 – 6.33); Arrhythmia 3.11 (CI 1.32 – 7.37); MI recurrence: 1.62(CI 0.93 – 2.8); Any hard events: 1.97 (CI 1.25 – 3.13); Revascularization: 0.82 (CI 0.53 – 1.26) | 3.66 (CI 1.68 – 7.99)** | Age, Smoking daily, LVEF^o^ ≤ 35% men^h^, LVEF < 35% women, BDI^p^ > 10^h^, Killip >2, non Q wave MI^h^
Irvine, 1999 | Sudden cardiac death | NA | NA | HR | AMI^q^: 0.52(CI 0.15 – 1.76) | NR | Prev MI^h^, CHF^r^ ^h^, dyspnea/fatigue^h^, social participation, social network contacts^h^, BDI somatic^h^, BDI affective^h^
Denollet, 2000 | Cardiac events | NA | QOL^s^: Poor perceived health at 5 yrs^t^, Depressive effect | OR | NR | 1.31 (CI 0.53 – 3.24)p=0.56 | Hyperlipidemia^h^, failure to quit smoking^h^, LVEF ≤ 50%^h^, Type D personality^h^
Lane, 2000 | Dep^u^: 9%, NonDep^v^: 1% | Dep: 10.1%, NonDep: 8% | Dart Dartmouth chart | OR | NR | NR | Peel Index score^h^, length of hospital stay^h^, Killip class^h^
Welin, 2000 | 17% | 24% | Non fatal recurrent MI; Stroke; Cancer | HR | TM: 2.45 (CI 1.49 – 4.02) ***, CM^w^: 3.54 (CI 1.85 – 6.79)*** | TM 1.75 (CI 1.02 – 2.99)*, CM 3.16 (CI 1.38 – 7.25)*** | Gender^h^, Social support^h^, LV failure^h^, Ventricular dysrhythmia^h^, Post-MI depression^h^
Bush, 2001 | NA | Dep: 13%, NonDep: 4% | NA | RR | 3.8 p=0.008 | 3.5 p=0.001 | Age^h^, EF^x^ 35%^h^, DM†, Killip class, Depression^h^, CAD^y^
Druss, 2001 | NA | NA | NA | HR | Mental: 1.19 (CI 1.04 – 1.36), Affective 1.11 (CI 1.03 – 1.18) | NR | Smoking cessation, ASA^z^, ACE^aa^, Lytics
Lane, 2001 | 10% | 10% | QOL | OR | CM 1.15 (CI 0.49 – 2.69) | NR | Age^h^, Peel index^h^, Killip class^h^,
Lane, 2002 | Dep: 10% | NA | NA | OR | TM: 1.04 (CI 0.5 – 2.16), CM: 0.84 (CI 0.37 – 1.90) | NR | Age^h^, Killip class^h^, Peel^h^, Urban^h^, Education^h^, Beta-blocker^h^
Lesperance, 2002 | < 5 yr: 7%; 5 – 9 yr: 14%; 10–18 yr: 19%; > 19 yr: 27% | 44***; < 5 yr: 11%; 5 – 9 yr: 16%; 10–18 yr: 23%; > 19 yr: 33% | NA | HR | BDI 5 – 9: 1.94 (CI 1.16 – 3.25) p=0.01; BDI 10 – 18: 2.8 (CI 1.68 – 4.66) p<0.001; BDI > 19: 1.32 (CI 2.4 – 7.75) p<0.001 | TM: BDI 10 – 18: 2.35 (CI 1.53 – 3.61)*** BDI ≥ 19 (CI 2.16 – 5.92)*** TM: BDI 10 – 18: 3.17 (CI 1.79 – 5.6)*** BDI ≥ 19: 3.13 (CI 1.56 – 6.27)*** | Age^h^, gender, HT h/o Rx^ab^, smoking, previous MI^h^, LVEF^h^, Killip Class > 1, thrombolysis^h^, Q wave MI, education < 8y, unmarried, revascularization^h^, B blockers, Diabetes, BDI > 10
Carney, 2003 | NA | NA | Non Fatal AMI | HR | NR | TM 2.4 (CI 1.2 – 4.7)** Non-Fatal AMI 1.2 (CI 0.7 – 2.0)* | Age^h^, DM^h^, Smoking (ever smoker)^h^, LVEF < 50%^h^, LVEF< 40%^h^, Coronary bypass after index MI^h^
Frasure-Smith, 2003 | At 5 yr | NA | NA | HR | NR | 1.44 (CI 91.17-1.78)*** | Age^h^, Female, Smoking, Previous MI^h^, LVEF ≤ 35%^h^, Killip Class > I, Social support, Thrombolysis at index admission^h^, Q wave MI, Negative affectivity^h^, Overt anger, Education < 8y, Revascularization of index admission^h^, B-blocker at discharge^h^, BDI - cognitive^h^, BDI - somatic^h^, Diabetic medicine at discharge^h^

a Comparison statistic

b Versus

c Not applicable

d Total mortality

e Risk ratio

f Not reported

g Confidence interval

h Significant at p<0.05

i Premature ventricular contractions per minute

j Myocardial infarction

k Ventricular tachycardia

l Odds ratio

m Months

n Hazard ratio

o Left ventricular ejection fraction

p Beck Depression Inventory

q Acute myocardial infarction

r Congestive heart failure

s Quality of life

t Years

u Depressed

v Non Depressed

w Cardiac mortality

x Ejection fraction

y Coronary artery disease

z Acetylsalicyclic Acid

aa Acute coronary event

ab History of hypertension treatment

Evidence Table 3.5B. Results of Studies on the Relation of Depression to Cardiac Events after Myocardial Infarction (Question 3)

Study Author, Year | Outcome | | | Stats^a^ | Univariate Comparison | Multivariate Comparison | Independent Predictor Variables Adjusted for in the Multivariate Analyses
| Cardiac Events | Cardiac Mortality | Other
Irvine, 1999 | NR^b^ | Sudden cardiac death 34 Other cardiac death 16 | Vascular death 1, non-cardiac death 12 | RR^c^ | Depression not reported to be significant predictor of SCD^d^ in univariate analysis | Amiodarone Group: BDI^e^ somatic score 1.10(0.93,1.29) BDI cognitive-affective score 0.73 (0.52,1.01) Placebo Group: BDI somatic score 1.00(0.88,1.13) BDI cognitive-affective score 1.09(0.99,1.89) | Prev MI^f^, prev CHF^g^, dyspnea/fatigue, social participation, social network contacts
Frasure Smith, 2000 | Recurrent cardiac events (survived and nonsurvived reinfarctions), admission for unstable angina, arrhythmic deaths, survived cardiac arrests. | NA^h^ | NA | OR^i^ | Any cardiac event: 3.32 (1.69,6.53) Acute coronary syndrome 2.75 (1.32,5.72) Arrhythmic event: 3.65 (0.99,10.47) | Recurrent cardiac events 1.99(0.92,4.31) | Prev MI, Prescription of ACE-I^j^ at discharge, previous depression, anxiety.
Druss, 2000 | NA | Total mortality at 1 month | Likelihood of PTCA^k^ or CABG^l^ during index hospitalization | OR | Total Mortality 7.3% in patients with affective disorders compared to 10.8% in patients with no mental disorders. | Total Mortality 0.63 ( p=0.2) in patients with affective disorders RR for use of PTCA and CABG in patients with affective disorders: PTCA: 0.51 CABG : 0.63 | Age, gender, race/ethnicity, HT^m^, DM^n^, smoker, prev MI, LVEF^o^, angina, pulse, discharged home, PTCA past yr, CABG past yr, SBP^p^, CCF, anterior infarction, thrombolysis Rx^q^, shock
Shiotani, 2002 | Annual cardiac event rate 31.2% in Dep^r^ patient and 23.9% in NonDep^s^ patient. Cardiac events: Dep 138, NonDep 145; MI: Dep 19, NonDep 15; Arrhythmias: Dep 2, NonDep 1; RePTCA: Dep 94, NonDep 110; Heart Failure: Dep 7, NonDep 5; Angina: Dep 6, NonDep 5 | Cardiac Mortality: Dep 4 NonDep 1 | Readmission Dep: 34 NonDep: 26 | OR | Cardiac Events: 1.46 (CI^t^ 1.11 – 1.92) | Cardiac Events: 1.41(CI 1.04 – 1.92) | Age, gender, HT, DM, smoking, Killip Class ≥ 2, peak creatinine kinase, depressive symptoms
Strik, 2003 | Non Fatal MI at 3–4 yrs^u^ | Fatal MI at 3 – 4 yrs | Healthcare consumption at 3–4 yrs^v^ | HR- cardiac events OR- Health care consumption | CI- Not reported as single variables. Healthcare Consumption: 1.61 (CI 1.00 – 2.57) | MI:CI 2.32 (1.04 – 5.18); Healthcare Consumption: 1.55 (CI 0.96 – 2.52) | Age> 58 yrs, LVEF(50%, use of antidepressants
Strik, 2004 | Major cardiac events 1 mo – 3 yrs (included death/recurrent MI; increased health care consumption, > 6 visits at the cardiac outpatient clinic during follow up) | NA | Healthcare consumption 1m – 3 yrs | Depression as predictor of major cardiac event-HR;depression as predictor of health care consumption- OR | Cardiac events: 1.1(0.36,3.42) Healthcare Consumption1.66 (CI 0.90 – 3.07) | Cardiac Events: 0.88(0.26,2.93) Healthcare Consumption 1.98 (CI 1.0 – 3.93) | Age > 58 yrs, gender, smoking(current), LVEF < 50%, PTCA, thrombolysis

a Comparison statistic

b Not reported

c Risk ratio

d Sudden cardiac death

e Beck Depression Inventory

f Myocardial infarction

g Congestive heart failure

h Not applicable

i Odds ratio

j Angiotensin I converting enzyme

k Percutaneous coronary angioplasty

l Coronary artery bypass graft

m Hypertension

n Diabetes

o Left ventricular ejection fraction

p Systolic blood pressure

q Treatment

r Depressed

s Non-depressed

t Confidence interval

u Years

v Cardiac rehospitalization and/or frequent visits

Evidence Table 3.5C. Results of Studies on the Relation of Depression to Quality of Life in Patients after Myocardial Infarction (Question 3)

Study Author, Year | Outcome | | Comparison Statistic | Univariate Comparison | Multivariate Comparison | Independent Variables Adjusted for in Multivariate Analyses
| QOL^a^ | Other
Travella, 1994 | Johns Hopkins functioning inventory, Social functioning exam | NA^b^ | Multivariate Rank | NR^c^ | Social functioning exam with depression after baseline: f=1.85 (p=0.167); 3mos^d^: f=7.73 (p=0.1), 6mos f=4.38 (p=0.45), 9mos: f=13.45 (p=0.001), 12mos f=7.94 (p=009) | NR
Drory, 1998 | Frequency of sexual activity after MI at 3 – 6mos, Satisfaction with sexual activity after MI^e^ | Depression | Pearson Correlation | Frequency of sexual activity -0.16 (p<0.01); Satisfaction with sexual activity -0.14 (p<0.01); | Frequency of sexual activity: -0.14(p<0.01); Satisfaction with sexual activity: -0.15(p<0.01)) | Age, Race/ethnicity, Diabetes, Previous heart disease, Other medical conditions, Depression by BDI, Perceived health prior to MI, Frequency prior to AMI^f^, Education,
Irvine, 1999 | Social perception and help, daily living | Sudden cardiac death | Cox | OR^g^ | NR | Prev MI, Prev CHF^h^, Dyspnea/Fatigue, Social participation, Social network contacts
Ladwig, 1999 | NA | Perception of angina pectoris | OR | NR | 2.98 (CI^i^ 1.50 – 5.90) | Age > 50years, SBP^j^ > 160 mmHG^k^, Pre-infarction angina, Recurrent infarction, SES^l^, Stroke, Non-fatal cardiac events, Re-infarction, Cardiac surgery, Hospitalization for severe angina, Episode of unconsciousness
O'Rourke, 1999 | Illness perception questionnaire | NA | Regression ANOVA | NR | NR | Anxiety, Control, Consequences
Soejima, 1999 | RTW^m^ | NA | Logistic regression OR | OR | RTW Extroversion 3.72 (CI 1.33 – 10.4) Despressive Sx^n^ in hospital0.15 (CI 0.02 – 0.87) | Age, Gender (male), Extraversion, Depressive Sx in Hospital, Education, Occupation
Bogg, 2000 | QOL after MI | NA | Regression | NR | Physical QOL male R^2^=46, Physical QOL female R^2^=27, Baseline anxiety R^2^=54 | NR
Denollet, 2000 | Global mood scale, Health complaint scale | NA | Regression or OR | NR | Failure to quit smoking 2.3 (1.2 – 4.5); Depressive sx 3.3 (1.9 – 5.8); Type D personality 2.2 (1.2 – 3.8); EF^o^ < 50% 2.0 (1.0 – 3.9); Hyperlipidemia 2.0 (1.1 – 3.4) | NR
Lane 2000 | Dartmouth COOP^p^ Charts, BDI^q^ | NA | Correlation score | Gender R=0.31, Partner status R=0.24,Living alone R=0.20, Employment status R=0.18, Frequency of exercise R= -0.21, Duration of exercise R= -0.17 BDI R=0.37, State anxiety R=0.28, Treat anxiety R=0.32, Peel Index R =0.27, LOS^r^ R=0.15 | BDI R^2^= 0.11 (p=0.0001), Partner status 0.05 (p=0.002), Peel Index 0.05 (p=0.001), State anxiety 0.02 | BDI, Peel Index, Partner status, State anxiety
Mayou, 2000 | SF-36 Score^s^ | NA | HR^t^ | Total mortality: NR; At baseline: 51.2(distressed), At baseline: 67.5(non distressed) p<0.05; At 3 mos: 38.7(distressed), At 3m: 62.3(nondistressed) p<0.05; At 12 mos: 47.2(distressed), At 12 mos: 64.0(non distressed) p<0.05 | Total mortality: NR | NR
Lane, 2001 | NR | NA | Regression Correlation | Gender R=0.2, Partner status R=0.22, Living alone R=0.3, Employment status R=0.18, Frequency of exercise R= -0.18, BDI R=0.32, State anxiety R=0.28, Treat anxiety R=0.24, Peel Index R=0.29, Killip class R=0.15, LOS R=0.25 | BDI 0.11, Living alone 0.07, Peel Index 0.07, State anxiety 0.03 | BDI, Peel Index, Partner status, State anxiety
Brink, 2002 | Physical Component SF-36, Mental Component SF-36 | NA | Zero order Correlation | NR | Physical Component:-0.47; Mental Component: -0.66 | HADS^u^-anxiety, Coping, Health complaints
Drory, 2002 | Perceived health status | NA | Hierarchical Regression | NR | Psychological well being | Sense of coherence, Depression, Education, Social support
Drory, 2003 | Perceived health status | NA | Regression | NR | NR | Health status, Concomitant health problems, Perceived health status

a Quality of life

b Not applicable

c Not reported

d Months

e Myocardial infarction

f Acute myocardial infarction

g Odds ratio

h Congestive heart failure

i Confidence interval

j Systolic blood pressure

k Millimeters of mercury

l Socio-economic status

m Return to work

n Symptoms

o Ejection fraction

p Dartmouth Primary Care Cooperative Information Project charts

q Beck Depression Inventory

r Length of stay

s Medical Outcomes Study 36-item short form questionnaire

t Hazard ratio

u Hospital Anxiety and Depression Scale

Evidence Table 3a.1. Characteristics of Studies on the Relation of Depression to Biomarkers in Patients After Myocardial Infarction (Question 3a)

Study Author, Year | Study Design | Target Population | Exclusion Criteria | Number of Study Sites | Study Site | Recruitment Period | Study Objective
Carney, 2001 | Pro cohort ^a^ | Only MI ^b^ patients | Active suicidal ideation, h/o ^c^ of alcoholism/substance, cognitively impaired, life threatening medical illness, severe psychiatric disorder, physically unable to complete the interview, lived too far away, atrial fibrillation or flutter, implanted pacemaker | Multicenter,4 | USA | Oct 1997 - Jan 2000 | To determine if depression is associated with reduced heart rate variability in patients with a recent MI.
Kuijpers, 2002 | Pro cohort | Only MI patients | Previous MI | NR ^d^ | Europe | NR | To investigate whether platelet function is increased in depressed patients with first MI using PF 4 ^e^ and B-TG ^f^ as markers compared with a group of non-depressed post-MI patients matched for age, sex, and size of MI.
Lesperance, 2004 | Pro cohort | 481 patients with ACS ^g^ 81.7% with MI Data for MI not reported seperately. | Terminally ill < 2 years, cognitively impaired, non French speaking, ACS secondary to medical illness, too far from intervention site, using antibiotics | Multicenter,2 | Canada | Aug 1999 - Aug 2001 | To determine whether or not depression is associated with higher levels of inflammatory markers in patients recovering from acute coronary syndromes.

a Prospective cohort study

b Myocardial infarction

c History of

d Not reported

e Platelet factor 4

f Beta-thromboglobulin

g Acute coronary syndrome

Evidence Table 3a.2. Patient Characteristics of Studies on the Relation of Depression to Biomarkers in Patients After Myocardial Infarction (Question 3a)

Study Author, Year | No. of Subjects | Mean Age | Male (%) | Married (%) | HTN ^a^ (%) | DM ^b^ (%) | Smoking (%) | Lipid ^c^ (%) | Killip Class (I–IV) (%) | Mean Ejection Fraction | H/o ^d^ Depression (%)
Carney, 2001 | Dep: 307, NonDep: 366 | Dep: 57, NonDep: 4 | Dep: 50, NonDep: 68 | Dep: 57, NonDep: 77 | Dep: 22, NonDep: 20 | Dep: 35, NonDep: 22 | Dep: 41, NonDep: 23 | NR ^e^ | NR | Dep: 46, NonDep: 47 | NR
Kuijpers, 2002 | Dep: 12, NonDep: 12 | Dep: 48, NonDep: 50 | Dep: 95, NonDep: 95 | NR | Dep: 8, NonDep: 50 | NR | Dep: 42, NonDep: 25 | NR | NR | NR | NR
Lesperance, 2004 | NonDep: 446, Dep: 35 | NonDep: 60, Dep: 57 | NonDep: 82, Dep: 66 | NR | NonDep: 66, Dep: 66 | NonDep: 32, Dep: 43 | NonDep: 14, Dep: 43 | NonDep: 48, Dep: 74 | NR | EF^f^< 45%, NonDep: 28%^g^ Dep: 31% | NonDep: 15, Dep: 40

a Hypertension

b Diabetes

c Hyperlipidemia

d History of

e Depressed

f Non-depressed

g Not reported

h Ejection fraction

i N=434

Evidence Table 3a.3. Assessment of Study Quality in Studies on the Relation of Depression to Biomarkers in Patients After Myocardial Infarction (Question 3a)

Study Author, Year | Representativeness | Description of Therapy & Management | Description of Assessment Protocol | Outcomes and Follow-Up | Statistical Analyses | Conflicts
Carney, 2001 | 80% | 17% | 100% | 58% | 75% | 79%
Kuijpers, 2002 | 40% | 50% | 100% | 50% | 75% | 75%
Lesperance, 2004 | 90% | 33% | 100% | 50% | 0% | 75%

Representativeness: Percentage score was based on a total maximum score of 10 points. This included assessment of how well the study described the study setting and population (2 points), inclusion/exclusion criteria (2 points), non-participating patients (2 points), patient characteristics at enrollment (2 patients), and whether the study used a consecutive series or randomly selected sample (2 patients).

Description of Therapy: Percentage score was based on a total maximum score of 6 points. This included assessment of how well the study described details of the cardiac therapy given (2 points), whether the study described details of the psychiatric treatment given (2 points), and whether there was adequate description of other treatments given (2 points).

Description of Assessment: Percentage score was based on a total maximum score of 4 points. This included assessment of the description of methods used for initial diagnosis of depression (2 points), and the description of the interpretation criteria for a diagnosis of depression (2 points).

Outcomes and Follow-up: Percentage score was based on a total maximum score of 12 points. This included assessment of whether the study reported numbers or reasons for withdrawals or those lost to follow-up (2 points), the percentage of patients withdrawn or lost to follow-up (2 points), whether the cardiac outcome measures were defined (2 points), whether the depression outcome measures were defined (2 points), whether the same tools for diagnosing depression were used for baseline and follow-up (2 points) and the planned length of follow-up (2 points).

Statistical Analyses: Percentage score was based on a total maximum score of 8 points. This included assessment of whether statistical tests were clearly identified (2 points), whether loss to follow-up was handled appropriately (2 points), whether the magnitude of the difference for primary endpoints or magnitude of association between outcomes and index variability is reported (2 points) and whether adjustment was made for confounding (2 points).

Conflict of Interest: Percentage score was based on a total maximum score of 2 points. This involved determination of whether the study identified the sources of funding and involvement of the funding agency.

Evidence Table 3a.4. Depression Characteristics of Studies on the Relation of Depression to Biomarkers in Patients after Myocardial Infarction (Question 3a)

Study Author, Year | No. Screened | No. Enrolled | Depression Instrument | Time of Baseline Assessment | Mean Follow-Up | Total Number at Enrollment | | Total Number at Last Follow-Up | | No at Follow-Up
| | | | | | Dep ^a^ | NonDep ^b^ | Dep | NonDep
Carney, 2001 | NR ^ c ^ | Dep 380 NonDep 424 | Screening: ENRICHD ^d^ modified DSM-IV ^e^ DISH ^f^: present depressive episode BDI ^g^: severity of depression | Recent acute MI ^h^ (≤28 d^i^) | NA ^ j ^ | 307 | 366 | NA | NA | NA
Kuijpers, 2002 | NR | NR | DSM-IV | 3–6 mos ^k^ after first MI | NA | 12 | 12 | NR | NR | NA
Lesperance, 2004 | 2716 | 965 | SCID ^ l ^ | 2 mos after hospital discharge | NA | 35 | 446 | NR | NR | NA

a Depressed

b Non-depressed

c Not reported

d Enhancing Recovery in Coronary Heart Disease

e Diagnostic & Statistical Manual of Mental Disorders

f Depression Interview and Structured Hamilton

g Beck Depression Inventory

h Myocardial infarction

i Day

j Not applicable

k Months

l Structured Clinical Interview for Diagnostic & Statistical Manual of Mental Disorders-IV

Evidence Table 3a.5. Results of Studies on the Relation of Depression to Biomarkers in Patients after Myocardial Infarction (Question 3a)

Study Author, Year | Outcome | Comparison Statistic | Depressed vs ^a^ Non-Depressed | Multivariate Comparison | Independent Predictor Variables Adjusted for in the Multivariate Analyses | Comments
| Biomarkers
Carney, 2001 | In univariate analysis all 4 indicies of 24 hour HRV ^b^ were significantly lower in patients with depression. | Linear regression | NR ^c^ | NR | Age, Gender, Diabetes smoking status. | Patients assessed for depression after excluding patients with score ≥10 on Orientation Memory concentration test.
| In multi-variate analysis all 3 indices except 24 hour HRV were significantly lower in patients with depression. | | | | | The ENRICHD ^d^ modified DSM-IV^e^ criteria allowed to be eligible if depressive symptoms present for atleast 7 days provided if patient had atleast one prior depressive episode.
Kuijpers, 2002 | PF4 ^f^ was significantly higher in depressed post MI patients compared to non-depressed post MI patients, p=0.021. | Mann-Whitney U | PF4 mean rank 15.75 IU/ml vs 9.25 IU/ml | NR | Age, Gender, Size of MI | No patients with diabetes, renal or hepatic failure.
| There was a trend toward a significantly increased B-TG ^g^ level with p=0.08, inspite of use of aspirin | | B-TG mean rank 15.04 IU/ml vs 9.96 IU/ml | | | Small sample size
| | | | | | Depressed patients did not use any anti-depressant medication. All patients were treated with anti hypertensive medications.
Lesperance, 2004 | Depressed patients had significantly higher sICAM?1 ^h^ levels even after adjustment for confounders. These results were only slightly attenuated by adjustment of antidepressant treatment. | Linear regression | NR | sICAM | Gender ^k^, Smoking ^k^, Metabolic syndrome ^k^ | Results derived from single blood sample with no inferences about the time course of inflammatory markers in relationship to cardiac event Higher non response rate.
| No significant association between depression and IL6 ^i^. Uncertain about the relationship of CRP ^j^ on depression as patients were on statins. | | | 0.095+/-0.044 (with depression)
| | | | 0.086+/-0.045 (with antidepressant added to the model)

a Versus

b Heart rate variability

c Not reported

d Enhancing Recovery in Coronary Heart Disease Trial

e Diagnostic & Statistical Manual of Mental Disorders

f Platelet factor 4

g Beta thromboglobulin

h Serum levels of soluble anti?intercellular adhesion molecule-1

i Interleukin 6

j C-reactive protein

k Significant at p< 0.05

Evidence Table 4.1. Characteristics of Studies of Treatment of Post Myocardial Infarction Depression (Question 4)

Study Author, Year | Study Design | Target Population | Exclusion criteria | Number of Study Sites | Study Site | Recruitment Period | Study Objective
Dracup, 1991 | Pro cohort^a^ | 141 patients with CABG^b^ 69% with MI^c^ | A^d^ < 25 or ≥ 80; h/o^e^ psychosis; bipolar disorder; non-English speaking; MI/CABG > 12 mos | Multicenter, 6 | USA | May 1985 - Apr 1989 | To compare the psychosocial adaptation of patients who participated in a multidimensional cardiac rehabilitation program with that of patients who did not.
| | No separate data for MI patients provided
Brown, 1993 | RCT^g^ | 81 patients with ACS^h^ included 62.5% with MI | A < 43 or > 75; unstable medical condition; severe depression status before cardiac event; suicidal ideation; changes in county residence; unwilling/unable to include partner | Multicenter, 5 | USA | May 1994 - Dec 1997 | To evaluate effectiveness of behavior therapy for treating distress in patients diagnosed with depression and/or anxiety after an MI or CABG.
| | No separate data for MI patients provided
Crowe, 1996 | RCT | Only MI patients | A > 73; non-English speaking; unable to complete questionnaire; unable to exercise with cycle ergometer/treadmill at low levels/limited by musculoskeletal; neurological/other medical conditions | Multicenter, 6 | Canada | Mar 1985 - Apr 1988 | To assess patients for symptoms of anxiety and depression while they were hospitalized for acute MI and to describe the occurrence of symptoms of anxiety and depression in a selected group of patients during the first year after the acute MI.
Frasure-Smith, 1997 | RCT | Only MI patients | Life-threatening conditions; cognitively impaired; residence from study hospital > 20 miles; deafness; refusal by patient physician; participation in other trials; no telephone; non-English/non-French speaking | Multicenter, 10 | Canada | Jan 1991 - Sep 1994 | To find out whether a program of monthly screening for psychological distress combined with supportive and educational home nursing interventions for distressed patients would reduce 1-year cardiac mortality for men and women.
Taylor, 1997 | RCT | Only MI patients | A > 70; serious comorbid conditions; non-English speaking; substance abuse/other psychological problems | Multicenter, 5 | USA | 1988 - 1991 | To assess effects of a nurse-case managed, mutlifactorial risk reduction program on psychological distress among post-MI patients.
Roose, 1998 | RCT | 81 patients with ACS included 62.5% with MI | MI within 3 mos; QTc^i^ > 460 ms; taking class I antiarrhythmic; taking warfarin; unstable angina/cressendo | Multicenter, 4 | USA | Not specified | To compare the efficacy, cardiovascular effects and safety of an SSRI^j^ (paroxetine) with a tricyclic antidepressant (nortriptyline hydrochloride) in depressed patients with ischemic heart disease.
| | No separate data for MI patient provided
Johnston, 1999 | RCT | Only MI patients | A > 70; non-English speaking; unable to give informed consent | Single center | Europe | Jan 1992 - Feb 1983 | To see after a first MI, whether patients who receive an inpatient cardiac rehabilitation demonstrate equal or greater benefit than those receiving normal care or an extended program.
Strik, 2000 | RCT | Only MI patients | A < 18 or > 75; hepatic dysfunction; other significant non-reactive disease; psychosis; bipolar disorder; organic brain syndrome; dementia; serious comorbidity; pregnant or lactating; use of psychotropic drugs; right ventricular filling pressure > 30 mmHg; ATVI^k^ < 20 cm; hypersensitivity to fluoxetine | Multicenter, 2 | Europe | May 1994 - Dec 1997 | To investigate the efficacy and safety of the anti-depressant fluoxetine in patients with depression after their first MI.
McFarlane, 2001 | RCT | Only MI patients | CHF^l^; life threatening illness; inability to complete questionnaire; already on antidepressants; 24 hour pre-discharge holter monitoring with AF^m^ /ventricular ectopic beat > 100/hour | Single center | Canada | Sep 1996 - Mar 1999 | To determine whether sertraline, an SSRI, facilitates rate of recovery of cardiac autonomic function after an acute MI in patients with depression
Glassman, 2002 | RCT | 369 patients with ACS 79.67%,with MI | Anticipating cardiac surgery within 6m; index ACS < 3 mos after surgery; resting HR^n^ < 40/min; Killip Class > III; uncontrolled HTN^o^; persistent clinically significant abnormalities; renal dysfunction; hepatic dysfunction; other significant noncardiac illness; anemia; cocaine use; alcohol or substance abuse; women of childbearing potential not using adequate contraception; psychosis; bipolar disorder; organic brain syndrome; dementia; significant suicide risk; terminally ill; MMSE^p^ < 23; concomitant Rx^q^ with class I anti-arrhythmic | Multicenter, 40 | USA Canada Europe Australia | Apr 1997 - Apr 2001 | To evaluate safety and efficacy of sertraline treatment of MDD^r^ in patients hospitalized for MI or unstable angina and free of other life threatening illness.
| | No separate data for MI provided
Berkman, 2003 | RCT | Only MI patients | Noncardiac conditions fatal within 1y; too ill to participate; participating in another protocol; major psychiatric comorbidity; imminent risk for suicide; physician disallowed participation; receiving psychotherapy for depression; MI following PCI^s^ or CABG | Multicenter, 8 | USA | Oct 1996 - Oct 1999 | To determine whether mortality and recurrent infarction are reduced by treatments of depression and LPSS^t^ with cognitive behavior therapy, supplemented with SSRI when indicated, in patients enrolled within 28 days after MI.
Swenson, 2003 | RCT | Included cases of MI and unstable angina. Patients of unstable angina not recruited till 1998 | Anticipating cardiac surgery; index ACS < 3 mos after surgery; non-atherosclerotic MI; Killip Class > III; uncontrolled HTN; persistent clinically significant abnormalities; renal dysfunction; hepatic dysfunction; other significant cardiac disease; women of childbearing A not using adequate contraception; alcohol or substance abuse; psychosis; bipolar disorder; organic brain syndrome; dementia; resting HR < 40/min; Rx with class I antiarrhythmic; reserpine; guanethidine; clonidine; methyldopa; anticonvulsants; neuroleptics; antidepressant; regular benzodiazepine; initiation of psychotherapy in 3m prior to study entry | Multicenter, 7 countries 40 outpatient cardiology centers and psychiatry clinics | USA, Canada, Europe, Australia | Apr 1997 - Apr 2001 | To examine the effect of sertraline treatment on quality of life and functioning in patients diagnosed with major depression who had been recently hospitalized for acute MI or unstable angina.
| | No separate data for MI provided

a Prospective cohort study

b Coronary artery bypass graft

c Myocardial infarction

d Age

e History of

f Months

g Randomized controlled trial

h Acute coronary syndrome

i QT Interval corrected for heart rate

j Selective serotonin reuptake inhibitor

k Aortic time velocity integral

l Congestive heart failure

m Atrial fibrillation

n Heart rate

o Hypertension

p Mini Mental State Evaluation

q Treatment

r Major depressive disorder

s Percutaneous Coronary Intervention

t Low perceived social support

Evidence Table 4.2. Characteristics of Patients in Studies of Treatment of Post Myocardial Infarction Depression (Question 4)

Study Author, Year | No. of Subjects | Mean Age | Male (%) | White (%) | Married^a^ (%) | Education^b^ (%) | Employed^c^ (%) | HTN^d^ (%) | DM^e^ (%) | Smoking (%) | Lipid^f^ (%) | Killip Class (%) | Mean Ejection Fraction (%) | H/o^g^ Dep (%)
Dracup, 1991 | 41^h^; 100^i^ | 63^h^; 63^i^ | 93^h^; 88^i^ | NR | 95^h^; 97^i^ | 34^h^; 15^i^ | 39^h^; 46^ii^ | NR | NR | NR | NR | NR | NR | NR
Brown, 1993 | 20^ i^; 20^j^ | 63i; 58^j^ | 55i; 90^j^ | 100i; 100^j^ | 90^i^; 85^j^ | 100^i^; 100^j^ | NR | NR | NR | NR | NR | NR | NR | NR
Crowe, 1996 | 99^j^; 102^i^ | 55 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Frasure-Smith, 1997 | 692^k^; 684^l^ | 59^k^; 59^l^ | 66k; 65^l^ | NR | NR | NR | NR | Reported HTN Rx^m^: 37^k^; 34^l^ | NR | 49^k^; 50^l^ | NR | Class I: 63^k^, 66l; Class II: 16^k^; 14^l^; Class III – IV: 21^k^; 20^l^ | 49^k^, 49^l^ EF^n^ ≤35%: 16^k^; 16^l^ | NR
Taylor, 1997 | 199^s^; 179^l^ | 57^s^; 57^l^ | 80^s^; 75^l^ | 76^s^; 80^l^ | 78^s^; 82^l^ | NR | Full time: 74^s^; 69^l^ | NR | NR | 41^s^; 39^l^ | NR | NR | NR | NR
Roose, 1998 | 41^r^; 40^t^ | 58^r^; 58^t^ | 88^r^; 78^t^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | 58^r^; 60^t^ | 73^r^; 67^t^
Johnston, 1999 | 29k; 38^l^; 33^l^ | 57^k^; 54^l^; 57^l^ | 67^k^; 71^l^; 59^l^ | NR | NR | 100^k^; 100^l^; 100^l^ | NR | NR | NR | 48^k^; 74^l^; 61^l^ | NR | NR | NR | NR
Strik, 2000 | 27^v^; 27^p^ | 54^v^; 59^p^ | 77^v^; 62^p^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | 51^v^; 51^u^ | NR
McFarlane, 2001 | 12^r^; 15^t^ | 56^r^; 56^t^ | 67^r^; 53^t^ | NR | NR | NR | NR | 50^r^; 38^t^ | 30^r^; 23^t^ | 58^r^; 67^t^ | NR | NR | 53^r^; 58^t^ | NR
Glassman, 2002 | 186^w^; 183^u^ | 57^w^; 58^u^ | 63^w^; 64^u^ | 74^w^; 79^u^ | NR | NR | NR | 61^w^; 69^u^ | 31^w^; 30^u^ | 27^w^; 28^u^ | 70^w^; 67^u^ | Class II–IV: 7.1^w^; 7.1^u^ | 54^w^; 52^u^ | 52^w^; 50^u^
Berkman, 2003 | 1238^s^; 1243^l^ | 61^s^; 61^l^ | 57^s^; 56^l^ | 67^s^; 66^l^ | 53^s^; 51^l^ | 48^s^; 46^l^ | NR | 60^s^; 61^l^ | 32^s^; 33^l^ | 64^s^; 65^l^ | 58^s^; 56^l^ | Class III – IV 7^s^; 7^l^ | NR | NR
Swenson, 2003 | 184^r^; 183^u^ | 57^r^; 58^u^ | 63^r^; 64^u^ | 74^r^; 79^u^ | 55^r^; 72^u^ | 73^r^; 69^u^ | 38^r^; 38^u^ | 61^r^; 69^u^ | 30^r^; 31^u^ | 78^r^; 74^u^ | 69^r^; 67^u^ | Class II – IV 7.0^r^; 7.1^u^ | 54^r^; 52^u^ | NR

a Married or living with a partner

b Education high school or higher

c Employment full time or part time

d Hypertension

e Diabetes mellitus

f Hyperlipidemia

g History of

h Cardiac rehabilitation

i Usual care

j Rehabilitation

k Psychosocial intervention

l Behavioral intervention

m Treatment

n Ejection fraction

o Usual care, no supportive therapy

p Extended cardiac counseling

q Inpatient cardiac counseling

r Intervention

s Paroxetine

t Nortriptyline

u Placebo

v Fluoxetine

w Sertraline

Evidence Table 4.3. Assessment of Study Quality in Studies of Treatment of Post Myocardial Infarction Depression (Question 4)

Article ID | Representativeness | Bias and Conflict | Description Therapy and Management | Description Protocol | Outcomes and Follow-Up | Statistical Analyses | Conflicts
Dracup, 1991 | 35% | 33% | 34% | 34% | 34% | 34% | 34%
Crowe, 1996 | 80% | 38% | 59% | 48% | 53% | 51% | 52%
Frasure-Smith, 1997 | 85% | 88% | 86% | 87% | 87% | 87% | 87%
Roose, 1998 | 70% | 58% | 64% | 61% | 63% | 62% | 62%
Johnston, 1999 | 60% | 88% | 74% | 81% | 77% | 79% | 78%
McFarlane, 2001 | 75% | 88% | 81% | 84% | 83% | 84% | 83%
Berkman, 2003 | 100% | 63% | 81% | 72% | 77% | 74% | 75%
Swenson, 2003 | 90% | 100% | 95% | 98% | 96% | 97% | 97%
Brown, 1993 | 70% | 75% | 73% | 74% | 73% | 73% | 73%
Taylor, 1997 | 70% | 50% | 60% | 55% | 58% | 56% | 57%
Strik, 2000 | 85% | 83% | 84% | 84% | 84% | 84% | 84%
Glassman, 2002 | 95% | 88% | 91% | 89% | 90% | 90% | 90%

Representativeness: Percentage score was based on a total maximum score of 10 points. This included assessment of how well the study described the study setting and population (2 points), inclusion/exclusion criteria (2 points), non participating patients (2 points), patient characteristics at enrollment (2 patients), and whether the study used a consecutive series or randomly selected sample (2 patients).

Bias and Confounding: Percentage score was based on a total maximum score of 6 points. This included assessment of whether patients were randomly assigned to study groups (2 points), wether patient groups had important differences in patient characteristics (2 points), and whether there was blinding of test interpretation (2 patients)

Description of Therapy: Percentage score was based on a total maximum score of 10 points. This included assessment of how well the study described details of the cardiac therapy given (2 points), whether the study described details of the psychiatric treatment given (2 points), whether there was adequate description of other treatments given (2 points), whether description of the flow of participants was adequate (2 points), and whether assessment of adherence to therapy was given.

Description of Assessment: Percentage score was based on a total maximum score of 4 points. This included assessment of the description of methods used for initial diagnosis of depression (2 points), and the description of the interpretation criteria for a diagnosis of depression (2 points).

Outcomes and Follow up: Percentage score was based on a total maximum score of 12 points. This included assessment of whether the study reported numbers or reasons for withdrawals or those lost to follow up (2 points), the percentage of patients withdrawn or lost to follow up (2 points), whether cardiac outcome measures were defined (2 points), whether depression outcome measures were defined (2 points), whether the same tools for diagnosing depression were used for baseline and follow up (2 points), whether the length of follow-up was planned (2 points).

Statistical Analyses: Percentage score was based on a total maximum score of 8 points. This included assessment of whether statistical tests were clearly identified (2 points), whether loss to follow up was handled appropriately (2 points), whether adjustment was made for confounding (2 points), and whether confidence intervals were reported (2 patients).

Conflict of Interest: Percentage score was based on a total maximum score of 2 points. This involved determination of whether the study identified the sources of funding and involvement of the funding agency.

Evidence Table 4.4. Results of Studies on Treatment of Post Myocardial Infarction Depression (Question 4)

Study Author, Year | Random^a^ | Meds SSRI^b^ | Psychotherapy | Cardiac Rehabilitation | Duration of Intervention | Duration of FU^c^ | Drop-Out Rate | Depression Scores | Cumulative Cardiac Events | Other Outcomes
Dracup, 1991 | NA^d^ | NA | NA | A: Cardiac Rehabilitation Program; B: No participation to a formal program | 12 wks^e^ | 6 mos^f^ | NR^g^ | Multiple Affective Adjective Checklist @ 6mos A: 8, B: 13 | NA | Multiple Affective Adjective Checklist
| | | | | | | | | | Anxiety
| | | | | | | | | | A: baseline 7, 6 mos 5; B: baseline 7, 6 mos 6;
| | | | | | | | | | Psychosocial adjustment to Illness
| | | | | | | | | | A: baseline 42, 6 mos 36; B: baseline 44; 6 mos 42;
| | | | | | | | | | Marital Adjustment
| | | | | | | | | | A: baseline 115, 6 mos 121; B: baseline 114; 6 mos 111
Brown, 1993 | 4 to 24 mos | NA | C: Cognitive Behavioral Therapy; D: Control | NA | C: 12 wkly 1-hr sessions; D: 12 wkly 1-hr sessions | C: 3, 9, 15mos; D: 3, 9, 15 mos | NR | SCL 90-R | NA | NA
| | | | | | | | C: pre 65.1, 3 mos 62.1, 15 mos 56.1; D: pre 71.2, 3 mos 62.3, 15 mos 63.3;
| | | | | | | | BDI
| | | | | | | | C: pre 12.1, 3 mos 6.9, 15 mos 5.6; D: pre 17.3, 3 mos 9.4, 15 mos 10.5;
| | | | | | | | MMPI-168
| | | | | | | | C: pre 74.1, 3 mos 68.1, 15 mos 67.5; D: pre 79.2, 3 mos 72.8, 15 mos 77.4
Crowe, 1996 | 6 wks | NA | NA | NA | NR | 1 yr^k^ | 18% | BDI | NA | NA
| | | | | | | | E: 3 d 4.1, 3 mos 3.3, 6 mos 2.6, 14 mos 3.2; F: 3 d 3.9, 3 mos 3.7; 6 mos 3.3, 14 mos 2.9;
Frasure-Smith, 1997 | NR | NA | NA | G: Intervention that involved a combination of emotional support, reassurance, education, practical advice & health resources. H: usual care | 1 yr | 12 mos | 6.5% | BDI | Cardiac Mortality | Total Mortality
| | | | | | | | G: baseline 8.1, 12 mos 6.9; H: baseline 8.4, 12 mos 7.6 | G: 4.8%; H: 3.4%; | G: 5.5%, H: 3.9%
| | | | | | | | | MI^l^
| | | | | | | | | G: 4.8%; H: 5%;
| | | | | | | | | Revascularization
| | | | | | | | | G: 13.4%; H: 14%
Taylor, 1997 | Day 3 or as soon as their medical condition stabilized | NA | NA | I: Nurse-managed, home-based system for coronary risk factor modification and stress management. J: Usual medical care | 1 yr | Upto 1 yr | I: 29%; J: 37% | Low levels depressed mood | Mortality | Low levels anxious mood
| | | | | | | | I: baseline 1.7, 12 mos 1.3; J: baseline 1.8, 12 mos 1.2; | I: 4%; J: 3% | I: baseline 1.9, 12 mos 1.4; J: baseline 1.5, 12 mos 1.5;
| | | | | | | | Moderate-high levels depressed mood | | Moderate-high levels anxious mood
| | | | | | | | I: baseline 6.1, 12 mos 1.4; J: baseline 5.7, 12 mos 1.5 | | I: baseline 6.1, 12 mos 2.6; J: baseline 5.9, 12 mos 2.7;
| | | | | | | | | | Low levels stress
| | | | | | | | | | I: baseline 2.0, 12 mos 1.7; J: baseline 2.0; 12 mos 1.8;
| | | | | | | | | | Moderate-high levels stress
| | | | | | | | | | I: baseline 6.4, 12 mos 2.8; J: baseline 6.7, 12 mos 3.7;
| | | | | | | | | | Low anger frequency
| | | | | | | | | | I: baseline 2.8, 12 mos 2.2; J: baseline 2.6, 12 mos 2.2;
| | | | | | | | | | Moderate-high anger frequency
| | | | | | | | | | I: baseline 5.6, 12 mos 3.1; J: baseline 5.6, 12 mos 3.0
Roose, 1998 | NS | K: Paroxetine 10–20mg/ day, L: Nortriptyline 25mg/ day | NA | NA | 2 wks | 6 wks | NR | Heart rate | NA | NA
| | | | | | | | K: baseline 10%, 6 wks 6%; L: baseline 11%, 6 wks 7%;
| | | | | | | | Standing pulse rate standing
| | | | | | | | K: baseline 11%, 6 wks 11%; L: baseline 14%, 6 wks 16%;
| | | | | | | | Supine pulse rate supine
| | | | | | | | K: baseline 10%, 6 wks 10%; L: baseline 12%, 6 wks 14%;
| | | | | | | | HRV SDNN
| | | | | | | | K: baseline 37%, 6 wks 27; L: baseline 19%, 6 wks 16%;
| | | | | | | | HRV pNN50
| | | | | | | | K: baseline 10%, 6 wks 4%; L: baseline 9%, 6 wks 7%
Johnston, 1999 | Within 72 hrs | NA | NA | M: Extended program involving additional sessions in the 2m after discharge. N: Inpatient cardiac rehabilitation program. O: Control | 6 wks | Up to 1 yr | NR | HADS | NA | HADS Anxiety
| | | | | | | | M: baseline 4.1, 12 mos 3; N: baseline 4.4, 12 mos 3.6; O: baseline 4.6, 12 mos 5.8 | | M: 1 mo 4.8, 12 mos 3; N: 1 mo 5, 12 mos 4.5; O: 1 mo 5; 12 mos 6
Strik, 2000 | 3 – 12 mos | A: Fluoxetine 20mg/ day; B: Placebo | NA | NA | Maximum 25 wks | Up to 1 yr | A: 33%; B: 19% | HAMD change @ 25 wks | NA | Chest Pain
| | | | | | | | Group P: 9.65(7.2), Group Q: 6.9(6.9) | | A: 5; B: 4
| | | | | | | | | | GI Complaints
| | | | | | | | | | A: 8; B: 6;
| | | | | | | | | | Agitation
| | | | | | | | | | A: 6; B: 3;
| | | | | | | | | | Other
| | | | | | | | | | A: 17; B: 12;
| | | | | | | | | | Rehospitalization
| | | | | | | | | | A: 1; B: 6
| | | | | | | | | | Decrease in ATVI
| | | | | | | | | | A: 8; B: 0;
| | | | | | | | | | QRS interval increase
| | | | | | | | | | A: 15;
| | | | | | | | | | QRS interval increase
| | | | | | | | | | B:9
McFarlane, 2001 | At discharge from MI | Sertraline 50mg daily, Placebo daily | NA | NA | 6 mos | 6 mos | 29% | NR | NA | SDNN(SEM) at 1.5 mos
| | | | | | | | | | A:119 (10), B:103 (7.9),
| | | | | | | | | | SDNN(SEM) at 5.5 mos
| | | | | | | | | | A: 121 (17), B: 86 (10)
| | | | | | | | | | RMSSD(SEM) at 1.5 mos
| | | | | | | | | | A: 28.8 (4,7), B: 26.7 (3);
| | | | | | | | | | RMSSD(SEM) at 5.5 mos
| | | | | | | | | | A: 30 (7.1), B: 23.7 (5.7);
| | | | | | | | | | LF/HF ratio at 1.5 mos
| | | | | | | | | | A: 1.34 (0.15), B: 1.62 (0.22)
Glassman, 2002 | 33.7 (9.9) days | A: Sertraline 50mg/d daily; B: Placebo daily | N/A | N/A | 149.5 for sertraline and 153.8 days for placebo group | 24 wks | A: 18%; B: 12% | CGI - 1 mean score | MI | Total Mortality
| | | | | | | | A: 2.57, B: 2.75; | A: 5, B: 7; | A: 2; B: 5;
| | | | | | | | HAM-D mean change in score at 6 mos | Congestive heart failure | Composite End-point
| | | | | | | | A: -8.4, B: -7.6 | A:5, B:7 | A: 32, B:41
| | | | | | | | | Angina
| | | | | | | | | A:26, B:30
Berkman, 2003 | Within 28 days | Sertraline 50mg/d | A: Usual care B: Cognitive behavioral therapy, Social problem solving, plus SSRI certain conditions | NA | 180 days | A: 18 mos; B: 18 mos | NR | BDI change (baseline- at 6 mos) | Cardiac Mortality | Total Mortality
| | | | | | | | A: -5.8(8.9), B -8.6(9.2) | A: 115 (9.3%); B: 96 (7.8%); | A: 172 (13.8%); B: 168 (13.6%);
| | | | | | | | HRSD change (baseline- at 6 mos) | MI (recurrent non-fatal) | Cardiovascular hospitalization
| | | | | | | | A: -8.4(7.7) B -10.1(7.8) | A: 170 (13.7%); B: 168 (13.6%), | A: 467 (37.6%); B: 442 (35.7%)
| | | | | | | | | Revascularization
| | | | | | | | | A: 230 (18.5%); B: 216 (17.4%)
Swenson, 2003 | A: 34 B: 34 | A: Sertraline 50mg/daily; B: Placebo daily | NA | NA | 24 wks | A: 18 mos; B: 18 mos | NR | HAMD score change at 16 wks | NR | SF-36 Mental component change score
| | | | | | | | A: -8.4(0.4) B:-7.6(0.4) | | A:17.4 B:15.2
| | | | | | | | BDI score change at 16 wks | | Physical component change score
| | | | | | | | A:-8.0(0.6) B:-7.3(0.6) | | A:10.6 B:10.1

a Time to randomization after myocardial infarction

b Medications selective serotonin reuptake inhibitor

c Follow-up

d Not applicable

e Weeks

f Months

g Not reported

h Symptom Checklist 90

i Beck Depression Inventory

j Minnesota Multiphase Personality Inventory

k Year

l Myocardial infarction

Evidence Table 5.1. Characteristics of Studies on Methods of Screening for Depression in Myocardial Infarction Patients (Question 5)

Study Author, Year | Study Design | Exclusion Criteria | Study Site | Recruitment Period | Study Objective | Number of Subjects | Mean Age | Males (%)
Davis, 1988 | Pro cohort a, single center | Age > 65; psychiatric treatment | Canada | NR^b^ | To identify optimal methods of detecting depression in medically ill subjects. | 52 | 51 | 90
Martin, 2000 | Cross-sectional, single center | Non-English speaking | Europe | NR | To determine the utility of HADS^c^ in acute MI^d^ patients by examination of the instrument's underlying factor structure. | 194 | 63.4 | 73
Wojciechowski, 2000 | Pro cohort, single center | Age < 18 or > 75; previous MI | Europe | May 1994 - Jan 1996 | To investigate whether or not depression and vital exhaustion are separate entities. | 143 | 57.8 | 81
Strik, 2001 | Cross-sectional, single center | Recurrent MI | Europe | May 1997 - Sep 1999 | To assess sensitivity and specificity of 3 self-report questionnaires and one observer rating scale as screening instruments for major and minor depression following first MI. | 206 | 59.9 | 76
Freedland, 2002 | Pro cohort | AMI^e^ post CABG^f^/invasive procedure; significant other medica/major psychiatric comorbidity; psychiatric medications/psychotherapy | USA | Oct 1996 - Oct 1999 | To evaluate the effects of a psychosocial intervention on cardiovascular morbidity and mortality in post-MI patients exhibiting depression and/or social isolation. | 2404 | 61 | 56
Martin, 2003 | Pro cohort, multi-center | NR | Europe | NR | To determine the factor structure of the HADS in a clinical population following MI and to determine change-sensitivity characteristics and psychometric reliability of the HADS in this patient group. | 335 | 67.4 | 67

a Prospective cohort

b Not reported

c Hospital Anxiety and Depression Scale

d Myocardial infarction

e Acute myocardial infarction

f Coronary artery bypass graft

Evidence Table 5.2. Assessment of Study Quality in Studies on Methods of Screening for Depression in Myocardial Infarction Patients (Question 5)

Study Author, Year | Representativeness | Bias and Confounding | Assessment of Therapy and Management | Description of Assessment Protocol | Test/Interpretation | Outcomes and Follow-Up | Statistical Analyses | Conflicts of Interest
Davis, 1988 | 46% | 50% | 0% | 58% | 33% | 50% | 25% | 0%
Wojciechowski, 2000 | 75% | 67% | 42% | 58% | 71% | 100% | 100% | 0%
Martin, 2003 | 71% | 0% | 8% | 100% | 33% | 75% | 100% | 0%
Martin, 2000 | 75% | 40% | 0% | 17% | 42% | 0% | 100% | 50%
Strik, 2001 | 83% | 40% | 0% | 67% | 50% | N/A | 100% | 0%
Freedland, 2002 | 100% | 60% | 0% | 50% | 17% | 100% | 50% | 100%

Representativeness: Percentage score was based on a total maximum score of 10 points. This included assessment of how well the study described the study setting and population (2 points), inclusion/exclusion criteria (2 points), non participating patients (2 points), patient characteristics at enrollment (2 patients), and whether the study used a consecutive series or randomly selected sample (2 patients).

Bias and Confounding: Percentage score was based on a total maximum score of 10 points. This included assessment of whether the decision to obtain the reference test was affected by results of the study instrument (2 points), whether there was blinding of test interpretation (2 patients), whether interpretation of the study test was performed by two or more independent observers (2 patients), whether interpretation of the reference test was performed by two or more independent observers (2 points), and whether the reference standard and study test were measured before interventions were started with knowledge of test results (2 points).

Description of Therapy: Percentage score was based on a total maximum score of 6 points. This included assessment of how well the study described details of the cardiac therapy given (2 points), whether the study described details of the psychiatric treatment given (2 points), and whether there was adequate description of other treatments given (2 points).

Description of Assessment: Percentage score was based on a total maximum score of 4 points. This included assessment of the description of methods used for initial diagnosis of depression (2 points), and the description of the interpretation criteria for a diagnosis of depression (2 points).

Test Interpretation: Percentage score was based on a total maximum score of 12 points. This included assessment of the description of interpretation criteria of the study test for depression (2 points) and of the reference test (2 points), whether individuals receiving the study test also received the reference test (2 points), whether a summary index of test performance and index of variability was reported for the study test (2 points), whether methods for calculating test reproducibility were described (2 patients), and whether authors described how indeterminate results were handled (2 patients).

Outcomes and Follow up: Percentage score was based on a total maximum score of 6 points. This included assessment of whether the study reported numbers or reasons for withdrawals or those lost to follow up (2 points), the percentage of patients withdrawn or lost to follow up (2 points), and whether the same tools for diagnosing depression were used for baseline and follow up (2 points).

Statistical Analyses: Percentage score was based on a total maximum score of 8 points. This included assessment of whether statistical tests were clearly identified (2 points), whether loss to follow up was handled appropriately (2 points), whether adjustment was made for confounding (2 points), and whether confidence intervals were reported (2 patients).

Conflict of Interest: Percentage score was based on a total maximum score of 2 points. This involved determination of whether the study identified the sources of funding and involvement of the funding agency.

Evidence Table 5.3. Results of Studies on Methods of Screening for Depression in Myocardial Infarction Patients (Question 5)

Study | Test | | Sensitivity | Specificity | Other
Davis, 1988 | #1 | SCID^a^ nurse & therapist interview | NR^b^ | NR | Concordance: 80.8%
| #2 | SCID nurse and BDl | NR | NR | Concordance: 13.5%
| #3 | Therapist interview and BDI | NR | NR | Concordance: 11.5%
Martin, 2000 | | HADS^d^ all items / including HADS Depression subscale | NR | NR | Internal consistency 0.82 for HADS, 0.72 for HADS-D;
| | | | | Exploratory factor analysis reported
Wojciechowski, 2000 | #1 | Zung^e^ / SCL-90-Dep^f^ | NR | NR | Pearson correlations:0.70; 0.76; 0.77; 0.75, at 1, 3, 6, 12 months after MI^g^
| #2 | Zung SDS / Maastricht Quest (vital exhaustion) | NR | NR | Pearson correlations: 0.79; 0.76; 0.78; 0.81, at 1, 3, 6, 12 months after MI
| #3 | SCL-90-Dep / Maastricht Quest (vital exhaustion) | NR | NR | Pearson correlations: 0.75; 0.83; 0.76; 0.76, at 1, 3, 6, 12 months after MI
Strik, 2001 | #1 | SCL-90 | 81.1% (for major and minor depression), 95.5% (for major depression only) | 83.5% (for major and minor depression), 74% (for major depression only) | PPV^h^:
| | | | | 40% (for major and minor depression), 36.8% (for major depression only);
| | | | | NPV^i^:
| | | | | 93.3% (for major and minor depression), 96.2% (for major depression only)
| #2 | BDI | 83.8% (for major and minor depression), 81.8% (for major depression only) | 71.7% (for major and minor depression), 78.7% (for major depression only) | PPV:
| | | | | 25.3% (for major and minor depression), 33.3% (for major depression only);
| | | | | NPV:
| | | | | 98.3% (for major and minor depression), 97.9% (for major depression only)
Strik, 2001 | #3 | HADS/HADS-Depression subscale | HADS 78.1% (for major and minor depression), 90% (for major depression only); | HADS 85% (for major and minor depression), 84.3% (for major depression only); | HADS PPV:
| | | HADS-D^j^ 75% (for major and minor depression), 85% (for major depression only) | HADS-D 77.6% (for major and minor depression), 74.8% (for major depression only) | 45.2% (for major and minor depression), 45.2% (for major depression only);
| | | | | HADS NPV:
| | | | | 99.3% (for major and minor depression), 99.3% (for major depression only);
| | | | | HADS-D PPV:
| | | | | 32.1% (for major and minor depression), 32.1% (for major depression only);
| | | | | HADS-D NPV:
| | | | | 98.4% (for major and minor depression), 98.4% (for major depression only)
| | | | | Note: There appears to be a misprint in original article tables listing PPV and NPV as equal for both major and major/minor depression, which does not reconcile with other statistical data presented.
| #4 | 17-item HAM-D^k^ | 76.3% (for major and minor depression), 86.4% (for major depression only) | 86.0% (for major and minor depression ), 92.2% (for major depression only) | PPV:
| | | | | 40.7% (for major and minor depression),
| | | | | NPV:
| | | | | 99.3% (for major and minor depression ), 98.2% (for major depression only)
Freedland, 2002 | | BDI / HAM-D | NR | NR | Pearson correlation = 0.64
Martin, 2003 | | HADS all items / including HADS Depression subscale | NR | NR | Internal consistency:
| | | | | 0.87 for HADS, 0.76 for HADS-D at 1 week;
| | | | | 0.88 for HADS, 0.80 for HADS-D at 6 weeks;
| | | | | 0.90 for HADS, 0.81 for HADS-D at 6 months;
| | | | | Confirmatory factor analysis reported

a Structured Clinical Interview for Diagnostic & Statistical Manual of Mental Disorders IV

b Not reported

c Beck Depression Inventory

d Hospital Anxiety and Depression Scale

e Zung Self Rating Depression Scale

f Symptom Check List 90

g Myocardial infarction

h Positive predictive value

i Negative predictive value

j Hospital Anxiety and Depression Scale - depression subscale

k Hamilton Rating Scale for Depression

Evidence Table 6.1. Characteristics of Studies on Relation of Depression to Use of Treatment in Patients after Hospitalization for Myocardial Infarction (Question 6)

Study | Study Design | Target Population | Exclusion criteria | Number of Study Sites | Study Site | Recruitment Period | Study Objective
Blumenthal,1982 | Pro cohort ^a^ | Only MI ^b^ patients (recent MI) | NR ^c^ | Single center | USA | NR | To determine whether baseline physiological and psychological factors determine drop-out from cardiac rehabilitation program.
Conn, 1991 | Retro cohort ^d^ | Only MI patients (MI in preceding 1–2 years) | Multiple MI; planned/received cardiac surgery; received daily assistance from paid health care worker; institutionalized; unable to participate in interview | Single center | USA | NR | To examine relationship between anxiety, depression, self-care and QOL ^e^ among older adult MI survivors.
Druss, 2000 | Retro cohort | Only MI patients (Medicare claims for MI) | Age < 65; transferred to/from other facility; terminal illness; DNR ^f^ order | Mutlicenter | USA | Feb 1994 - Jul 1995 | To assess whether having a comorbid mental disorder is associated with a lower likelihood of cardiac catheterization and/or revascularization after acute MI.
Ziegelstein, 2000 | Pro cohort | Only MI patients (acute MI) | Unable to interview due to being cognitive impairment/medically unstable; transferred to other facility; died < 48 hours post-MI | Single center | USA | NR | To determine whether depression affects adherence to recommendations intended to reduce the risk of cardiac events after an MI.
Romanelli, 2002 | Pro cohort | Only MI patients (acute MI) | Age < 65; major cognitive problems; unable to interview due to medical instability within first 5days post-MI; comorbid non-cardiac illness likely to cause death within the next 6months; transferred to another facility; died within first 48 hours post-MI | Single center | USA | NR | To determine the significance of post-MI depression in individuals aged 65 and older.
Bennet, 2003 | Pro cohort | First acute MI | Age > 75; prior MI; need for cardiac surgery | Single center | Europe | NR | To determine if affective and social-cognitive variables predict risk behavior for CHD ^g^ after MI.
Lauzon, 2003 | Pro cohort | Only MI patients (acute MI) | Non-English/non-French speaking; transferred from another hospital; physically incapable of responding to a questionnaire; unable to give informed consent | Mutlicenter, 10 | Canada | Dec 1996 - Nov 1998 | To measure the prevalence and prognostic impact of depressive symptoms after acute myocardial infarction.
Whitmarsh, 2003 | Pro cohort | Only MI patients (acute MI able to participate in cardiac rehabilitation) | NR | Single center | Europe | Oct 1999 - May 2000 | To identify psychological determinants of non-attendance at cardiac rehabilitation.
Steeds, 2004 | Pro cohort | Only MI patients (acute MI) | Age > 75; incapable of giving written; informed consent | Single center | Europe | 1999 - 2000 | To determine the prevalence of an elevated BDI ^h^ and to determine the relation between BDI score and prognosis in a UK population following MI.
Strik, 2004 | Pro cohort | Only MI patients (first MI) | Major psychiatric disorders other than affective disorder; cognitive dysfunction; non-Dutch speaking; lived more than 50km away from study center; comorbid life-threatening illness | Single center | Europe | NR | To evaluate prospectively cumulative 1 year incidence of major and minor depression in consecutive cohort of patients following first MI. Secondly to evaluate whether Major and minor depression, and depressive symptoms, predicted cardiac mortality and morbidity up to 3 years post MI.

a Prospective cohort

b Myocardial infarction

c Not reported

d Retrospective cohort study

e Quality of life

f Do not resuscitate

g Coronary heart disease

h Beck Depression Inventory

Evidence Table 6.2. Results of Studies of Relation of Depression to use of Treatment in Patients after Hospitalization for Myocardial Infarction (Question 6)

Study Author, Year | No. of Subjects | Mean Age | Male (%) | White (%) | HTN a (%) | DM b (%) | Smoking (%) | Lipid c (%) | Killip Class d (%) | Mean Ejection Fraction | History of Depression (%)
Blumenthal, 1982 | 35 | 54 | NR^e^ | NR | NR | NR | NR | NR | NR | NR | NR
Conn, 1991 | 94 | 74 | 50 | NR | NR | NR | NR | NR | NR | NR | NR
Druss, 2000 | 5365^f^; 08288^g^ | 76 | 52^f^; 46^g^ | 92^f^; 91^g^ | 42^f^; 41^g^ | 22^f^; 26^g^ | 23^f^; 15^g^ | NR | NR | EF > 55%: 14^f^, 14^g^; EF 40 – 54%: 29^f^, 29^g^; EF < 40%: 52^h^, 52^g^ | NR
Ziegelstein; 2000 | 35^i^; 169^j^; 31^k^; 173^l^ | 46^i^; 55^j^; 42^k^; 54^l^ | 46^i^; 59^j^; 52^k^; 58^l^ | NR | 71^i^; 62^j^; 71^k^; 63^l^ | 31^i^; 30^j^; 36^k^; 31^l^ | 31^i^; 27^j^; 29^k^; 27^l^ | 69^i^; 61^j^; 71^k^; 60^l^ | Class II: 31^i^, 37^j^, 32^k^, 35^l^; Class III: 32^i^, 37^j^, 32^k^, 35^l^; Class IV: 31^i^, 37^j^, 32^k^, 35^l^ | 37^i^; 23^j^; 23^k^; 25^l^ | 45^i^; 11^j^; 33^k^; 12^l^
Romanelli; 2002 | 35^h^; 118^m^ | 75^h^; 74^m^ | 57^h^; 55^m^ | 97^h^; 90^m^ | 71^h^; 70^m^ | 49^h^; 33^m^ | NR | 57^h^; 60^m^ | Class > I: 54^h^; 49^m^ | EF ≤ 35%: 50^h^; 33^m^ | NR
Bennet; 2003 | 37 | 62 | 73 | NR | NR | NR | NR | NR | NR | NR | NR
Lauzon; 2003 | 191^h^; 359^m^ | 60^h^; 60^m^ | 75^h^; 81^m^ | 94^h^; 97^m^ | 34^h^; 36^m^ | 16^h^; 16^m^ | 40^h^; 40^m^ | 35^h^; 39^m^ | Class I: 81^h^; 83^m^ | NR | NR
Whitmarsh; 2003 | 93 | 64 | 76 | 100 | NR | NR | 61 | NR | NR | NR | NR
Steeds; 2004 | 62^n^; 69^o^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Strik; 2004 | 63^h^; 143^m^ | 59 | 67^h^; 80^m^ | NR | NR | NR | 10^h^; 13^m^ | 35^h^; 29^m^ | NR | EF ≥ 50%: 56^h^; 70^m^ | 32^h^; 13^m^

a Hypertension

b Diabetes

c Hyperlipedemia

d Killip Class I – IV

e Not reported

f Mental disorders

g No mental disorders

h Depressed

i BDI >10

j BDI <10

k Major depression/dysthymia

l No major depression/dysthmia

m Not depressed

n BDI 12

o BDI < 12

Evidence Table 6.3. Assessment of Study Quality in Studies of Depression to Use of Treatment in Patients after Hospitalization for Myocardial Infarction (Question 6)

Author, Year | Representativeness of Study Population | Description of Therapy and Management | Description of Assessment Protocol | Outcomes and Follow-Up | Statistical Analyses | Bias and Confounding | Conflicts of Interest
Conn, 1991 | 90% | 17% | 100% | 71% | 0% | 0% | 100%
Druss, 2000 | 15% | 0% | 50% | 25% | 25% | 0% | 0%
Ziegelstein, 2000 | 85% | 9% | 50% | 50% | 84% | 100% | 50%
Strik, 2004 | 75% | 58% | 50% | 50% | 67% | 0% | 0%
Steeds, 2004 | 40% | 0% | 100% | 50% | 50% | 0% | 0%
Blumenthal, 1982 | 25% | 0% | 25% | 100% | 75% | 25% | 150%
Whitmarsh, 2003 | 60% | 0% | 88% | 17% | 50% | 25% | 0%
Romanelli, 2002 | 75% | 25% | 50% | 50% | 50% | 0% | 0%
Lauzon, 2003 | 65% | 33% | 100% | 100% | 33% | 0% | 100%

Representativeness: Percentage score was based on a total maximum score of 10 points. This included assessment of how well the study described the study setting and population (2 points), inclusion/exclusion criteria (2 points), non-participating patients (2 points), patient characteristics at enrollment (2 patients), and whether the study used a consecutive series or randomly selected sample (2 patients).

Bias and Confounding: Percentage score was based on a total maximum score of 10 points. This included assessment of whether the decision to obtain the reference test was affected by results of the study instrument (2 points), whether there was blinding of test interpretation (2 patients), whether interpretation of the study test was performed by two or more independent observers (2 patients), whether interpretation of the reference test was performed by two or more independent observers (2 points), and whether the reference standard and study test were measured before interventions were started with knowledge of test results (2 points).

Description of Therapy: Percentage score was based on a total maximum score of 6 points. This included assessment of how well the study described details of the cardiac therapy given (2 points), whether the study described details of the psychiatric treatment given (2 points), and whether there was adequate description of other treatments given (2 points).

Description of Assessment: Percentage score was based on a total maximum score of 4 points. This included assessment of the description of methods used for initial diagnosis of depression (2 points), and the description of the interpretation criteria for a diagnosis of depression (2 points).

Test Interpretation: Percentage score was based on a total maximum score of 12 points. This included assessment of the description of interpretation criteria of the study test for depression (2 points) and of the reference test (2 points), whether individuals receiving the study test also received the reference test (2 points), whether a summary index of test performance and index of variability was reported for the study test (2 points), whether methods for calculating test reproducibility were described (2 patients), and whether authors described how indeterminate results were handled (2 patients).

Outcomes and Follow-up: Percentage score was based on a total maximum score of 6 points. This included assessment of whether the study reported numbers or reasons for withdrawals or those lost to follow-up (2 points), the percentage of patients withdrawn or lost to follow-up (2 points), and whether the same tools for diagnosing depression were used for baseline and follow-up (2 points).

Statistical Analyses: Percentage score was based on a total maximum score of 8 points. This included assessment of whether statistical tests were clearly identified (2 points), whether loss to follow-up was handled appropriately (2 points), whether adjustment was made for confounding (2 points), and whether confidence intervals were reported (2 patients).

Conflict of Interest: Percentage score was based on a total maximum score of 2 points. This involved determination of whether the study identified the sources of funding and involvement of the funding agency.

Evidence Table 6.4. Results of Studies on the Relation of Depression to Use of Treatment after Hospitalization for Myocardial Infarction (Question 6)

Study Author, Year | Study Group | Diagnosis of MI | Method of Assessing Depression Used for Analysis | No. of Subjects | Follow-Up | Cardiac Cath ^a^ (%) | PTCA ^b^ (%) | CABG ^c^ (%) | Aspirin/Antiplatelet (%) | Beta Blockers (%)
Druss, 2000 | Major depression/affective | ICD-9 ^d^ | ICD-9 | 315 | 16 mos ^e^ | 33 ^f^ | 9 | 8 | NR | NR
| No mental disorders | | | 108288 | 16 mos | 44 ^f^ | 17 | 13 | NR | NR
Ziegelstein, 2000 | Major depression/dysthmia | Pain, EKG ^g^, CPK-MB ^h^ | SCID ^i^ BDI ^j^ > 10 | 31 | 4 mos | NR | NR | NR | NR | 72
| Not depressed | | | 173 | 4 mos | NR | NR | NR | NR | 88
Romanelli, 2002 | Depressed (BDI ≥ 10) | Pain, EKG, CPK-MB | SCID | 35 | 4 mos | NR | NR | NR | 86 | 74
| Not depressed | | | 118 | 4 mos | NR | NR | NR | 84 | 86
Lauzon, 2003 | Depressed | NR | BDI-10 | 191 | 30 d ^k^ | 57 | 32 | 7 | NR | NR
| Not depressed | NR | | 359 | 30 d | 47 | 25 | 8 | NR | NR
| Depressed | NR | BDI-10 | 191 | 1 yr ^l^ | 67 | 39 | 19 | 84 | 56
| Not depressed | NR | | 359 | 1 yr | 55 | 30 | 16 | 86 | 64
Steeds, 2004 | Depressed | Pain, EKG, CPK-MB | BDI-12 | 62 | 32 mos | NR | NR | NR | NR | 32
| Not depressed | | | 69 | 32 mos | NR | NR | NR | NR | 55
Strik, 2004 | Depressed/Minor depression | Pain, EKG, ASAT ^m^ | SCID | 63 | 1 yr | NR | 36 | NR | 81 ^f^ | 40
| Not depressed | | | 143 | 1 yr | NR | 36 | NR | 95 ^f^ | 40

a Cardiac catheterization

b Percutaneous transluminal coronary angioplasty

c Coronary artery bypass graft

d The International Statistical Classification of Diseases and Related Health Problems

e Months

f p < 0.001

g Electrocardiogram

h Creatine phosphokinase - muscle brain

i Structured Clinical Interview for Diagnostic & Statistical Manual of Mental Disorders IV

j Beck Depression Inventory

k Day

l Year

m Aspartate aminotransferase