# Appendix F. Grading the Strength of Evidence

Evidence Grade Table 1. Grading of the Quality of Evidence on the Prevalence of Depression After Myocardial Infarction (Questions 1 and 2)

Evidence Grade Table 1. Grading of the Quality of Evidence on the Prevalence of Depression After Myocardial Infarction (Questions 1 and 2)

| During Initial Hospitalization | One or More Months after Hospitalization
[underlined: Quantity of Evidence:]
Number of studies | 23 | 23
Total number of patients studied | 14,017 | 5,216
[underlined: Quality and Consistency of Evidence:]
Were study designs appropriate for determining prevalence? (yes = high quality; no = low quality) | No | No
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0
Did the studies have important inconsistency? (-1) | -1 | -1
Was there some (-1) or major (-2) uncertainty about the directness or extent to which the people, measures and outcomes are similar to those of interest? | 0 | -1
Were data imprecise or sparse? (-1) | 0 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0
Did the studies show strong evidence of association between depression and myocardial infarction? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) | Not Applicable | Not Applicable
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | Not Applicable | Not Applicable
What was median (and range) of estimated prevalence? | ~26% | ~21%*
| Range 2– 47% | Range 2.7– 47%
Overall quality grade (high, medium, low, very low) | Medium | Medium

* NOTE - Numbers based on data at 1–3 months (N=17)

Evidence grading scheme as described in: Grade Working Group. Grading quality of evidence and strength of recommendations. BMJ 2004; 328: 1490–7.

Evidence Grade Table 2. Grading of the Quality of Evidence on the Independent Association of Measures of Depression with Clinical Outcomes in Patients with Acute Myocardial Infarction (Question 3)

Evidence Grade Table 2. Grading of the Quality of Evidence on the Independent Association of Measures of Depression with Clinical Outcomes in Patients with Acute Myocardial Infarction (Question 3)

| Survival | Cardiac Events | Quality of Life
[underlined: Quantity of Evidence:]
Number of studies | 14 | 6 | 14
Total number of patients studied | 92958 | 116,697 | 3, 381
[underlined: Quality and Consistency of Evidence:]
Were study designs appropriate for determining the association between depression and outcomes? (yes = high quality; no = low quality) | Yes | Yes | Yes
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | -1
Did the studies have important inconsistency? (-1) | -1 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness or extent to which the people, measures and outcomes are similar to those of interest? | 0 | -1 | -1
Were data imprecise or sparse? (-1) | 0 | 0 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0
Did the studies show strong evidence of association between depression and outcomes? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) | +1 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | +1 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0
What was median (and range) of estimated association? | Not Applicable | Not Applicable | Not Applicable
Overall quality grade (high, medium, low, very low) | High | Medium | Very low
Importance of outcome (critical, important, or not important) | Critical | Important | Important

Evidence grading scheme as described in: Grade Working Group. Grading quality of evidence and strength of recommendations. BMJ 2004; 328: 1490–7.

Evidence Grade Table 3. Grading of the Quality of Evidence on the Independent Association of Measures of Depression with Surrogate Measures of Disease Severity in Patients with Acute Myocardial Infarction (Question 3a)

Evidence Grade Table 3. Grading of the Quality of Evidence on the Independent Association of Measures of Depression with Surrogate Measures of Disease Severity in Patients with Acute Myocardial Infarction (Question 3a)

| Heart Rate Variability | Beta-Thromboglobulin | Platelet Factor 4 | Soluble Intercellular Adhesion Molecule-1 | Interleukin-6 | C - Reactive Protein
[underlined: Quantity of Evidence:]
Number of studies | 1 | 1 | 1 | 1 | 1 | 1
Total number of patients studied | 804 | 24 | 24 | 481 | 481 | 481
[underlined: Quality and Consistency of Evidence:]
Were study designs appropriate for determining the association between depression and the surrogate measures? (yes = high quality; no = low quality) | Yes | Yes | Yes | Yes | Yes | Yes
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | -1 | -1 | -1 | -1 | -1
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Was there some (-1) or major(-2) uncertainty about the directness or extent to which the people, measures and outcomes are similar to those of interest? | 0 | 0 | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) | 0 | -1 | -1 | 0 | 0 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between depression and the surrogate measures? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0 | 0 | 0
What was median (and range) of estimated association? | Not Applicable | Not Applicable | Not Applicable | Not Applicable | Not Applicable | Not Applicable
Overall quality grade (high, medium, low, very low) | High | Low | Low | High | High | High
Importance of outcome (critical, important, or not important) | Important | Important | Important | Important | Important | Important

Evidence grading scheme as described in: Grade Working Group. Grading quality of evidence and strength of recommendations. BMJ 2004; 328: 1490–7.

Evidence Grade Table 4. Grading of the Quality of Evidence on the Efficacy of Depression Treatment for Myocardial Infarction Patients with Depression (Question 4)

Evidence Grade Table 4. Grading of the Quality of Evidence on the Efficacy of Depression Treatment for Myocardial Infarction Patients with Depression (Question 4)

| Medications | Psychosocial Interventions
[underlined: Quantity of Evidence:]
Number of studies | 5 | 7
Total number of patients studied | Active group: 490 | Active group: 2356
| Control group: 408 | Control group: 2361
[underlined: Quality and Consistency of Evidence:]
Were study designs randomized trials (high quality), non-randomized controlled trials (medium quality), or observational studies (low quality)? | 5 randomized controlled trials | 6 randomized controlled trials, 1 prospective cohort
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | -1
Did the studies have important inconsistency? (-1) | No | No
Was there some (-1) or major (-2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? | No | No
Were data imprecise or sparse? (-1) | -1 | -1
Did the studies have high probability of reporting bias? (-1) | No | No
Did the studies show strong evidence of association between treatment and outcomes? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) | No | No
Did the studies have evidence of a dose-response gradient? (+1) | No | No
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | No | No
What was median (and range) of estimated treatment effect? | Depression: unable to assess due to the different methods of assessing depression used, the different follow-up times and the different antidepressants evaluated. | Depression: difficult to assess due to the different methods of assessing depression used and the different follow-up times.
| Total mortality: unable to assess, as only one study reported results for total mortality (Relative Risk for death was 0.39 with 95% confidence intervals between 0.08 and 1.39 comparing sertraline to placebo). | Total Mortality (range) (follow-up from 12–18 months)
| | Intervention group:4–13.6%
| | Control group: 3–13.8%
Overall quality grade (high, medium, low, very low) | Medium | Low
Importance of outcome (critical, important, or not important) | Important | Important

Evidence grading scheme as described in: Grade Working Group. Grading quality of evidence and strength of recommendations. BMJ 2004; 328: 1490–7.

Evidence Grade Table 5. Grading of the Quality of Evidence on the Performance Characteristics of Methods Used to Screen for Depression After Myocardial Infarction (Question 5)

Evidence Grade Table 5. Grading of the Quality of Evidence on the Performance Characteristics of Methods Used to Screen for Depression After Myocardial Infarction (Question 5)

| BDI | HADS | SCL-90 Dep. | Zung | HAM-D
[underlined: Quantity of Evidence:]
Number of studies | 3 | 3 | 2 | 1 | 2
Total number of patients studied | 2,739 | 735 | 349 | 143 | 2,687
[underlined: Quality and Consistency of Evidence:]
Were study designs appropriate for determining the performance characteristics of the screening methods? (yes = high quality; no = low quality) | Yes | Yes | Yes | No | Yes
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | 0 | -1 | -2 | -1
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness or extent to which the people, measures and outcomes are similar to those of interest? | 0 | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) | -1 | 0 | -1 | -1 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the estimated validity and reliability? (+1) | +1 | 0 | 0 | 0 | +1
What was median (and range) of estimated sensitivity, specificity and reliability? | Sensitivity: MDD* .82 (1 study) | Sensitivity: MDD .90 (1 study) | Sensitivity: MDD .96 (1 study) | Sensitivity: No data | Sensitivity: MDD .86 (1 study)
| Specificity: MDD .79 (1 study) | Specificity: MDD .84 (1 study) | Specificity: MDD .74 (1 study) | Specificity: No data | Specificity: MDD .92 (1 study)
| Reliability: No data | Reliability: .88 (.82, .90) | Reliability: No Data | Reliability: No data | Reliability: No Data
Overall quality grade (high, medium, low, very low) | Low | Medium | Low | Very Low | Low

* Major depressive disorder

Evidence grading scheme as described in: Grade Working Group. Grading quality of evidence and strength of recommendations. BMJ 2004; 328: 1490–7.

Evidence Grade Table 6. Grading of the Quality of Evidence on Whether Use of Recommended Treatment for Patients with Acute Myocardial Infarction Differs For Those With and Without Depression (Question 6)

Evidence Grade Table 6. Grading of the Quality of Evidence on Whether Use of Recommended Treatment for Patients with Acute Myocardial Infarction Differs For Those With and Without Depression (Question 6)

| Cardiac Procedures | Lifestyle Interventions | Medications | Cardiac Rehabilitation
[underlined: Quantity of Evidence:]
Number of studies | 3 | 1 | 4 | 2
Total number of patients studied | 109359 | 108 | 1244 | 128
[underlined: Quality and Consistency of Evidence:]
Were study designs appropriate for determining the association between depression and use of treatment? (yes = high quality; no = low quality) | Yes | Yes | Yes | Yes
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | 0
Did the studies have important inconsistency? (-1) | -1 | 0 | -1 | 0
Was there some (-1) or major (-2) uncertainty about the directness or extent to which the people, measures and outcomes are similar to those of interest? | -1 | -1 | -1 | -1
Were data imprecise or sparse? (-1) | 0 | -1 | 0 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between depression and use of treatment? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0
What was median (and range) of estimated association? | Not Applicable | Not Applicable | Not Applicable | Not Applicable
Overall quality grade (high, medium, low, very low) | Low | Very low | Low | Low

Evidence grading scheme as described in: Grade Working Group. Grading quality of evidence and strength of recommendations. BMJ 2004; 328: 1490–7.