# Appendix E. Abstraction Forms

General Content Review Form

JOHNS HOPKINS EVIDENCE-BASED PRACTICE CENTER
POST MYOCARDIAL INFARCTION DEPRESSION
GENERAL FORM
Article ID: _______________________ | First Author: _______________________
Reviewer 1: ________________________ | Reviewer 2: ________________________

1. Exclude article from review because (Check one):

□ does not include human data

□ no original data

□ not in English

□ meeting abstract (no full article for review)

□ case report or case series (no denominator)

□ letter

□ published before 1980

□ no data reported on when MI occurred relative to when depression assessed

□ study population is mixed (i.e. cardiac and non-cardiac)

AND

□ patients with MI not reported separately

□ patients with MI not reported separately in study (e.g., CAD, MI and unstable angina)

AND

□ patients with MI represent < 50% of the sample

□ does not apply to any of the questions

□ other: (specify) ________________________________________________________

IF ANY OF THE ABOVE IS CHECKED, STOP! DO NOT CONTINUE

Return article and form.

2. Key Questions: (Check all that apply)

□ Q1. What is the prevalence of depression in patients diagnosed with and hospitalized for acute myocardial infarction (MI)? [depression assessed during initial hospitalization for MI]

□ Q1a. What is the prevalence of depression in patients diagnosed with and hospitalized for acute MI, with and without a history of previous depression as reported by study investigators?

□ Q2. What percentage of patients with post-MI depression continue to have depression (or depressive symptoms) one or more months after initial hospital discharge? [depression assessed one or more months after initial hospitalization and not during the initial hospitalization]

□ Q3. What is the association of post-MI depression with outcomes independent of other predictors of post-MI outcomes? [must include at least one of the following outcomes: death, MI, rehospitalization, revascularization, arrhythmias, utilization, quality of life, disability and adherence]

□ Q3a.What is the association of post-MI depression with surrogate markers of cardiac risk independent of other predictors of post-MI outcomes? [must include at least one of the following surrogate markers: heart rate variability, platelet reactivity, C-reactive protein or other markers of inflammation]

□ Q4. Do post-MI patients with depression have better outcomes with depression treatment compared to those without depression treatment?

□ If the study does not involve a concurrent comparison, check this box as not eligible for Q4.

□ Q4a. Do outcomes differ with or without improvement in depression for post-MI patients with depression that do receive depression treatment?

□ Q4b. Do outcomes differ with or without improvement in depression for post-MI patients with depression that do not receive depression treatment?

□ Q5. What are the performance characteristics (e.g., sensitivity, specificity, reliability, and predictive value) of instruments or methods that are used to screen for depression (or depressive symptoms) following an acute MI?

□ If the study does not use a validated reference standard, check this box as not eligible for Q5.

□ If the study does not use quantitative methods to assess depression, check this box as not eligible for Q5.

□ Q5a. During hospitalization?

□ Q5b. Within 3 months after hospitalization?

□ Q6. Does the use of cardiac treatment for patients with acute MI differ for those with and without depression?

□ None of the above. If this is checked, STOP HERE. Return article and forms

ASSESSMENT OF STUDY DESIGN AND QUALITY

3. Study design

□ case control study

□ nested case control study

□ cross-sectional study

□ retrospective cohort study

□ prospective cohort study

□ randomized clinical trial

□ other (specify): ___________________________________________________________

CHARACTERISTICS OF STUDY

4. Provide a brief statement of the main aims beginning with “To ...”

___________________________________________________________________________

___________________________________________________________________________

5. Source of funding (check all that apply):

□ University

□ Pharmaceutical company

□ Government

□ Private

□ No funding

□ Not reported

□ Other (specify): __________________________________________________________

6. In what geographical area was the study mainly performed (check all that apply)?

□ North America (USA)

□ North America (Canada)

□ South or Central America

□ Europe

□ Asia

□ Africa

□ Australia

7. Was this a multicenter study?

□ Yes. Number of centers, if known _________________________________________

□ No

□ Unclear

8. Data comes from patients diagnosed with MI between which years (mo/yr)

Start: ______/_________

Mo. Yr.

End: ______/__________

Mo. Yr.

□ Not applicable

9. Does this study include patients with acute coronary syndromes other than acute MI?

□ Yes

□ No

If yes:

a. How many patients had an acute coronary syndrome?____________________
b. What percentage of these patients had an acute MI? _____________________
c. Was the data for acute MI reported separately?
  □ Yes
  □ No

This item DOES NOT apply to Q1, Q2 & Q5

10. Does this study include patients with mental disorders other than depression?

□ Yes

□ No

If yes:

a. How many patients were diagnosed with mental disorders? _______________
b. What percentage of these patients had depression or affective disorder? _____
c. Was the data for depression or affective disorder reported separately?
  □ Yes
  □ No

11. Study inclusion and exclusion criteria

NOTE: Record in terms of exclusions if possible

| Not Applicable | Inclusion | Exclusion | Range
Age | □ | □ | □ | _________________________
Gender | □ | □ | □ | _________________________
Race | □ | □ | □ | _________________________
Education | □ | □ | □ | _________________________
Marital status | □ | □ | □ | _________________________
Occupation | □ | □ | □ | _________________________
Cardiac surgery anticipated | □ | □ | □ | _________________________
Index ACS developed after CABG | □ | □ | □ | _________________________
Significant bradycardia | □ | □ | □ | _________________________
MI of non-atherosclerotic etiology | □ | □ | □ | _________________________
Killip class | □ | □ | □ | _________________________
Uncontrolled hypertension | □ | □ | □ | _________________________
Persistent clinically significant abnormalities | □ | □ | □ | _________________________
Renal dysfunction | □ | □ | □ | _________________________
Hepatic dysfunction | □ | □ | □ | _________________________
Other significant nonreactive disease | □ | □ | □ | _________________________
Women of childbearing potential not using adequate contraception | □ | □ | □ | _________________________
Alcohol or substance abuse | □ | □ | □ | _________________________
Psychotic symptoms | □ | □ | □ | _________________________
History of psychosis, bipolar disorder, organic brain syndrome or dementia | □ | □ | □ | _________________________
Significant suicide risk | □ | □ | □ | _________________________
Terminally ill | □ | □ | □ | _________________________
Serious comorbidities | □ | □ | □ | _________________________
Cognitive impairment | □ | □ | □ | _________________________
Non-English speaking | □ | □ | □ | _________________________
Other:_________________ | □ | □ | □ | _________________________
_______________________ | □ | □ | □ | _________________________
_______________________ | □ | □ | □ | _________________________
_______________________ | □ | □ | □ | _________________________
_______________________ | □ | □ | □ | _________________________

12. Criteria for diagnosis of myocardial infarction: (Check all that apply)

□ In hospital assessment:

□ Chest pain

□ Electrocardiogram

□ Creatine kinase

□ Troponin

□ Other cardiac enzymes

□ Other (specify): ___________________________________________________

□ Physician report (e.g., as documented in medical record)

□ Patient self report

□ Radionuclide (e.g. thallium) study

□ Other (specify): _____________________________________________________

Depression measurement:

13. Was a validated questionnaire used to assess depression? (Check at least one)

□ Beck Depression Inventory (BDI)

□ Hamilton Rated Scale for Depression (HAM - D)

□ Zung Self-Assessment Depression Scale

□ General Health Questionnaire (GHQ)

□ Center for Epidemiologic Study Depression Scale (CES-D)

□ Hospital Anxiety and Depression Scale (HADS)

□ Geriatric Depression Scale

□ Symptom Check List 90 (SCL-90)

□ Clinical Global Impression (CGI-1)

□ Other (specify): __________________________________________________

□ No validated questionnaire

14. Was a standardized psychiatric interview used to assess depression? (Check at least one)

□ Diagnostic Interview Schedule (DIS)

□ Depression Interview and Structured Hamilton (DISH)

□ Structured Clinical Interview for DSM-IV (SCID)

□ Semi-structured Clinical Interview for DSM-IV (SCID)

□ Other (specify): __________________________________________________

□ No standardized psychiatric interview

15. Was a clinical interview by a mental health professional (DSM III, III-R, IV criteria) used to assess depression? (Check at least one)

□ Yes

□ No

16. Was another method used to assess depression? (Check at least one)

□ Review of medical records

□ Other (specify): _________________________________________________

□ Not stated

□ None

17. Provide a description for each group in reference to acute MI, depression and other key characteristics (e.g. A: Acute MI depression, B: Acute MI without depression).

Group | Description
| Acute MI | Depression | Other
A | yes | yes
| no:_________________ | no:_________________
B | yes | Yes
| no:_________________ | no:_________________
C | Yes | yes
| no:_________________ | no:_________________
D | yes | Yes
| no:_________________ | no:_________________

Comments:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

18. Description of subjects [use % except for total number and age]

| Group A | Group B | Group C | Group D
Total number (N)
Age (mean +/- SD)
(Median and range)
Gender, male %
Race/ethnicity:
Caucasian, %
Non-Caucasian, %
African American, %
Asian American, %
Hispanic American, %
Other, ____________%
Marital status, married, %
Discharged home, %
Education high school or higher, %
Employed full/part time, %
Cardiac risk factors:
Hypertension
Diabetes mellitus
Smoking
Hyperlipidemia
Obesity
Prior cardiac disease (___________________)
Previous angina
Previous MI
Previous heart failure
Peripheral vascular disease
Sedentary lifestyle
Features of MI:
Killip Class
Class I, %
Class II, %
Class III, %
Class IV, %
Other _______________
Ejection fraction,
mean +/- SD
Other______________
Maximum creatine kinase
mean +/- SD
Other_________________
Pre-discharge exercise test result in METS, mean
Received revascularization, %
History of depression
Family history of depression
Received thrombolytics, %
Other:_______________
_____________________
_____________________
_____________________

Quality Assessment Form

JOHNS HOPKINS EVIDENCE-BASED PRACTICE CENTER
POST MYOCARDIAL INFARCTION DEPRESSION
QUALITY ASSESSMENT FORM
Article ID: _________________________ | First Author: _______________________
Reviewer 1: ________________________ | Reviewer 2: ________________________

REPRESENTATIVENESS OF STUDY POPULATION

1. Did the study describe the setting and population from which the study sample was drawn, and the dates of the study?

a. Adequate (setting AND population described AND start and end date specified) | 2
b. Fair (setting AND population described but NOT start and end date) | 1
c. Inadequate (not specified) | 0

2. Were detailed inclusion/exclusion criteria provided?

a. Adequate (detailed description of specific inclusion and exclusion criteria OR statement that all eligible patients enrolled) | 2
b. Fair (some description, but would be difficult to replicate based on information provided) | 1
c. Inadequate (minimal description or not at all) | 0

3. Was information provided on excluded or non-participating patients?

a. Adequate (all reasons for exclusion AND number excluded OR no exclusion) | 2
b. Fair (only one of above criteria specified or information not sufficient to allow replication) | 1
c. Inadequate (none of the above criteria specified) | 0

4. Does the study describe key patient characteristics at enrollment?

Demographics: age, gender, race/ethnicity, education, marital status, occupation

Medical characteristics: current smoking, Body Mass Index (BMI), diabetes, hypertension, hypercholesterolemia, cerebrovascular disease, peripheral vascular disease, renal insufficiency, cardiac medications, antidepressants

Depression Features: depression measured by validated questionnaire, standardized psychiatric interview, clinical interview by mental health professional, and review of medical records; first episode of depression; recurrent depression; prior episodes of major depression; prior psychotropic treatment

Cardiac Features: cardiac event leading to current hospitalization, left ventricular ejection fraction (LVEF in %), previous MI, previous CABG surgery, previous PTCA, history of congestive heart failure, Killip class, peak CPK

a. Good: 4 of 4 categories described well (i.e., most items in each category described) | 2
b. Fair: 2 or 3 categories described well | 1
c. Poor: 0 or 1 categories described | 0

5. Did the study include a consecutive series of individuals presenting with the relevant symptoms or a randomly selected sample?

a. Consecutive series | 2
b. Random sample | 2
c. Other | 1
d. Unclear | 0

6. What was recruitment based on?

[THIS ITEM APPLIES TO Q5 ONLY]

a. Predetermined diagnostic criteria | 2
b. Previous testing with the index test/instrument or the reference standard used in the study | 1
c. Unclear | 0
d. Not applicable | N/A

BIAS AND CONFOUNDING

7. Was assignment of patients to study group randomized?

[THIS ITEM APPLIES TO Q4 ONLY]

a. Adequate (investigators could not predict assignment) | 2
b. Partial (date of birth, admission date, hospital record number, or other nonrandom scheme for assignment OR did not state) | 1
c. Not randomized | 0
d. Unclear | 0
e. Not applicable | N/A

8. Did the patient groups have any important differences in key patient characteristics?

[THIS ITEM APPLIES TO Q4 ONLY]

Demographics: age, gender, race/ethnicity, education, marital status, occupation, days from index MI to first day of therapy

Medical characteristics: current smoking, Body Mass Index (BMI) kg/m2, diabetes, hypertension, hypercholesterolemia, cerebrovascular disease, peripheral vascular disease, renal insufficiency, cardiac medications, antidepressants

Depression Features: depression measured by instruments such as HAM -D, CGI-1or Beck Depression Inventory; first episode of depression; recurrent depression; prior episodes of major depression; prior psychotropic treatment

Cardiac Features: cardiac event leading to current hospitalization, left ventricular ejection fraction (LVEF in %), previous MI, previous CABG surgery, previous PTCA, history of congestive heart failure, Killip class, peak CPK

a. Groups equivalent in all factors examined | 2
b. Groups have minor difference in 1 or 2 factors | 1.5
c. Groups have an important difference in one or more factors OR minor difference in more than two factors | 1
d. Analysis not done | 0
e. Not applicable | N/A

9. Was the decision to obtain the reference test affected in any way by the results of the study test/instrument, or vice versa?

[THIS ITEM APPLIES TO Q5 ONLY]

[Note: we want to understand the extent to which testing decisions were independent of each other. There are two ways for testing not to be independent:

1. The decision to perform the 2^nd^ test can be dependent on the results of the 1^st^ test
2. The decision to include a patient in the study can be based on a referral for testing]

a. Decision to test was NOT affected by either (1) above OR (2) above | 2
b. Decision to test was affected by either (1) above OR (2) above | 0
c. Unclear | 0
d. Not applicable | N/A

10. Was there blinding of study test interpretation, reference test interpretation, and clinical data?

[THIS ITEM APPLIES TO Q5 ONLY]

[Note: This question concerns blinding: not independence of interpretations]

a. Excellent (ALL 3 blinded, including both test interpretations with each other) | 2
b. Good (test interpretations blinded to each other but not to clinical data) | 1
c. Fair (test interpretations blinded to clinical data but not to each other) | 0.5
d. Poor (no blinding OR not stated) | 0
e. Not applicable | N/A

11. Was interpretation of the study test performed by two or more independent observers?

[THIS ITEM APPLIES TO Q5 ONLY]

a. Adequate (multiple observers AND independent) | 2
b. Fair (multiple observers but NOT independent) | 1
c. Inadequate (Neither OR not stated) | 0
d. Not applicable (e.g., if using self rating or test doesn't require interpretation) | N/A

12. Was interpretation of the reference test performed by two or more independent observers?

[THIS ITEM APPLIES TO Q5 ONLY]

a. Adequate (multiple observers AND independent) | 2
b. Fair (multiple observers but NOT independent) | 1
c. Inadequate (Neither OR not stated) | 0
d. Not applicable (e.g., if using self rating or test doesn't require interpretation) | N/A

13. Were the reference standard and the index test measured before any interventions were started with knowledge of test results?

[THIS ITEM APPLIES TO Q5 ONLY]

a. Yes | 2
b. No | 0
c. Unclear | 0
d. Not applicable | N/A

14. If the study was a controlled clinical trial, was there blinding of clinicians, patients, and outcome assessors?

[THIS ITEM APPLIES TO Q4 ONLY]

a. Excellent (All three blinded, including all treatment arms) | 2
b. Good (Only 2 of the 3 blinded, or some but not all of the arms) | 1.5
c. Fair (Only 1 of the 3 blinded) | 1
d. Poor (No blinding or not stated) | 0
e. Not applicable | N/A

DESCRIPTION OF THERAPY/MANAGEMENT

15. How well did the study describe details of the cardiac therapy regimen given for the MI?

(e.g., types of procedures, types of medications, dose intensity, duration of therapy)

a. Adequate - detailed enough that it could be replicated | 2
b. Fair - one or two key features not described | 1
c. Inadequate - not described | 0
d. Not applicable | N/A

16. Did the study describe details of the psychiatric treatment given for post-MI depression?

a. Adequate (treatment fully described) | 2
b. Fair (some description, but information not sufficient to allow replication) | 1
c. Inadequate (not described) | 0
d. Not applicable | N/A

17. How was the description of other medical or psychiatric treatments given study subjects while they were in the study? (e.g., other medications or procedures, psychiatric medications other than study drug, psychiatric therapy other than therapy being studied)

a. Adequate (other treatment fully described) | 2
b. Fair (some description, but information not sufficient to allow replication) | 1
c. Inadequate (not described) | 0
d. Not applicable | N/A

18. How did the study describe details of the flow of participants through each stage? For each group the number of participants randomly assigned, receiving intended treatment, completing the study protocol and analyzed for the primary outcome.

[THIS ITEM APPLIES TO Q4 ONLY]

a. Adequate | 2
b. Fair (one of the above NOT described) | 1
c. Inadequate (more than one of above NOT described) | 0

19. How was the assessment of adherence to the therapy of interest?

[THIS ITEM APPLIES TO Q4 ONLY]

a. Adequate (strong methods AND results of assessment reported in detail) | 2
b. Fair (weak methods such as self-report OR results of assessment not reported in detail but NOT both) | 1
c. Inadequate (neither reported) | 0
d. Not appliacable | N/A

DESCRIPTION OF THE ASSESSMENT PROTOCOLS

20. Was data collection planned before the index test/instrument and reference standard were performed (prospective study)?

[THIS ITEM APPLIES TO Q5 ONLY]

a. Yes | 2
b. No | 1
c. Unclear | 0

21. Did the study describe details of the methods used for the initial diagnosis of depression?

[THIS ITEM DOES NOT APPLY TO Q5]

a. Adequate (used a validated questionnaire or standardized interview process OR enough description to replicate) | 2
b. Fair (not a validated questionnaire or standardized interview process OR enough description to replicate) | 1
c. Inadequate (no description) | 0

22. Was the interpretation criteria for a positive diagnosis of depression described?

[THIS ITEM DOES NOT APPLY TO Q5]

a. Adequate (enough description to replicate) | 2
b. Fair (some description, but not enough to replicate) | 1
c. Inadequate (no description) | 0

23 Did the study describe details of the reference standard used to assess the study test/instrument protocol?

[THIS ITEM APPLIES TO Q5 ONLY]

a. Adequate (enough description to replicate) | 2
b. Fair (some description, but not enough to replicate) | 1
c. Inadequate (no description) | 0
d. Not applicable | N/A

24. Did the study report the time interval between performance of the index test/instrument and the reference standard?

[THIS ITEM APPLIES TO Q5 ONLY]

a. Yes AND it was within 1 day | 2
b. Yes AND it was more than 1 day but less than 1 week | 1
c. Yes AND it was 1 week or more | 0
d. Unclear | 0
e. Not applicable | N/A

TEST/INSTRUMENT INTERPRETATION

25. Were the interpretation criteria of a positive depression test/instrument described for the study test?

[THIS ITEM APPLIES TO Q5 ONLY]

a. Adequate (enough description to replicate) | 2
b. Fair (some description, but not enough to replicate) | 1
c. Inadequate (no description) | 0
d. Not applicable | N/A

26. Did all individuals receiving the study test/instrument also receive the reference test?

[THIS ITEM APPLIES TO Q5 ONLY]

a. All (all received BOTH tests) | 2
b. Some (some received both tests) | 1
c. None (no one received both tests) | 0
d. Unclear | 0
e. Not applicable | N/A

27. Were the interpretation criteria of a positive depression test/instrument described for the reference test?

[THIS ITEM APPLIES TO Q5 ONLY]

a. Adequate (enough description to replicate) | 2
b. Fair (some description, but not enough to replicate) | 1
c. Inadequate (no description) | 0
d. Not applicable | N/A

28. Was a summary index of test performance (e.g., sensitivity/specificity, area under ROC curve) reported for the study test AND an indicator of variability (standard error, confidence interval)?

[THIS ITEM APPLIES TO Q5 ONLY]

a. Adequate (both reported) | 2
b. Fair (test performance but no index of variability) | 1
c. Inadequate (no information given) | 0
d. Not applicable | N/A

29. Were methods for calculating test reproducibility described?

[THIS ITEM APPLIES TO Q5 ONLY]

a. Adequate (enough description to replicate) | 2
b. Fair (some description, but not enough to replicate) | 1
c. Inadequate (no description) | 0
d. Not applicable | N/A

30. Did the authors describe how indeterminate results, missing responses and outliers of the index test/instrument and the reference test were handled?

[THIS ITEM APPLIES TO Q5 ONLY]

a. Adequate (enough description to replicate) | 2
b. Fair (some description, but not enough to replicate) | 1
c. Inadequate (no description) | 0
d. Not applicable | N/A

OUTCOMES AND FOLLOW-UP

31. Did the study report the numbers or reasons for withdrawals from the study protocol or patients otherwise lost to follow-up?

a. Adequate (both numbers AND reasons reported, OR no withdrawals) | 2
b. Fair (only numbers OR reasons reported) | 1
c. Inadequate (neither given) | 0
d. Not applicable (no longitudinal follow-up was performed) | N/A

32. What was the percentage of patients that withdrew from the study protocol or were lost to follow-up?

[THIS ITEM APPLIES TO Q2, Q3, Q4 AND Q6 ONLY]

a. None | 2
b. < 10% | 1.5
c. 10 – 20% | 1
d. > 20% | 0
e. Not stated | 0
f. Not applicable (no follow-up) | N/A

33. How did the investigators determine whether the patients received cardiac treatment?

[THIS ITEM APPLIES TO Q6 ONLY]

a. Adequate (clear definitions of type of treatment AND exact techniques to assess whether treatments received) | 2
b. Fair (some description, but information not sufficient to allow replication) | 1
c. Inadequate (no information provided) | 0
d. Not applicable | N/A

34. How were cardiac heart disease outcome measures defined? (e.g., left ventricular ejection fraction (%), heart rate variability, blood pressure, standard ECG, runs of ventricular premature contractions, occurrence of cardiovascular events - myocardial infarction, stroke, severe angina, congestive heart failure, death)

[THIS ITEM APPLIES TO Q3 & Q4 ONLY]

a. Adequate (clear definitions of each outcome AND exact techniques to assess the outcome) | 2
b. Fair (some description, but information not sufficient to allow replication) | 1
c. Inadequate (no information provided) | 0
d. Not applicable (cardiac outcomes not measured OR no intervention) | N/A

35. How were depression outcome measures defined? (e.g., instruments such as Hamilton Rated Scale for Depression (HAM -D) and Beck Depression Inventory (BDI) scores, validated questionnaires, standardized psychiatric interview, clinical interview by mental health professional (DSM III or IV))

[THIS ITEM APPLIES TO Q3 & Q4 ONLY]

a. Adequate (clear definitions of each outcome measure AND exact techniques to assess the outcome) | 2
b. Fair (some description, but information not sufficient to allow replication) | 1
c. Inadequate (no information provided) | 0
d. Not applicable (no intervention) | NA

36. Were the same tools for diagnosing depression and the mode of administration used for baseline and follow up?

a. Adequate (tool AND method of administration are same) | 2
b. Fair (same tool but different mode of administration) | 1
c. Inadequate (different tool) | 0
d. Not applicable (e.g., no follow-up assessment of depression) | N/A

37. Did the study assess and report adverse effects experienced by patients?

[THIS ITEM APPLIES TO Q4 ONLY]

a. Adequate (cardiovascular adverse events AND at least one non-cardiovascular adverse effect assessed and reported) | 2
b. Fair (only cardiovascular events mentioned OR non-cardiovascular adverse effects mentioned, but NOT fully assessed and reported) | 1
c. Inadequate (cardiovascular adverse events NOT mentioned) | 0
d. Not applicable (no intervention) | N/A

38. What was the planned length of follow-up since initiation of treatment?

[THIS ITEM APPLIES TO Q3, Q4 AND Q6 ONLY]

a. >= 1 year | 2
b. 6 – 11 months | 1.5
c. 3 – 5 months | 1
d. < 3 months | 0
e. Not stated | 0
f. Not applicable (no follow-up) | N/A

STATISTICAL ANALYSIS

39. Was the statistical test of all analyses clearly identified?

a. Adequate (identified for all analyses) | 2
b. Fair (identified for some of the analyses) | 1
c. Inadequate (not identified) | 0
d. Not applicable (no statistical tests needed) | N/A

40. Was loss to follow-up handled appropriately in the analysis?

[THIS ITEM APPLIES TO Q2, Q3, Q4 &Q6 ONLY]

a. No loss to follow-up | 2
b. By intention to treat (or by original group assignment) | 2
c. Sensitivity analysis | 1
d. None of the above | 0
e. Not applicable (no follow-up) | N/A

41. For primary endpoints of the evaluation, does the study report the magnitude of difference between groups OR magnitude of the association between outcomes and patient characteristics AND an index of variability - including pre-post testing (e.g., test statistic, p value, standard error, confidence interval) ?

[THIS ITEM APPLIES TO Q3, Q4 & Q6]

a. Adequate (BOTH reported with index of variability using standard error or confidence intervals) | 2
b. Fair (BOTH reported with index of variability using only test statistic or p value) | 1
c. Inadequate (one OR both not reported) | 0
d. No comparisons (descriptive analysis only) | 0
e. Qualitative analysis only | N/A
f. Not applicable (e.g., no comparison group) | N/A

42. Was adequate adjustment made for confounding in the analysis from which the main findings were drawn?

a. Adequate (adjusted for all potential confounding factors that differed between groups) | 2
b. Fair (adjusted for some but not all potential confounding factors) | 1
c. Inadequate (did not adjust for confounding factors or unclear whether potential confounding factors differed between groups) | 0
d. Not applicable (e.g., groups did not differ in important patient characteristics) | N/A

43. Was the prevalence of depression reported using a 95% confidence interval?

[THIS ITEM APPLIES TO Q1 & Q2 ONLY]

a. Yes | 2
b. No | 0
c. Not applicable | N/A

CONFLICTS OF INTEREST

44. Did the study report identify the sources of funding and the type and degree of involvement of the funding agency?

a. Adequate (source AND type or degree of involvement OR no funding) | 2
b. Fair (source only) | 1
c. Inadequate (neither) | 0

Question 1 and 2 Form

JOHNS HOPKINS EVIDENCE-BASED PRACTICE CENTER
POST MYOCARDIAL INFARCTION DEPRESSION
QUESTION 1 & 2 FORM
Article ID: _______________________ | First Author: _______________________
Reviewer 1: ______________________ | Reviewer 2: ________________________

CHARACTERISTICS OF STUDY

1. Criteria used for diagnosis of depression:

For baseline assessment (during hospitalization for MI)

□ standard

□ modified (e.g., duration or impairment)

□ not applicable

For follow-up/ assessment (after hospitalization for MI)

□ standard

□ modified (e.g., duration or impairment)

□ not applicable

2. Timing of the depression measurement (check all that apply):

□ during hospitalization, NOS

□ within first two days

□ 3 – 13 days after MI

□ 2 – 4 weeks after MI

□ 1 – 5 months after MI

□ 6 – 11 months after MI

□ 1 – 2 years after MI

□ > 2 years after MI

□ other: specify _____________________________________________________

□ unclear

3. Minimum duration of symptoms to meet criteria:

At baseline

□ <2 weeks

□ =2 weeks

□ >2 weeks

□ not specified

At follow-up

□ <2 weeks

□ =2 weeks

□ >2 weeks

□ not specified

□ not applicable (no follow-up)

4. Symptoms of depression in relation to MI hospitalization:

□ symptoms appeared after hospitalization

□ symptoms appeared before hospitalization

□ both populations included

□ not specified

□ not applicable

5. Depression treatment given between initial hospitalization and the next period of assessment.

□ depression treatment given

If yes, assignment of treatment:

□ random

□ non-random

□ not stated

□ depression treatment not given

□ no information available

□ not applicable

6. Severity of depression (Check all that apply):

□ depression reported as continuous variable

□ depression reported as categorical variable

□ depression reported as dichotomous variable

□ not specified

□ severity not measured

RESULTS OF STUDY

7. What number and percentage of patients had depression during hospitalization?

Depression | n | % | 95% CI
□ primary instrument____________> __________
□ major depression
□ minor depression
□ major/minor depression
□ other affective disorders
□ other: __________________________________
□ other: __________________________________

□ Not applicable

8. What number and percentage of patients had depression at the first follow-up visit after the cardiac event?

Depression | n | % | 95% CI
□ primary instrument____________> __________
□ major depression
□ minor depression
□ major/minor depression
□ other affective disorders
□ other: ___________________________________
□ other: ___________________________________

□ Not applicable

9. When was the first follow-up visit? ____________weeks or ____________months

□ Not applicable

10. What number and percentage of patients had depression at the last follow-up visit after the cardiac event?

Depression | n | % | 95% CI
□ primary instrument____________> __________
□ major depression
□ minor depression
□ major/minor depression
□ other affective disorders
□ other: _________________________________
□ other: _________________________________

□ Not applicable

11. When was the last follow-up visit? _______weeks or _______months or _______years

□ Not applicable

12. Other comments about the study not already reported:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

Question 3 Form

JOHNS HOPKINS EVIDENCE-BASED PRACTICE CENTER
POST MYOCARDIAL INFARCTION DEPRESSION
QUESTION 3 FORM
Article ID: _________________________ | First Author: _______________________
Reviewer 1: ________________________ | Reviewer 2: ________________________

RESULTS OF STUDY

Outcome events

NOTE: Report number AND/OR % population. ***Include DENOMINATOR IF different from total***

Outcome | | Depression n ( % ) | No Depression n ( % )
1. | Total no. in group at enrollment (N)
2. | Total no. in group available for analysis at last follow-up
3. | Mean/median follow-up
| □ mean □ median

Comments:

_______________________________________________________________

_______________________________________________________________

_______________________________________________________________

Outcome | | Depression n ( % ) | | | No Depression n ( % ) | | | P-value | Comparison Statistic
| | | | | | | | | (+ 95% Confidence Interval)
| | | | | | | | | Relative Risk
| | | | | | | | | Odds Ratio
| | | | | | | | | Hazard Ratio
| | Mean | SD | CI | Mean | SD | CI | | Univariate | Multivariate
4. | Total Mortality at
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
5. | Cardiac Mortality at
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
6. | Myocardial Infarction (recurrent)
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
7. | Arrhythmias
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
8. | Revascularization procedure
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
9. | Utilization of healthcare services (specify) ____________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
10. | Cost of care (specify how defined) _________________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
11. | Quality of life (specify instrument) _________________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
12. | Depression Score (specify instrument) __________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
13. | Patients with depression (specify how defined)______________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
14. | Disability (specify how measured) _____________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
15. | Heart rate variability (specify how measured) _______________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
16. | Heart rate variability (specify how measured) ______________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
17. | Heart rate variability (specify how measured) _______________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
18. | Heart rate variability (specify how measured) _______________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
19. | Platelet reactivity (specify how defined) _______________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
20. | Platelet reactivity (specify how defined) _______________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
21. | C-reactive protein
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
22. | Other markers of inflammation (specify)_______________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
23. | Other markers of inflammation (specify)_______________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
24. | Other outcomes (specify) ______________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up
25. | Other outcomes (specify) _________________________
a. | 1 month
b. | 2 months
c. | 3 months
d. | 6 months
e. | 12 months
f. | last follow-up _________ record mean/median follow-up

Comments:

_______________________________________________________________

_______________________________________________________________

26. Which one of the following outcomes was the dependent variable in the main multivariate analyses?

□ None

□ Total mortality

□ Cardiac mortality

□ Myocardial Infarction (recurrent)

□ Arrhythmias

□ Revascularization procedure

□ Utilization (of health care facility)

□ Cost of care

□ Quality of life

□ Depression

□ Disability and adherence

□ Heart rate variability

□ Platelet reactivity

□ C-reactive protein

□ Other markers of inflammation (specify): ____________________________________

□ Other outcomes (specify): _______________________________________________

27. What were the independent variables in the main multivariate analysis?

(Check one box in each row)

Factor | p <= 0.05 | p > 0.05 | Not Considered
Age | □ | □ | □
Gender | □ | □ | □
Race/Ethnicity | □ | □ | □
Hypertension | □ | □ | □
Diabetes Mellitus | □ | □ | □
Serum Cholesterol | □ | □ | □
Smoking | □ | □ | □
Previous MI | □ | □ | □
Left ventricular ejection fraction (LVEF) | □ | □ | □
Killip Class | □ | □ | □
History of depression | □ | □ | □
Social Support | □ | □ | □
Other cardiac factor: (specify) _______________________________ | □ | □ | □
Other cardiac factor: (specify) _______________________________ | □ | □ | □
Other depression measure: (specify) _______________________________ | □ | □ | □
Other depression measure: (specify) _______________________________ | □ | □ | □
Other: (specify) _______________________________ | □ | □ | □
Other: (specify) _______________________________ | □ | □ | □

28. Which one of the following outcomes was the dependent variable in the other multivariate analysis?

□ None

□ Total mortality

□ Cardiac mortality

□ Myocardial Infarction (recurrent)

□ Arrhythmias

□ Revascularization procedure

□ Utilization (of health care facility)

□ Cost of care

□ Quality of life

□ Depression

□ Disability and adherence

□ Heart rate variability

□ Platelet reactivity

□ C-reactive protein

□ Other markers of inflammation (specify): ____________________________________

□ Other outcomes (specify): _______________________________________________

29. What were the independent variables in the other multivariate analysis? (Check one box in each row)

Factor | p <= 0.05 | p > 0.05 | Not Considered
Age | □ | □ | □
Gender | □ | □ | □
Race/Ethnicity | □ | □ | □
Hypertension | □ | □ | □
Diabetes Mellitus | □ | □ | □
Serum Cholesterol | □ | □ | □
Smoking | □ | □ | □
Previous MI | □ | □ | □
Left ventricular ejection fraction (LVEF) | □ | □ | □
Killip Class | □ | □ | □
History of depression | □ | □ | □
Social Support | □ | □ | □
Other cardiac factor: (specify) _______________________________ | □ | □ | □
Other cardiac factor: (specify) _______________________________ | □ | □ | □
Other depression measure: (specify) ________________________________ | □ | □ | □
Other depression measure: (specify) ________________________________ | □ | □ | □
Other: (specify) ________________________________ | □ | □ | □
Other: (specify) ________________________________ | □ | □ | □

Question 4 Form

JOHNS HOPKINS EVIDENCE-BASED PRACTICE CENTER
POST MYOCARDIAL INFARCTION DEPRESSION
Question 4 Form
Article ID: ________________________ | First Author: ________________________
Reviewer 1: ________________________ | Reviewer 2: ________________________

CHARACTERISTICS OF STUDY

1. For each group, provide a brief description of the intervention (less than 10 words)

Group A: _________________________________________________________________________________________

_________________________________________________________________________________________________

Group B: _________________________________________________________________________________________

_________________________________________________________________________________________________

Group C: _________________________________________________________________________________________

_________________________________________________________________________________________________

Group D: _________________________________________________________________________________________

_________________________________________________________________________________________________

2. Treatment

| Group A | Group B | Group C | Group D
Antidepressant drug
Starting dose (mg or units/kg)
Frequency of administration (e.g., QD, BID)
Duration of intervention in days
Cognitive behavioral therapy
Interpersonal therapy
Psychosocial therapy
Cardiac rehabilitation
Others________________

3. Protocol adherence achieved

NOTE: Report mean of value OR median if only median reported

| | Group A | Group B | Group C | Group D
Days from MI to starting antidepressant | mean
| median
Target no. of psychotherapy sessions
No. of psychotherapy sessions achieved | mean
| median
No. of weeks on study drug | mean
| median
Daily dose achieved in mg per day | mean
| median

4. Outcome events

NOTE: Report number AND/OR % of population. ***Include DENOMINATOR IF different from total***

Outcome | Group A n / % | | | Group B n / % | | | Group C n / % | | | Group D n / % | | | P Value | Comparison statistic | What groups are compared?
| Mean | SD^+^ | CI^++^ | Mean | SD^+^ | CI^++^ | Mean | SD^+^ | CI^++^ | Mean | SD^+^ | CI^++^ | | Risk Ratio | (if other than A vs. B)
| | | | | | | | | | | | | | Odds Ratio
| | | | | | | | | | | | | | Hazard Ratio
Total no. in group at enrollment (N)
Total no. in group available for analysis at last follow-up
Mean/median follow-up
mean median
Total mortality at
1 month, n (%)
2 months, n (%)
3 months, n (%)
6 months, n (%)
12 months, n (%)
last follow-up at _______ months, n (%) (if >12 months)
Cardiac mortality at
1 month, n (%)
2 months, n (%)
3 months, n (%)
6 months, n (%)
12 months, n (%)
last follow-up at _______ months, n (%) (if >12 months)
Myocardial infarction at
1 month, n (%)
2 months, n (%)
3 months, n (%)
6 months, n (%)
12 months, n (%)
last follow-up at _______ months, n (%) (if >12 months)
Revascularization procedures at
1 month, n (%)
2 months, n (%)
3 months, n (%)
6 months, n (%)
12 months, n (%)
last follow-up at _______ months, n (%) (if >12 months)
Quality of life: Instrument__________________ Score at
1 month, n (%)
2 months, n (%)
3 months, n (%)
6 months, n (%)
12 months, n (%)
last follow-up at _______ months, n (%) (if >12 months)
Cost of care: definition____________ mean costs at
1 month, n (%)
2 months, n (%)
3 months, n (%)
6 months, n (%)
12 months, n (%)
last follow-up at _______ months, n (%) (if >12 months)
Depression: Instrument_______________________________ Score at
1 month, n (%)
2 months, n (%)
3 months, n (%)
6 months, n (%)
12 months, n (%)
last follow-up at _______ months, n (%) (if >12 months)
Other outcome: (specify) ____________________ at
month(s), n (%)
_____months, n (%)
Other outcome: (specify) ____________________ at
_____month(s), n (%)
_____months, n (%)

+ CI - Confidence Interval

++ SD - Standard Deviation

Comments: __________________________________________________________

_______________________________________________________________________

_______________________________________________________________________

5. Subgroup analyses

Subgroup characteristics | Main outcome(s) reported | Results in subgroups | P-value

6. Summary of main conclusions:

______________________________________________________________________________

______________________________________________________________________________

______________________________________________________________________________

______________________________________________________________________________

______________________________________________________________________________

______________________________________________________________________________

Question 5 Form

JOHNS HOPKINS EVIDENCE-BASED PRACTICE CENTER
POST MYOCARDIAL INFARCTION DEPRESSION
Question 5 Form
Article ID: _____________________________ | First Author: ______________________
Reviewer 1: ____________________________ | Reviewer 2: _______________________

1. Results of test utility (specify study test _________________________________)

| | Statistic | Confidence Interval (P)
Sensitivity
Specificity
Reproducibility | Intra-rater
| Inter-rater
Percent agreement/correlation with validated questionnaire
Percent agreement/correlation with psychiatric interview
Percent agreement/correlation with mental health professional
Other :__________________
Other :__________________

2. Results of test utility (specify study test _________________________________)

| | Statistic | Confidence Interval (P)
Sensitivity
Specificity
Reproducibility | Intra-rater
| Inter-rater
Percent agreement/correlation with validated questionnaire
Percent agreement/correlation with psychiatric interview
Percent agreement/correlation with mental health professional
Other :__________________
Other :__________________

3. Results of test utility (specify study test _________________________________)

| | Statistic | Confidence Interval (P)
Sensitivity
Specificity
Reproducibility | Intra-rater
| Inter-rater
Percent agreement/correlation with validated questionnaire
Percent agreement/correlation with psychiatric interview
Percent agreement/correlation with mental health professional
Other :__________________
Other :__________________

4. Other comments:

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

Question 6 Form

JOHNS HOPKINS EVIDENCE-BASED PRACTICE CENTER
POST MYOCARDIAL INFARCTION DEPRESSION
Question 6
Article ID: _____________________________ | First Author: ______________________
Reviewer 1: ____________________________ | Reviewer 2: _______________________

Results of study

1. What number and percentage of subjects received the following procedures?

Cardiac Procedure | Group A n / % | Group B n / % | Group C n / % | Group D n / % | Comparison statistic | P Value | What groups are compared?
| | | | | ( + 95% CI ) | | (if other than A vs. B)
| | | | | Risk Ratio
| | | | | Odds Ratio
| | | | | Hazard Ratio
Catheterization
Revascularization (CABG or percutaneous intervention)
Percutaneous intervention (angioplasty, stenting)
CABG
Thrombolytic therapy
Other:_______________

□ Not applicable (N/A)

2. What number and percentage of subjects received and/or were recommended the following lifestyle interventions?

Lifestyle Interventions | Group A n / % | Group B n / % | Group C n / % | Group D n / % | Comparison statistic | P Value | What groups are compared?
| | | | | ( + 95% CI ) | | (if other than A vs. B)
| | | | | Risk Ratio
| | | | | Odds Ratio
| | | | | Hazard Ratio
Smoking cessation
Physical exercise
Weight management
CABG
Dietary lipid management
Other:_______________

□ Not applicable (N/A)

3. What number and percentage of subjects received and/or were recommended the following medications?

Medications | Group A n / % | Group B n / % | Group C n / % | Group D n / % | Comparison statistic | P Value | What groups are compared?
| | | | | ( + 95% CI ) | | (if other than A vs. B)
| | | | | Risk Ratio
| | | | | Odds Ratio
| | | | | Hazard Ratio
ACE inhibitors
Beta-blockers
Statins
Aspirin
Other antiplatelet therapy
Anticoagulants
Other:_______________

□ Not applicable (N/A)

4. What number and percentage of subjects received a referral for a cardiac rehabilitation program, and what number and percentage of subjects participated in a cardiac rehabilitation program?

| Group A n / % | Group B n / % | Group C n / % | Group D n / % | Comparison statistic | P Value | What groups are compared?
| | | | | ( + 95% CI )
| | | | | Risk Ratio
| | | | | Odds Ratio
| | | | | Hazard Ratio
Type of Program:
__________________
__________________
Referral
Participation

□ Not applicable (N/A)

5. Among studies that evaluated depression as a potential barrier to cardiac treatment, what were the other factors influencing cardiac treatment for patients with acute MI?

| Statistically Significant | Not Statistically Significant | Reported as Qualitatively Important | Reported as Qualitatively Not Important | Not Assessed
Lack of referral | □ | □ | □ | □ | □
Medical illness | □ | □ | □ | □ | □
Other psychiatric illness | □ | □ | □ | □ | □
Don't need treatment / exercise alone | □ | □ | □ | □ | □
Too busy | □ | □ | □ | □ | □
Transportation | □ | □ | □ | □ | □
Cost of treatment | □ | □ | □ | □ | □
Low socioeconomic status | □ | □ | □ | □ | □
Unemployment | □ | □ | □ | □ | □
Lack of insurance / inadequate insurance | □ | □ | □ | □ | □
Lack of availability of tertiary medical centers | □ | □ | □ | □ | □
Communication barrier | □ | □ | □ | □ | □
Lack of effective aftercare | □ | □ | □ | □ | □
Other:___________________ | □ | □ | □ | □ | □
Other:___________________ | □ | □ | □ | □ | □
Other:___________________ | □ | □ | □ | □ | □

□ Not applicable (N/A)

6. Was depression found to be a significant barrier to cardiac treatment (p < 0.05)?

□ Yes

□ No

□ Not applicable (N/A)

7. Subgroup Analyses

Subgroup Characteristics | Main Outcome(s) Reported | Results in Subgroups | p-value

Comments not captured by previous questions:

______________________________________________________________________________

______________________________________________________________________________

______________________________________________________________________________

______________________________________________________________________________

______________________________________________________________________________