# Appendix D. Abstract Review Form for Primary Literature

Date: | EPC Depression Post-MI | Reviewer: _________
| Abstract Review Form
| | Data Entry:________
Record ID:
Title:
Abstract:

Step 1: General Exclusion Criteria

Delete article because (check one):

□ not in English

□ does not include human data

□ no original data

□ meeting abstract (no full article for review)

□ other: (specify) ________________________

□ Unclear: get article to decide

Step 2: Article may address following questions (check all that apply):

□ depression during hospitalization (Q1)

□ depression during hospitalization w/ & w/out a known history (Q1a)

□ depression after initial hospitalization (Q2)

□ depression measures and outcomes (Q3)

□ depression measures and surrogate markers (Q3a)

□ outcomes w/ & w/out depression treatment (Q4)

□ outcomes w/ depression resolution (Q4a)

□ outcomes w/out depression resolution (Q4b)

□ screening performance characteristics (Q5)

□ screening performance characteristics during hospitalization (Q5a)

□ screening performance characteristics after hospitalization (Q5b)

□ cardiac treatment differences with depression (Q6)

□ This article does not apply to any of the questions

□ Get article for reference regarding: _________________________________________

Step 3: Question-Specific Exclusion Criteria

Question 4:

○ Not a concurrent comparison study

Questions 5:

○ Does not have a validated reference standard

Do not go on if any item above is checked.