# Appendix C. Literature Search Strategies

[underlined: Medline]

(myocardial infarction[mh] OR myocardial infarct*[tiab]) AND (depression[mh] OR mental disorder[mh] OR mood disorder[mh] OR depression[tiab] OR depressive symptom*[tiab] OR mood disorder[tiab] OR mental disorder[tiab] OR psychiatric disorder[tiab]) AND eng[la] NOT (animal[mh] NOT human[mh])

[underlined: Cochrane]

(myocardial next infarction) and (depression)

[underlined: EMBASE]

‘acute heart infarction’/exp OR ‘heart infarct’/exp OR ‘heart infarction’/exp OR (myocardial AND (‘infarct’/exp OR ‘infarction’/exp)) AND (‘depression’/exp OR ‘mood disorder’/exp OR ((mental OR ‘mood’/exp OR psychiatric) AND (disorder))) AND [english]/lim AND [humans]/lim AND [embase]/lim

[underlined: CINAHL]

(((myocardial or myocardiac) and (infarct*)) and ((depression) or (mental disorder) or (mood disorder) or (psychiatric disorder) or (depressive symptom))) and (ZL “ENGLISH”)

[underlined: PsychInfo]

((myocardial infarct*) and ((depression) or (mental disorder) or (psychiatric disorder) or (depressive symptom))) and (ZL “ENGLISH”)