# Appendix B. Priority Journals for Hand Searching

Priority Journal Titles
American Heart Journal
American Journal of Cardiology
American Journal of Medicine
American Journal of Psychiatry
Annals of Behavioral Medicine
Archives of General Psychiatry
Archives of Internal Medicine
Biological Psychiatry
Circulation
Health Psychology
JAMA
Journal of Behavioral Medicine
Journal of Cardiopulmonary Rehabilitation
Journal of the American College of Cardiology
Psychosomatic Medicine
Psychosomatics

* Tables of Contents reviewed from 1 October 2003 to 30 March 2004.