# Appendix A: Technical Experts and Peer Reviewers

Technical Experts
Expert Area and Organization | Name | Location
Partner Organization
American Academy of Family Physicians (AAFP) | Lee Green MD, MPH | University of Michigan Ann Arbor, MI
Government
Center for Medicaid and Medicare Services (CMS) | Carlos Cano MD | Woodlawn, MD
Payer
IPRO | Charles Stimler MD, MPH | Lake Success, NY
University
Washington University School of Medicine | Robert M. Carney PhD | St. Louis, MO
University of Birmingham | Douglas Carroll PhD | Edgbaston, Birmingham, United Kingdom
Tilburg University | Johan Denollet, PhD | Tilburg, The Netherlands
McGill University | Nancy Frasure-Smith PhD | Montreal, QC Canada
Columbia University | Alexander Glassman MD | New York, NY
Professional Organizations
American College of Physicians (ACP) | Vincenza Snow MD | Philadelphia, PA

Peer Reviewer
Expert Area and Organization | Name | Location
Partner Organization
American Academy of Family Physicians (AAFP) | Lee Green MD, MPH | University of Michigan Ann Arbor, MI
American Academy of Family Physicians (AAFP) | Belinda Ireland MD, MS | Leawood, KS
Government
Center for Medicaid and Medicare Services (CMS) | Carlos Cano MD | Woodlawn, MD
Payer
IPRO | Charles Stimler MD, MPH | Lake Success, NY
University
Columbia University | Alexander Glassman MD | New York, NY
Professional Organizations
American College of Physicians (ACP) | Vincenza Snow MD | Philadelphia, PA
American Association of Cardiovascular and Pulmonary Rehabilitation (AACVPR) | Douglas R. Southard PhD, MPH, PA-C | Roanoke, VA