# Appendixes

Appendix A: Technical Experts and Peer Reviewers

Appendix B. Priority Journals for Hand Searching

Appendix C. Literature Search Strategies

Appendix D. Abstract Review Form for Primary Literature

Appendix E. Abstraction Forms

Appendix F. Grading the Strength of Evidence

Appendix G. Evidence Tables

Appendix H. List of Excluded Studies