# Excluded Articles

Antman K, Amato D, Wood W, et al. Selection bias in clinical trials. J Clin Oncol. 1985;3(8):1142-1147. does not report a controlled trial or recruitment to a controlled trial. [pmid: 4020412].
Ashing-Giwa K. The recruitment of breast cancer survivors into cancer control studies: a focus on African-American women. J Natl Med Assoc. 1999;91(5):255-60. does not report a controlled trial or recruitment to a controlled trial. [pmid: 10365546]. [pmcid: 2608496].
Baines CJ. Impediments to recruitment in the Canadian National Breast Screening Study: response and resolution. Control Clin Trials. 1984;5(2):129-40. other: does not address underserved populations. [pmid: 6744885].
Barr JK, Franks AL, Lee NC, et al. A randomized intervention to improve ongoing participation in mammography. Am J Manag Care. 2001;7(9):887-94. other: does not address underserved populations. [pmid: 11570022].
Baum M. The ATAC (Arimidex, Tamoxifen, alone or in combination) adjuvant breast cancer trial in postmenopausal patients:factors influencing the success of patient recruitment. Eur J Cancer. 2002;38(15):1984-6. other: does not address underserved populations. [pmid: 12376201].
Berglund G, Bolund C, Gustafsson UL, et al. Is the wish to participate in a cancer rehabilitation program an indicator of the need? Comparisons of participants and non-participants in a randomized study. Psychooncology. 1997;6(1):35-46. other: does not address underserved populations. [pmid: 9126714].
Berner ES, Partridge EE, Baum SK. The effects of the PDQ patient information file (PIF) on patients' knowledge, enrollment in clinical trials, and satisfaction. J Cancer Educ. 1997;12(2):121-5. other: no subgroup analysis of an underserved population. [pmid: 9229276].
Bijker N, Peterse JL, Fentiman IS, et al. Effects of patient selection on the applicability of results from a randomised clinical trial (EORTC 10853) investigating breast-conserving therapy for DCIS. Br J Cancer. 2002;87(6):615-20. other: does not address underserved populations. [pmid: 12237770].
Bleyer WA, Tejeda HA, Murphy SB, et al. Equal participation of minority patients in U.S. national pediatric cancer clinical trials. J Pediatr Hematol Oncol. 1997;19(5):423-7. does not report a controlled trial or recruitment to a controlled trial. [pmid: 9329463].
Bohnen RF, Winter JM, Catlin GE, et al. Effective participation in cooperative clinical trials by an independent community organization. An NCOG model. Am J Clin Oncol. 1983;6(2):245-52. other: no subgroup analysis of an underserved population. [pmid: 6829499].
Brown DR, Fouad MN, Basen-Engquist K, et al. Recruitment and retention of minority women in cancer screening, prevention, and treatment trials. Ann Epidemiol. 2000;10(8 Suppl):S13-21. does not report a controlled trial or recruitment to a controlled trial. [pmid: 11189088].
Burhansstipanov L, Krebs LU, Bradley A, et al. Lessons learned while developing “Clinical Trials Education for Native Americans” curriculum. Cancer Control. (Sep-Oct). 2003;10(5 Suppl):29-36. does not report a controlled trial or recruitment to a controlled trial. [pmid: 14581902].
Burnett CB, Koczwara B, Pixley L, et al. Nurses' attitudes toward clinical trials at a comprehensive cancer center. Oncol Nurs Forum. 2001;28(7):1187-92. other: does not address underserved populations. [pmid: 11517851].
Butler L. Consenting to participate in research for the treatment of cancer: the patient's perspective. Can Oncol Nurs J. 1996;6(3):124-9. other: does not address underserved populations.
Camerini T, De Palo G, Mariani L, et al. Accrual issues for chemoprevention trials: the example of the 4-HPR study for the prevention of contralateral breast cancer. Tumori. 1999;85(4):299-303. other: does not address underserved populations. [pmid: 10587038].
Cappelli M, Hunter AG, Stern H, et al. Participation rates of Ashkenazi Jews in a colon cancer community-based screening/prevention study. Clin Genet. 2002;61(2):104-14. does not report a controlled trial or recruitment to a controlled trial. [pmid: 11940085].
Cassileth BR, Lusk EJ, Miller DS, et al. Attitudes toward clinical trials among patients and the public. JAMA. 1982;248(8):968-70. other: does not address underserved populations. [pmid: 7097966].
Chang SM, Barker FG 2nd, Schmidt MH, et al. Clinical trial participation among patients enrolled in the Glioma Outcomes Project. Cancer. 2002;94(10):2681-7. other: no barriers to an underserved group reported. [pmid: 12173337].
Christian MC, Trimble EL. Increasing participation of physicians and patients from underrepresented racial and ethnic groups in National Cancer Institute-sponsored clinical trials. Cancer Epidemiol Biomarkers Prev. 2003;12(3):277s-283s. no original data. [pmid: 12646527].
Cole SR, Young GP, Esterman A, et al. A randomised trial of the impact of new faecal haemoglobin test technologies on population participation in screening for colorectal cancer. J Med Screen. 2003;10(3):117-22. does not report a controlled trial or recruitment to a controlled trial. [pmid: 14561262].
Cooley ME, Sarna L, Brown JK, et al. Challenges of recruitment and retention in multisite clinical research. Cancer Nurs. 2003;26(5):376-84. quiz 385–6. does not report a controlled trial or recruitment to a controlled trial. [pmid: 14710799].
Cooper SE. Some social-demographic characteristics of patients self-referred for a clinical trial of laetrile. J Psychosoc Oncol. 1983;1(2):83-91. does not report a controlled trial or recruitment to a controlled trial.
Corbie-Smith G, Ammerman AS, Katz ML, et al. Trust, benefit, satisfaction, and burden: a randomized controlled trial to reduce cancer risk through African-American churches. J Gen Intern Med. 2003;18(7):531-41. does not report a controlled trial or recruitment to a controlled trial. [pmid: 12848836]. [pmcid: 1494890].
Corbie-Smith G, Thomas SB, Williams MV, et al. Attitudes and beliefs of African Americans toward participation in medical research. J Gen Intern Med. 1999;14(9):537-46. does not address cancer treatment or prevention. [pmid: 10491242]. [pmcid: 1496744].
Corrie P, Shaw J, Harris R. Rate limiting factors in recruitment of patients to clinical trials in cancer research: descriptive study. BMJ. 2003;327(7410):320-1. other: does not address underserved populations. [pmid: 12907485]. [pmcid: 169635].
Cottin V, Arpin D, Lasset C, et al. Small-cell lung cancer: patients included in clinical trials are not representative of the patient population as a whole. Ann Oncol. 1999;10(7):809-15. other: does not address underserved populations. [pmid: 10470428].
Cox K. Informed consent and decision-making: patients' experiences of the process of recruitment to phases I and II anti-cancer drug trials. Patient Educ Couns. 2002;46(1):31-8. other: does not address underserved populations. [pmid: 11804767].
Cox K. Investigating psychosocial aspects of participation in early anti-cancer drug trials: towards a choice of methodology. J Adv Nurs. 1998;27(3):488-96. no original data. [pmid: 9543033].
Cox K. Setting the context for research:exploring the philosophy and environment of a cancer clinical trials unit. J Adv Nurs. 2000;32(5):1058-65. other: does not address underserved populations. [pmid: 11114988].
Coyne CA, Xu R, Raich P, et al. Randomized, controlled trial of an easy-to-read informed consent statement for clinical trial participation:a study of the Eastern Cooperative Oncology Group. J Clin Oncol. 2003;21(5):836-42. other: does not address underserved populations. [pmid: 12610182].
Crighton MH, Goldberg AN, Kagan SH. Reciprocity for patients with head and neck cancer participating in an instrument development project. Oncol Nurs Forum. 2002;29(10):E127-31. other: does not address underserved populations. [pmid: 12432421].
Crosson K, Eisner E, Brown C, et al. Primary care physicians' attitudes, knowledge, and practices related to cancer clinical trials. J Cancer Educ. 2001;16(4):188-92. other: no subgroup analysis of an underserved population. [pmid: 11848665].
Crowley R, Casarett D. Patients' willingness to participate in symptom-related and disease-modifying research: results of a research screening initiative in a palliative care clinic. Cancer. 2003;97(9):2327-33. does not report a controlled trial or recruitment to a controlled trial. [pmid: 12712490].
Curbow B, Fogarty LA, McDonnell K, et al. Can a brief video intervention improve breast cancer clinical trial knowledge and beliefs?. Soc Sci Med. 2004;58(1):193-205. does not report a controlled trial or recruitment to a controlled trial. [pmid: 14572931].
Daly M, Seay J, Balshem A, et al. Feasibility of a telephone survey to recruit health maintenance organization members into a tamoxifen chemoprevention trial. Cancer Epidemiol Biomarkers Prev. 1992;1(5):413-6. other: does not address underserved populations. [pmid: 1305474].
Derose KP, Hawes-Dawson J, Fox SA, et al. Dealing with diversity: recruiting churches and women for a randomized trial of mammography promotion. Health Educ Behav. 2000;27(5):632-48. other: screening program. [pmid: 11009131].
Diener-West M, Earle JD, Fine SL, et al. The COMS randomized trial of iodine 125 brachytherapy for choroidal melanoma, II:characteristics of patients enrolled and not enrolled. COMS Report No. 17. Arch Ophthalmol. 2001;119(7):951-65. other: does not address underserved populations. [pmid: 11448318].
Dietrich AJ, O'Connor G, Keller A, et al. Will community physicians participate in rigorous studies of cancer control? The methodology and recruitment of a randomized trial of physician practices. Prog Clin Biol Res. 1990;339:373-81. other: does not address underserved populations. [pmid: 2202996].
DiPalma AM, Barnes SE, DiPalma JA. Patient participation in colon cancer screening programs. South Med J. 1998;91(4):342-4. does not report a controlled trial or recruitment to a controlled trial. [pmid: 9563424].
Donovan J, Mills N, Smith M, et al. Quality improvement report:Improving design and conduct of randomised trials by embedding them in qualitative research: ProtecT (prostate testing for cancer and treatment) study. Commentary:presenting unbiased information to patients can be difficult. BMJ. 2002;325(7367):766-70. other: does not address underserved populations. [pmid: 12364308]. [pmcid: 1124277].
Donovan JL, Peters TJ, Noble S, et al. Who can best recruit to randomized trials? Randomized trial comparing surgeons and nurses recruiting patients to a trial of treatments for localized prostate cancer (the ProtecT study). J Clin Epidemiol. 2003;56(7):605-9. other: does not address underserved populations. [pmid: 12921927].
Ellis PM, Butow PN, Tattersall MH. Informing breast cancer patients about clinical trials: a randomized clinical trial of an educational booklet. Ann Oncol. 2002;13(9):1414-23. other: does not address underserved populations. [pmid: 12196367].
Ellis PM, Butow PN, Simes RJ, et al. Barriers to participation in randomized clinical trials for early breast cancer among Australian cancer specialists. Aust N Z J Surg. 1999;69(7):486-91. other: does not address underserved populations. [pmid: 10442918].
Ellis PM, Butow PN, Tattersall MH, et al. Randomized clinical trials in oncology: understanding and attitudes predict willingness to participate. J Clin Oncol. 2001;19(15):3554-61. other: does not address underserved populations. [pmid: 11481363].
Elwood M, McNoe B, Smith T, et al. Once is enough--why some women do not continue to participate in a breast cancer screening programme. N Z Med J. 1998;111(1066):180-3. does not report a controlled trial or recruitment to a controlled trial. [pmid: 9640316].
Emmons KM, Stoddard AM, Gutheil C, et al. Cancer prevention for working class, multi-ethnic populations through health centers:the healthy directions study. Cancer Causes Control. 2003;14(8):727-37. does not report a controlled trial or recruitment to a controlled trial. [pmid: 14674737].
Englisbe BH, Jimpson GE, Harper GR, et al. Encouraging mammography use among underserved women through a celebration of breast health. Am J Public Health. 1995;85(10):1446-7. does not report a controlled trial or recruitment to a controlled trial. [pmid: 7573635]. [pmcid: 1615603].
Fetting JH, Siminoff LA, Piantadosi S, et al. Effect of patients' expectations of benefit with standard breast cancer adjuvant chemotherapy on participation in a randomized clinical trial: a clinical vignette study. J Clin Oncol. 1990;8(9):1476-82. other: no barriers to an underserved group reported. [pmid: 2202790].
Fisher WB, Cohen SJ, Hammond MK, et al. Clinical trials in cancer therapy: efforts to improve patient enrollment by community oncologists. Med Pediatr Oncol. 1991;19(3):165-8. other: does not address underserved populations. [pmid: 2023564].
Fleissig A, Jenkins V, Fallowfield L. Results of an intervention study to improve communication about randomised clinical trials of cancer therapy. Eur J Cancer. 2001;37(3):322-31. other: does not address underserved populations. [pmid: 11239753].
Foley JF, Moertel CG. Improving accrual into cancer clinical trials. J Cancer Educ. 1991;6(3):165-73. other: does not address underserved populations. [pmid: 1931596].
Ford LG, Minasian LM, McCaskill-Stevens W, et al. Prevention and early detection clinical trials: opportunities for primary care providers and their patients. CA Cancer J Clin. 2003;53(2):82-101. no original data. [pmid: 12691266].
George SL. Reducing patient eligibility criteria in cancer clinical trials. J Clin Oncol. 1996;14(4):1364-70. other: commentary. [pmid: 8648395].
Gibson LMR. A four-phase program to recruit African American women into breast cancer promotion programs. ABNF J. 2000;11(4):94-6. does not report a controlled trial or recruitment to a controlled trial. [pmid: 11760311].
Gohagan JK, Prorok PC, Hayes RB, et al. The Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial of the National Cancer Institute:history, organization, and status. Control Clin Trials. 2000;21(6 Suppl):251S-272S. other: does not address underserved populations. [pmid: 11189683].
Goodman GE, Valanis B, Meyskens FL Jr, et al. Strategies for recruitment to a population-based lung cancer prevention trial: the CARET experience with heavy smokers. Beta-Carotene and Retinol Efficacy Trial. Cancer Epidemiol Biomarkers Prev. 1998;7(5):405-12. other: does not address underserved populations. [pmid: 9610790].
Goodman PJ, Tangen CM, Crowley JJ, et al. Implementation of the Prostate Cancer Prevention Trial (PCPT). Control Clin Trials. 2004;25(2):203-22. does not report a controlled trial or recruitment to a controlled trial. [pmid: 15020037].
Goodwin PJ, Leszcz M, Quirt G, et al. Lessons learned from enrollment in the BEST study--a multicenter, randomized trial of group psychosocial support in metastatic breast cancer. J Clin Epidemiol. 2000;53(1):47-55. other: does not address underserved populations. [pmid: 10693903].
Gordon EJ, Daugherty CK. Referral and decision making among advanced cancer patients participating in Phase I trials at a single institution. J Clin Ethics. 2001;12(1):31-8. other: does not address underserved populations. [pmid: 11428154].
Gudmundsdottir T, Tryggvadottir L, Allende M, et al. Eligibility and willingness of young Icelandic women to participate in a HPV vaccination trial. Acta Obstet Gynecol Scand. 2003;82(4):345-50. other: does not address underserved populations. [pmid: 12716319].
Gurwitz JH, Guadagnoli E, Landrum MB, et al. The treating physician as active gatekeeper in the recruitment of research subjects. Med Care. 2001;39(12):1339-44. does not report a controlled trial or recruitment to a controlled trial. [pmid: 11717575].
Harris Y, Gorelick PB, Samuels P, et al. Why African Americans may not be participating in clinical trials. J Natl Med Assoc. 1996;88(10):630-4. does not report a controlled trial or recruitment to a controlled trial. [pmid: 8918067]. [pmcid: 2608128].
Holcombe RF, Jacobson J, Li A, et al. Inclusion of black Americans in oncology clinical trials: the Louisiana State University Medical Center experience. Am J Clin Oncol. 1999;22(1):18-21. Does not report a controlled trial or recruitment to a controlled trial. [pmid: 10025373].
Hudmon KS, Love RR, Chamberlain RM. Perceived benefits of and barriers to participation in a phase I/II colon cancer chemoprevention trial. J Cancer Educ. 1999;14(2):83-7. other: does not address underserved populations. [pmid: 10397482].
Hudmon KS, Stoltzfus C, Chamberlain RM, et al. Participants' perceptions of a phase I colon cancer chemoprevention trial. Control Clin Trials. 1996;17(6):494-508. other: does not address underserved populations. [pmid: 8974209].
Hunt JM, Gless GL, Straton JA. Pap smear screening at an urban aboriginal health service: report of a practice audit and an evaluation of recruitment strategies. Aust N Z J Public Health. 1998;22(6):720-5. does not report a controlled trial or recruitment to a controlled trial. [pmid: 9848971].
Hutchison C, Campbell S. Evaluation of an information booklet for patients considering participation in phase I clinical trials in cancer. Eur J Cancer Care (Engl). 2002;11(2):131-8. other: does not address underserved populations. [pmid: 12099949].
Jack WJ, Chetty U, Rodger A. Recruitment to a prospective breast conservation trial: why are so few patients randomised?. BMJ. 1990;301(6743):83-5. other: does not address underserved populations. [pmid: 2390587]. [pmcid: 1663425].
Jenkins V, Fallowfield L. Reasons for accepting or declining to participate in randomized clinical trials for cancer therapy. Br J Cancer. 2000;82(11):1783-8. other: does not address underserved populations. [pmid: 10839291].
Joffe S, Weeks JC. Views of American oncologists about the purposes of clinical trials. J Natl Cancer Inst. 2002;94(24):1847-53. other: does not address underserved populations. [pmid: 12488478].
Johnson RE, Williams RD, Nagy MC, et al. Retention of under-served women in clinical trials: a focus group study. Ethn Dis. 2003;13(2):268-78. does not address cancer treatment or prevention. [pmid: 12785425].
Joseph RR. Viewpoints and concerns of a clinical trial participant. Cancer. 1994;74(9 Suppl):2692-3. no original data. [pmid: 7954288].
Kinney AY, Richards C, Vernon SW, et al. The effect of physician recommendation on enrollment in the Breast Cancer Chemoprevention Trial. Prev Med. 1998;27(5 Pt 1):713-9. does not apply to the key questions. [pmid: 9808803].
Klabunde C, Kaluzny A, Ford L. Community Clinical Oncology Program participation in the Breast Cancer Prevention Trial:factors affecting accrual. Cancer Epidemiol Biomarkers Prev. 1995;4(7):783-9. other: no subgroup analysis of an underserved population. [pmid: 8672997].
Koretz MM, Jackson PM, Torti FM, et al. A comparison of the quality of participation of community affiliates and that of universities in the Northern California Oncology Group. J Clin Oncol. 1983;1(10):640-4. other: does not address underserved populations. [pmid: 6668485].
Langley C, Gray S, Selley S, et al. Clinicians' attitudes to recruitment to randomised trials in cancer care: a qualitative study. J Health Serv Res Policy. 2000;5(3):164-9. other: does not address underserved populations. [pmid: 11183627].
Langley GR, Sutherland HJ, Wong S, et al. Why are (or are not) patients given the option to enter clinical trials?. Control Clin Trials. 1987;8(1):49-59. other: does not address underserved populations. [pmid: 3568696].
Lara PN Jr,, Higdon R, Lim N, et al. Prospective evaluation of cancer clinical trial accrual patterns: identifying potential barriers to enrollment. J Clin Oncol. 2001;19(6):1728-33. other: does not address underserved populations. [pmid: 11251003].
Larkey LK, Staten LK, Ritenbaugh C, et al. Recruitment of Hispanic women to the Women's Health Initiative. the case of Embajadoras in Arizona. Control Clin Trials. 2002;23(3):289-98. other: primary prevention trial. [pmid: 12057880].
Lee JY, Marks JE, Simpson JR. Recruitment of patients to cooperative group clinical trials. Cancer Clin Trials. 1980;3(4):381-4. other: no subgroup analysis of an underserved population. [pmid: 7428142].
Leslie NS, Deiriggi P, Gross S, et al. Knowledge, attitudes, and practices surrounding breast cancer screening in educated Appalachian women. Oncol Nurs Forum. 2003;30(4):659-67. does not apply to the key questions. [pmid: 12861325].
Liaschenko J, Underwood SM. Children in research: fathers in cancer research -- meanings and reasons for participation. Journal of Family Nursing. 2001;7(1):71-91. other: does not address underserved populations.
Lindholm E, Berglund B, Haglind E, et al. Factors associated with participation in screening for colorectal cancer with faecal occult blood testing. Scand J Gastroenterol. 1995;30(2):171-6. other: does not address underserved populations. [pmid: 7732341].
Llewellyn-Thomas HA, McGreal MJ, Thiel EC, et al. Patients' willingness to enter clinical trials: measuring the association with perceived benefit and preference for decision participation. Soc Sci Med. 1991;32(1):35-42. other: does not address underserved populations. [pmid: 2008619].
Loescher LJ, Graham VE, Aickin M, et al. Development of a contingency recruitment plan for a phase III chemoprevention trial of cervical dysplasia. Prog Clin Biol Res. 1990;339:151-63. other: no subgroup analysis of an underserved population. [pmid: 2202990].
Mannel RS, Walker JL, Gould N, et al. Impact of individual physicians on enrollment of patients into clinical trials. Am J Clin Oncol. 2003;26(2):171-3. other: does not address underserved populations. [pmid: 12714890].
Marcus AC, Ahnen D, Cutter G, et al. Promoting cancer screening among the first-degree relatives of breast and colorectal cancer patients:the design of two randomized trials. Prev Med. 1999;28(3):229-42. other: no subgroup analysis of an underserved population. [pmid: 10072740].
Martin RC 2nd, Polk HC Jr, Jaques DP. Does additional surgical training increase participation in randomized controlled trials?. Am J Surg. 2003;185(3):239-43. other: no subgroup analysis of an underserved population. [pmid: 12620563].
McCusker J, Wax A, Bennett JM. Cancer patient accessions into clinical trials: a pilot investigation into some patient and physician determinants of entry. Am J Clin Oncol. 1982;5(2):227-36. does not apply to the key questions. [pmid: 7091044].
McNeil C. Why patients enroll in clinical trials: physicians play a key role. J Natl Cancer Inst. 1996;88(11):709-11. no original data. [pmid: 8637023].
Mettlin C, Cummings KM, Walsh D. Risk factor and behavioral correlates of willingness to participate in cancer prevention trials. Nutr Cancer. 1985;7(4):189-98. Other: does not address underserved populations. [pmid: 3834402].
Mick R, Lane N, Daugherty C, et al. Physician-determined patient risk of toxic effects: impact on enrollment and decision making in phase I cancer trials. J Natl Cancer Inst. 1994;86(22):1685-93. other: does not address underserved populations. [pmid: 7966396].
Miller HH, Bauman LJ, Friedman DR, et al. Psychosocial adjustment of familial polyposis patients and participation in a chemoprevention trial. Int J Psychiatry Med. 1986;16(3):211-230. other: no subgroup analysis of an underserved population. [pmid: 3026981].
Moon TE, Levine N, Cartmel B, et al. Design and recruitment for retinoid Skin Cancer Prevention (SKICAP) trials. The Southwest Skin Cancer Prevention Study Group. Cancer Epidemiol Biomarkers Prev. 1995;4(6):661-9. other: no subgroup analysis of an underserved population. [pmid: 8547834].
Motzer SA, Moseley JR, Lewis FM. Recruitment and retention of families in clinical trials with longitudinal designs. West J Nurs Res. 1997;19(3):314-33. other: does not address underserved populations. [pmid: 9170990].
Naranjo LE, Dirksen SR. The recruitment and participation of Hispanic women in nursing research: a learning process. Public Health Nurs. 1998;15(1):25-9. does not address cancer treatment or prevention. [pmid: 9503950].
Omenn GS, Goodman G, Grizzle J, et al. Recruitment for the beta-carotene and retinol efficacy trial (CARET) to prevent lung cancer in smokers and asbestos-exposed workers. West J Med. 1992;156(5):540-4. does not report a controlled trial or recruitment to a controlled trial. [pmid: 1595284]. [pmcid: 1003322].
Owen JE, Klapow JC, Roth DL, et al. Improving the effectiveness of adjuvant psychological treatment for women with breast cancer:the feasibility of providing online support. Psychooncology. 2004;13(4):281-92. other: does not address underserved populations. [pmid: 15054732].
Pentz RD, Flamm AL, Sugarman J, et al. Study of the media's potential influence on prospective research participants' understanding of and motivations for participation in a high-profile phase I trial. J Clin Oncol. 2002;20(18):3785-91. other: no subgroup analysis of an underserved population. [pmid: 12228198].
Prochaska JO, Velicer WF, Fava JL, et al. Evaluating a population-based recruitment approach and a stage-based expert system intervention for smoking cessation. Addict Behav. 2001;26(4):583-602. other: does not address underserved populations. [pmid: 11456079].
Psillidis L, Flach J, Padberg RM. Participants strengthen clinical trial research: the vital role of participant advisors in the Breast Cancer Prevention Trial. J Womens Health. 1997;6(2):227-32. no original data. [pmid: 9140857].
Richardson MA, Post-White J, Singletary SE, et al. Recruitment for complementary/alternative medicine trials: who participates after breast cancer. Ann Behav Med. 1998;20(3):190-8. other: no subgroup analysis of an underserved population. [pmid: 9989326].
Rimer BK, Schildkraut JM, Lerman C, et al. Participation in a women's breast cancer risk counseling trial. Who participates? Who declines? High Risk Breast Cancer Consortium. Cancer. 1996;77(11):2348-55. other: no subgroup analysis of an underserved population. [pmid: 8635106].
Roberts F. Qualitative differences among cancer clinical trial explanations. Soc Sci Med. 2002;55(11):1947-55. other: does not address underserved populations. [pmid: 12406463].
Rogers AS. Adolescent under enrollment in national clinical research: it is time to ask why. J Adolesc Health. 1997;21(6):374-5. no original data. [pmid: 9401855].
Ruffin MT 4th, Baron J. Recruiting subjects in cancer prevention and control studies. J Cell Biochem Suppl. 2000;(34):80-3. no original data.
Schaefer KM, Ladd E, Gergits MA, et al. Backing and forthing: the process of decision making by women considering participation in a breast cancer prevention trial. Oncol Nurs Forum. 2001;28(4):703-9. other: does not address underserved populations. [pmid: 11383184].
Schatzkin A, Lanza E, Freedman LS, et al. The polyp prevention trial I: rationale, design, recruitment, and baseline participant characteristics. Cancer Epidemiol Biomarkers Prev. 1996;5(5):375-83. other: primary prevention trial. [pmid: 9162304].
Schiffman M, Adrianza ME. ASCUS-LSIL Triage Study. Design, methods and characteristics of trial participants. Acta Cytol. 2000;44(5):726-42. other: does not address underserved populations. [pmid: 11015972].
Schutta KM, Burnett CB. Factors that influence a patient's decision to participate in a phase I cancer clinical trial. Oncol Nurs Forum. 2000;27(9):1435-8. does not report a controlled trial or recruitment to a controlled trial. [pmid: 11058975].
Scott DA, Valery PC, Boyle FM, et al. Does research into sensitive areas do harm? Experiences of research participation after a child's diagnosis with Ewing's sarcoma. Med J Aust. 2002;177(9):507-10. does not report a controlled trial or recruitment to a controlled trial. [pmid: 12405895].
Segnan N, Senore C, Giordano L, et al. Promoting participation in a population screening program for breast and cervical cancer:a randomized trial of different invitation strategies. Tumori. 1998;84(3):348-53. does not report a controlled trial or recruitment to a controlled trial. [pmid: 9678615].
Seroussi B, Bouaud J. Using OncoDoc as a computer-based eligibility screening system to improve accrual onto breast cancer clinical trials. Artif Intell Med. 2003;29(12):153-67. other: does not address underserved populations. [pmid: 12957785].
Shavers VL, Lynch CF, Burmeister LF. Racial differences in factors that influence the willingness to participate in medical research studies. Ann Epidemiol. 2002;12(4):248-56. does not report a controlled trial or recruitment to a controlled trial. [pmid: 11988413].
Siminoff LA, Zhang A, Colabianchi N, et al. Factors that predict the referral of breast cancer patients onto clinical trials by their surgeons and medical oncologists. J Clin Oncol. 2000;18(6):1203-11. other: no subgroup analysis of an underserved population. [pmid: 10715289].
Simon C, Zyzanski SJ, Eder M, et al. Groups potentially at risk for making poorly informed decisions about entry into clinical trials for childhood cancer. J Clin Oncol. 2003;21(11):2173-8. does not report a controlled trial or recruitment to a controlled trial. [pmid: 12775743].
Simon MS, Brown DR, Du W, et al. Accrual to breast cancer clinical trials at a university-affiliated hospital in metropolitan Detroit. Am J Clin Oncol. 1999;22(1):42-6. other: no subgroup analysis of an underserved population. [pmid: 10025379].
Slevin M, Mossman J, Bowling A, et al. Volunteers or victims: patients' views of randomised cancer clinical trials. Br J Cancer. 1995;71(6):1270-4. other: does not address underserved populations. [pmid: 7779722].
Sorensen JB, Rossel P, Holm S. Patient-physician communication concerning participation in cancer chemotherapy trials. Br J Cancer. 2004;90(2):328-32. other: does not address underserved populations. [pmid: 14735172].
Spiro SG, Gower NH, Evans MT, et al. Recruitment of patients with lung cancer into a randomised clinical trial: experience at two centres. On behalf of the Big Lung Trial Steering Committee. Thorax. 2000;55(6):463-5. other: does not address underserved populations. [pmid: 10817793]. [pmcid: 1745775].
Strauss B. Best hope or last hope: access to phase III clinical trials of HER-2/neu for advanced stage breast cancer patients. J Adv Nurs. 2000;31(2):259-66. no original data. [pmid: 10672081].
Sugarman J, Regan K, Parker B, et al. Ethical ramifications of alternative means of recruiting research participants from cancer registries. Cancer. 1999;86(4):647-51. other: does not address underserved populations. [pmid: 10440692].
Susman EJ, Dorn LD, Fletcher JC. Participation in biomedical research: the consent process as viewed by children, adolescents, young adults, and physicians. J Pediatr. 1992;121(4):547-52. does not report a controlled trial or recruitment to a controlled trial. [pmid: 1403387].
Sutherland HJ, da Cunha R, Lockwood GA, et al. What attitudes and beliefs underlie patients' decisions about participating in chemotherapy trials?. Med Decis Making. 1998;18(1):61-9. other: does not address underserved populations. [pmid: 9456210].
Taylor KM, Kelner M. Interpreting physician participation in randomized clinical trials: the Physician Orientation Profile. J Health Soc Behav. 1987;28(4):389-400. other: does not address underserved populations. [pmid: 3429808].
Taylor KM, Margolese RG, Soskolne CL. Physicians' reasons for not entering eligible patients in a randomized clinical trial of surgery for breast cancer. N Engl J Med. 1984;310(21):1363-7. other: does not address underserved populations. [pmid: 6717508].
Taylor KM. Physician participation in a randomized clinical trial for ocular melanoma. Ann Ophthalmol. 1992;24(9):337-44. other: no barriers to an underserved group reported. [pmid: 1471822].
Trauth JM, Musa D, Siminoff L, et al. Public attitudes regarding willingness to participate in medical research studies. J Health Soc Policy. 2000;12(2):23-43. other: does not address underserved populations. [pmid: 11184441].
Tworoger SS, Yasui Y, Ulrich CM, et al. Mailing strategies and recruitment into an intervention trial of the exercise effect on breast cancer biomarkers. Cancer Epidemiol Biomarkers Prev. 2002;11(1):73-7. other: primary prevention trial. [pmid: 11815403].
Wang LD, Zheng S, Zheng ZY, et al. Primary adenocarcinomas of lower esophagus, esophagogastric junction and gastric cardia:in special reference to China. World J Gastroenterol. 2003;9(6):1156-64. no original data. [pmid: 12800215].
Weijer C, Freedman B, Shapiro S, et al. Assessing the interpretation of criteria for clinical trial eligibility: a survey of oncology investigators. Clin Invest Med. 1998;21(1):17-26. does not report a controlled trial or recruitment to a controlled trial. [pmid: 9512881].
Weinrich SP, Ellison GL, Boyd M, et al. Participation in prostate cancer screening among low-income men. Psychol Health Med. 2000;5(4):439-450. does not report a controlled trial or recruitment to a controlled trial.
Weinrich SP, Greiner E, Reis-Starr C, et al. Predictors of participation in prostate cancer screening at worksites. J Community Health Nurs. 1998;15(2):113-29. does not report a controlled trial or recruitment to a controlled trial. [pmid: 9631594].
Weinrich SP, Weinrich M, Mettlin C, et al. Urinary symptoms as a predictor for participation in prostate cancer screening among African American men. Prostate. 1998;37(4):215-22. does not report a controlled trial or recruitment to a controlled trial. [pmid: 9831217].
Winn RJ, Miransky J, Kerner JF, et al. An evaluation of physician determinants in the referral of patients for cancer clinical trials in the community setting. Prog Clin Biol Res. 1984;156:63-73. other: does not address underserved populations. [pmid: 6473453].
Woods VD, Montgomery SB, Herring RP. Recruiting black/African American men for research on prostate cancer prevention. Cancer. 2004;100(5):1017-25. does not report a controlled trial or recruitment to a controlled trial. [pmid: 14983498].
Wright JR, Crooks D, Ellis PM, et al. Factors that influence the recruitment of patients to Phase III studies in oncology: the perspective of the clinical research associate. Cancer. 2002;95(7):1584-91. other: does not address underserved populations. [pmid: 12237929].
Yancey AK, Miles OL, McCarthy WJ, et al. Differential response to targeted recruitment strategies to fitness promotion research by African-American women of varying body mass index. Ethn Dis. 2001;11(1):115-23. other: primary prevention trial. [pmid: 11289232].
Yeomans-Kinney A, Vernon SW, Frankowski RF, et al. Factors related to enrollment in the breast cancer prevention trial at a comprehensive cancer center during the first year of recruitment. Cancer. 1995;76(1):46-56. other: does not address underserved populations. [pmid: 8630876].
Yoder LH, O'Rourke TJ, Etnyre A, et al. Expectations and experiences of patients with cancer participating in phase I clinical trials. Oncol Nurs Forum. 1997;24(5):891-6. other: does not address underserved populations. [pmid: 9201741].
Yu M, Seetoo AD, Hong OS, et al. Cancer screening promotion among medically underserved Asian American women:integration of research and practice. Res Theory Nurs Pract. 2002;16(4):237-48. does not report a controlled trial or recruitment to a controlled trial. [pmid: 12643332].
Zabora JR, Morrison C, Olsen SJ, et al. Recruitment of underserved women for breast cancer detection programs. Cancer Pract. 1997;5(5):297-303. does not report a controlled trial or recruitment to a controlled trial. [pmid: 9341352].