# References and Included Articles

1 Ward E, Jemal A, Cokkinides V, et al. Cancer disparities by race/ethnicity and socioeconomic status. CA Cancer J Clin. 2004;54(2):78-93. [pmid: 15061598].
2 Singh GH, Miller BA, Hankey BF, et al. Area socioeconomic variations in U.S. cancer incidence, mortality, stage, treatment, and survival 1975-1999., NCI Cancer Surveillance Monograph Series, Number 4. Bethesda MD. National Cancer Institute, 2003. NIH Publication No. 03-5417.
3 Adler NE. A consideration of multiple pathways from socioeconomic status to health. In J. A. Auerbach & B. K. Krimgold (Eds.) Income, Socioeconomic Status, and Health: Exploring the Relationships. Washington, D. C. 2001, National Policy Association.
4 Klassen AC, Curriero FC, Hong JH, et al. The role of area-level influences on prostate cancer grade and stage at diagnosis. Prev Med. 2004;39(3):441-8. [pmid: 15313082].
5 Swan J, Breen N, Coates RJ, et al. Progress in cancer screening practices in the United States: results from the 2000 National Health Interview Survey. Cancer. 2003;97(6):1528-40. [pmid: 12627518].
6 Sambamoorthi U, McAlpine DD. Racial, ethnic, socioeconomic, and access disparities in the use of preventive services among women. Prev Med. 2003;37(5):475-84. [pmid: 14572431].
7 Jemal A, Clegg LX, Ward E, Anderson RN, Edwards BK. Annual report to the nation on the status of cancer, 1975-2001, with a special feature regarding survival. Cancer. 2004;101(1):3-27. [pmid: 15221985].
8 Jemal A, Tiwari RC, Murray T, et al. Cancer Statistics, 2004. CA Cancer J Clin. 2004;54(1):8-29. [pmid: 14974761].
9 American Cancer Society. Cancer Facts & Figures, 2004. Atalnta, GA. American Cancer Society. 2004.
10 Freeman HP. Poverty, Culture, and Social Injustice: Determinants of Cancer Disparities. CA Cancer J Clin. 2004;54(2):72-7. [pmid: 15061597].
11 Jatoi I, Becher H, Leake CR. , Widening disparity in survival between white and African-American patients with breast carcinoma treated in the U. S. Department of Defense Healthcare system. Cancer. 2003;98(5):894-9. [pmid: 12942554].
12 Royak-Schaler R, Chen S, Zang E, et al. Does access to screening through health maintenance organization membership translate into improved breast cancer outcomes for African American patients?. J Am Med Womens Assoc. 2003;58(3):154-6. [pmid: 12948106].
13 Underwood W, De Monner S, Ubel P, et al. Racial/ethnic disparities in the treatment of localized/regional prostate cancer. J Urol. 2004;171(4):1504-7. [pmid: 15017208].
14 Bach PB, Cramer LD, Warren JL, et al. Racial Differences in the Treatment of Early-Stage Lung Cancer. N Engl J Med. 1999;341(16):1198-1205. [pmid: 10519898].
15 Shavers VL, Brown ML, Potosky AL, et al. Race/ethnicity and the receipt of watchful waiting for the initial management of prostate cancer. J Gen Intern Med. 2004;19(2):146-55. [pmid: 15009794]. [pmcid: 1492143].
16 Schneider EC, Zaslavsky AM, Epstein AM. Racial Disparities in the Quality of Care for Enrollees in Medicare Managed Care. JAMA. 2002;287(10):1288-1294. [pmid: 11886320].
17 Chu KC, Lamar CA, Freeman HP. Racial disparities in breast carcinoma survival rates: separating factors that affect diagnosis from factors that affect treatment. Cancer. 2003;97(11):2853-60. [pmid: 12767100].
18 Institute of Medicine. Unequal Treatment Confronting Racial and Ethnic Disparities in Healthcare. Washington, DC. National Academic Press. 2002.
19 Institute of Medicine, The Unequal Burden of Cancer: An Assessment of NIH Research and Programs for Ethnic Minorities and the Medically Underserved. Washington, DC. National Academic Press. 1999.
20 Koff SG, Connelly RR, Bauer JJ, et al. Primary hormonal therapy for prostate cancer: experience with 135 consecutive PSA-ERA patients from a tertiary care military medical center. Prostate Cancer Prostatic Dis. 2002;5(2):152-8. [pmid: 12497006].
21 Shavers VL, Brown ML. Racial and ethnic disparities in the receipt of cancer treatment. J Natl Cancer Inst. 2002;94(5):334-57. [pmid: 11880473].
22 Weinrich SP, Boyd MD, Bradford D, et al. Recruitment of African Americans into prostate cancer screening. Cancer Pract. 1998;6(1):23-30. [pmid: 9460323].
23 Weinrich SP, Boyd MD, Weinrich M, et al. Increasing prostate cancer screening in African American men with peer-educator and client-navigator interventions. J Cancer Educ. 1998;13(4):213-19. [pmid: 9883780].
24 Barber KR, Shaw R, Folts M, et al. Differences between African American and Caucasian men participating in a community-based prostate cancer screening program. J Community Health. 1998;23(6):441-51. [pmid: 9824793].
25 Bonfill X, Marzo M, Pladevall M, et al. Strategies for increasing women participation In community breast cancer screening. Cochrane Database Syst Rev. 2001;(1):CD002943.
26 ACS, Cancer Facts & Figures for African Americans: 2003-2004. 2003, American Cancer Society: Atlanta.
27 Bach PB, Pham HH, Schrag D, et al. Primary care physicians who treat blacks and whites. N Engl J Med. 2004;351(6):575-84. [pmid: 15295050].
28 Charlson ME, Horwitz RI. Applying results of randomized trials to clinical practice: impact of losses before randomization. BMJ. 1984;289:1281-4. [pmid: 6437520]. [pmcid: 1443545].
29 Swanson GM, Bailar JC. Selection and description of cancer clinical trials participants--science or happenstance?. Cancer. 2002;9(5):950-9. [pmid: 12209677].
30 National Institutes of Health, 2003. Monitoring Adherence to the NIH Policy on the Inclusion of Women and Minorities as Subjects in Clinical Research. Available at: www4.od.nih.gov/orwh/GoldReport_2000-01.pdf. Accessed October 1, 2004
31 National Institute of Health. 1993. NIH Guidelines On The Inclusion Of Women And Minorities As Subjects In Clinical Research. Available at: http://grants.nih.gov/grants/funding/women_min/guidelines_update.htm. Accessed October 1, 2004.
32 Sateren WB, Trimble EL, Abrams J, et al. How sociodemographics, presence of oncology specialists, and hospital cancer programs affect accrual to cancer treatment trials. J Clin Oncol. 2002;20(8):2109-17. [pmid: 11956272].
33 Lovato LC, Hill K, Hertert S, et al. Recruitment for controlled clinical trials: literature summary and annotated bibliography. Control Clin Trials. 1997;18(4):328-52. [pmid: 9257072].
34 Swanson GM, Ward AJ. Recruiting minorities into clinical trials: toward a participant-friendly system. J Natl Cancer Inst. 1995;87(23):1747-59. [pmid: 7473831].
35 U.S Department of Health and Human Services. Making Cancer Health Disparities History: Report of the Trans-HHS Cancer Health Disparities Progress Review Group. 2004. Executive Summary pp. vi-vii.
36 Agency for Healthcare Research and Quality. National Health Disparities Report. U.S. Department of Health and Human Services. Rockville, MD. 2004;152 pp.
37 National Cancer Institute. Special Populations Networks for Cancer Awareness Research and Training. Available at: http://crchd.nci.nih.gov/spn/introduction/ accessed December 6, 2004.
38 National Institutes of Health. Strategic Research Plan to Reduce and Ultimately Eliminate Health Disparities. Fiscal Years 2002-2006. Executive Summary, pp. 2-4. U.S. Department of Health and Human Services. Rockville, MD.
39 Powe NR and Gary TL. Race and Research in Focus: Perspectives on Minority Participation in Health Studies: Clinical Trials Chapter. In Bettina M (Ed). 2004, American Public Health Association.
40 Grade Working Group. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295]. [pmcid: 428525].
41 Berman BA, Grosser SC, Gritz ER. Recruitment to a school-based adult smoking-cessation program: do gender and race/ethnicity make a difference?. J Cancer Educ. 1998;13(4):220-5. [pmid: 9883781].
42 Brewster WR, Anton-Culver H, Ziogas A, et al. Recruitment strategies for cervical cancer prevention study. Gynecol Oncol. 2002;85(2):250-4. [pmid: 11972383].
43 Ford M, Havstad S, Davis SD. A randomized trial of recruitment methods for older African-American Men in the Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial. Clinical Trials. 2004;1:343-51. [pmid: 16279272].
44 Kaluzny A, Brawley O, Garson-Angert D, et al. Assuring access to state-of-the-art care for U.S. minority populations: the first 2 years of the Minority-Based Community Clinical Oncology Program. J Natl Cancer Inst. 1993;85(23):1945-50. [pmid: 8230286].
45 Paskett ED, Cooper MR, DeGraffinreid CR, et al. Community clinical oncology program as a recruitment vehicle for cancer control research. The Southeast Cancer Control Consortium experience. N C Med J. 1995;56(6):283-6. [pmid: 7603584].
46 Paskett ED, Cooper MR, Stark N, et al. Clinical trial enrollment of rural patients with cancer. Cancer Pract. 2002;10(1):28-35. [pmid: 11866706].
47 Sears SR, Stanton AL, Kwan L, et al. Recruitment and retention challenges in breast cancer survivorship research: results from a multi-site, randomized intervention trial in women with early stage breast cancer. Cancer Epidemiol Biomarkers Prev. 2003;12(10):1087-90. [pmid: 14578147].
48 Thornquist MD, Patrick DL, Omenn GS. Participation and adherence among older men and women recruited to the Beta-Carotene and Retinol Efficacy Trial (CARET). Gerontologist. 1991;31(5):593-97. [pmid: 1778482].
49 Zhu K, Hunter S, Bernard LJ, et al. Recruiting elderly African-American women in cancer prevention and control studies: a multifaceted approach and its effectiveness. J Natl Med Assoc. 2000;92(4):169-75. [pmid: 10976173]. [pmcid: 2640591].
50 Advani AS, Atkeson B, Brown CL, et al. Barriers to the participation of African-American patients with cancer in clinical trials: a pilot study. Cancer. 2003;97(6):1499-506. [pmid: 12627515].
51 Maurer LH, Davis T, Hammond S, et al. Clinical trials in a rural population: professional education aspects. J Cancer Educ. 2001;16(2):89-92. [pmid: 11440069].
52 Linnan LA, Emmons KM, Klar N, et al. Challenges to improving the impact of worksite cancer prevention programs: comparing reach, enrollment, and attrition using active versus passive recruitment strategies. Ann Behav Med. 2002;24(2):157-66. [pmid: 12054321].
53 Randall-David B, Stark N, Gierisch J, et al. ‘What do they know about it?’ How the North Carolina public views cancer clinical trials: implications for primary care doctors. N C Med J. 2001;62(5):281-5. [pmid: 11570327].
54 Yee KW, Pater JL, Pho L, et al. Enrollment of older patients in cancer treatment trials in Canada: why is age a barrier?. J Clin Oncol. 2003;21(8):1618-23. [pmid: 12697888].
55 Alexander GA, Chu KC, Ho RC. Representation of Asian Americans in clinical cancer trials. Ann Epidemiol. 2000;10(8 Suppl):S61-67. [pmid: 11189094].
56 Benson AB 3rd, Pregler JP, Bean JA, et al. Oncologists' reluctance to accrue patients onto clinical trials: an Illinois Cancer Center study. J Clin Oncol. 1991;9(11):2067-75. [pmid: 1941065].
57 Goodwin JS, Hunt WC, Humble CG, et al. Cancer treatment protocols. Who gets chosen?. Arch Intern Med. 1988;148(10):2258-60. [pmid: 3178383].
58 Hunter CP, Frelick RW, Feldman AR, et al. Selection factors in clinical trials: results from the Community Clinical Oncology Program Physician's Patient Log. Cancer Treat Rep. 1987;71(6):559-65. [pmid: 3581095].
59 Klabunde CN, Springer BC, Butler B, et al. Factors influencing enrollment in clinical trials for cancer treatment. South Med J. 1999;92(12):1189-93. [pmid: 10624912].
60 Krailo MD, Bernstein L, Sullivan-Halley J, et al. Patterns of enrollment on cooperative group studies. An analysis of trends from the Los Angeles County Cancer Surveillance Program. Cancer. 1993;71(10 Suppl):3325-30. [pmid: 8490876].
61 Lewis JH, Kilgore ML, Goldman DP, et al. Participation of patients 65 years of age or older in cancer clinical trials. J Clin Oncol. 2003;21(7):1383-9. [pmid: 12663731].
62 Moinpour CM, Atkinson JO, Thomas SM, et al. Minority recruitment in the prostate cancer prevention trial. Ann Epidemiol. 2000;10(8 Suppl):S85-91. [pmid: 11189097].
63 Murthy VH, Krumholz HM, Gross CP. Participation in cancer clinical trials: race-, sex-, and age-based disparities. JAMA. 2004;291(22):2720-6. [pmid: 15187053].
64 Simon MS, Du W, Flaherty L, et al. Factors associated with breast cancer clinical trials participation and enrollment at a large academic medical center. J Clin Oncol. 2004;22(11):2046-52. [pmid: 15082724].
65 Trimble EL, Carter CL, Cain D. Representation of Older Patients in Cancer Treatment Trials. Cancer. 1994;74(7):2208-14. [pmid: 8087794].
66 Kemeny MM, Peterson BL, Kornblith AB, et al. Barriers to clinical trial participation by older women with breast cancer. J Clin Oncol. 2003;21(12):2268-75. [pmid: 12805325].
67 Schiffman M, Adrianza ME. ASCUS-LSIL Triage Study. Design, methods and characteristics of trial participants. Acta Cytol. 2000;44(5):726-42. [pmid: 11015972].
68 Christian MC, Trimble EL. Increasing participation of physicians and patients from underrepresented racial and ethnic groups in National Cancer Institute-sponsored clinical trials. Cancer Epidemiol Biomarkers Prev. 2003;12(3):277s-283s. [pmid: 12646527].
69 Adams-Campbell LL, Ahaghotu C, Gaskins M, et al. Enrollment of African Americans onto clinical treatment trials: study design barriers. J Clin Oncol. 2004;22(4):730-4. [pmid: 14966098].
70 Barofsky I, Sugarbaker PH. Determinants of patient nonparticipation in randomized clinical trials for the treatment of sarcomas. Cancer Clin Trials. 1979;2:237-46.
71 Bieniasz ME, Underwood D, Bailey J, et al. Women's feedback on a chemopreventive trial for cervical dysplasia. Appl Nurs Res. 2003;16(1):22-8. [pmid: 12624859].
72 Broome ME, Richards DJ, Hall JM. Children in research: the experience of ill children and adolescents. J Fam Nurs. 2001;7(1):32-49.
73 Broome ME, Richards DJ. The influence of relationships on children's and adolescents' participation in research. Nurs Res. 2003;52(3):191-7. [pmid: 12792260].
74 Brown DR, Fouad MN, Basen-Engquist K, et al. Recruitment and retention of minority women in cancer screening, prevention, and treatment trials. Ann Epidemiol. 2000;10(8 Suppl):S13-21. [pmid: 11189088].
75 Brown DR, Topcu M. Willingness to participate in clinical treatment research among older African Americans and Whites. Gerontologist. 2003;43(1):62-72. [pmid: 12604747].
76 Chen CI, Skingley P, Meyer RM. A comparison of elderly patients with aggressive histology lymphoma who were entered or not entered on to a randomized phase II trial. Leuk Lymphoma. 2000;38(3-4):327-34. [pmid: 10830739].
77 Comis RL, Miller JD, Aldige CR, et al. Public attitudes toward participation in cancer clinical trials. J Clin Oncol. 2003;21(5):830-5. [pmid: 12610181].
78 Diener-West M Hawkins BS Moy CSfor the Collaborative Ocular Melanoma Study Group. Sociodemographic and clinical predictors of participation in two randomized trials: findings from the Collaborative Ocular Melanoma Study COMS report no. 7 Control Clin Trials 2001 22 5 526 37 11578786
79 Fouad MN, Partridge E, Green BL, et al. Minority recruitment in clinical trials: a conference at Tuskegee, researchers and the community. Ann Epidemiol. 2000;10(8 Suppl):S35-40. [pmid: 11189091].
80 Fouad MN, Partridge E, Wynn T, et al. Statewide Tuskegee Alliance for clinical trials. A community coalition to enhance minority participation in medical research. Cancer. 2001;91(1 Suppl):237-41. [pmid: 11148586].
81 Green BL, Partridge EE, Fouad MN, et al. African American attitudes regarding cancer clinical trials and research studies: results from focus group methodology. Ethn Dis. 2000;10(1):76-86. [pmid: 10764133].
82 Grunfeld E, Zitzelsberger L, Coristine M, et al. Barriers and facilitators to enrollment in cancer clinical trials: qualitative study of the perspectives of clinical research associates. Cancer. 2002;95(7):1577-83. [pmid: 12237928].
83 Kemp N, Skinner E, Toms J. Randomized clinical trials of cancer treatment--a public opinion survey. Clin Oncol. 1984;10(2):155-61. [pmid: 6734007].
84 Kornblith AB, Kemeny M, Peterson BL, et al. Survey of oncologists' perceptions of barriers to accrual of older patients with breast carcinoma to clinical trials. Cancer. 2002;95(5):989-96. [pmid: 12209681].
85 Lee MM, Chamberlain RM, Catchatourian R, et al. Social factors affecting interest in participating in a prostate cancer chemoprevention trial. J Cancer Educ. 1999;14(2):88-92. [pmid: 10397483].
86 Lerman C, Rimer BK, Daly M, et al. Recruiting high risk women into a breast cancer health promotion trial. Cancer Epidemiol Biomarkers Prev. 1994;3(3):271-6. [pmid: 8019378].
87 Ling J, Rees E, Hardy J. What influences participation in clinical trials in palliative care in a cancer centre?. Eur J Cancer. 2000;36(5):621-6. [pmid: 10738127].
88 McCaskill-Stevens W, Pinto H, Marcus AC, et al. Recruiting minority cancer patients into cancer clinical trials: a pilot project involving the Eastern Cooperative Oncology Group and the National Medical Association. J Clin Oncol. 1999;17(3):1029-39. [pmid: 10071298].
89 Millon-Underwood S, Sanders E, Davis M. Determinants of participation in state-of-the-art cancer prevention, early detection/screening, and treatment trials among African-Americans. Cancer Nurs. 1993;16(1):25-33. [pmid: 8457983].
90 Mouton CP, Harris S, Rovi S, et al. Barriers to black women's participation in cancer clinical trials. J Natl Med Assoc. 1997;89(11):721-7. [pmid: 9375475]. [pmcid: 2608280].
91 Outlaw FH, Bourjolly JN, Barg FK. A study on recruitment of black Americans into clinical trials through a cultural competence lens. Cancer Nurs. 2000;23(6):444-51. quiz 451–2. [pmid: 11128123].
92 Pinto HA, McCaskill-Stevens W, Wolfe P, et al. Physician perspectives on increasing minorities in cancer clinical trials: an Eastern Cooperative Oncology Group (ECOG) Initiative. Ann Epidemiol. 2000;10(8 Suppl):S78-84. [pmid: 11189096].
93 Roberson NL. Clinical trial participation. Viewpoints from racial/ethnic groups. Cancer. 1994;74(9 Suppl):2687-91. [pmid: 7954287].
94 Robinson SB, Ashley M, Haynes MA. Attitude of African-Americans regarding prostate cancer clinical trials. J Community Health. 1996;21(2):77-87. [pmid: 8728357].
95 Spaight SJ, Nash S, Finison LJ, et al. Medical oncologists' participation in cancer clinical trials. Prog Clin Biol Res. 1984;156:49-61. [pmid: 6473452].
96 Twelves CJ, Thomson CS, Young J, et al. Entry into clinical trials in breast cancer: the importance of specialist teams. Scottish Breast Cancer Focus Group and Scottish Cancer Therapy Network. Eur J Cancer. 1998;34(7):1004-7. [pmid: 9849447].
97 Woods MN, Harris KJ. Ahluwalia J, et al. Participation of African Americans in a smoking cessation trial: A quantitative and qualitative study. J Natl Med Assoc. 2002;94(7):609-618. [pmid: 12126287]. [pmcid: 2594312].
98 Burhansstipanov L, Krebs LU, Bradley A, et al. Lessons learned while developing “Clinical Trials Education for Native Americans” curriculum. Cancer Control. (Sep-Oct). 2003;10(5 Suppl):29-36. [pmid: 14581902].
99 Moore DH. Ovarian cancer in the elderly patient. Oncology. 1994;8:21-25. [pmid: 7888309].
100 Fallowfield L, Ratcliffe D, Souhami R. Clinicians' attitudes to clinical trials of cancer therapy. Eur J Cancer. 1997;33(13):2221-9. [pmid: 9470810].
101 Richardson JL, Myrtle R, Solis JM, et al. Participation of community medical oncologists in clinical research trials. Prog Clin Biol Res. 1986;216:269-80. [pmid: 3523532].
102 Burack RC, Gimotty PA, George J, et al. Promoting screening mammography in inner-city settings: a randomized controlled trial of computerized reminders as a component of a program to facilitate mammography. Med Care. 1994;32(6):609-24. [pmid: 8189778].
103 Barr JK, Franks AL, Lee NC, et al. A randomized intervention to improve ongoing participation in mammography. Am J Manag Care. 2001;7(9):887-94. [pmid: 11570022].
104 Segnan N, Senore C, Giordano L, et al. Promoting participation in a population screening program for breast and cervical cancer: a randomized trial of different invitation strategies. Tumori. 1998;84(3):348-53. [pmid: 9678615].