# Acknowledgments

The Evidence-based Practice Center thanks Karen Robinson for her guidance in designing the literature search, Christine Napolitano for her assistance with literature searching and database management, Dhwani Mankad for her assistance with data entry and cleaning, and Brenda Zacharko for her assistance with data entry and final preparations of the report.