# Discussion

Since the enactment of the NIH Revitalization Act in 1993, ^31^ cancer researchers have made significant efforts to discover evidence regarding barriers to participation in clinical trials, especially for ethnic minority populations. While some advances have been made in defining these barriers, significant gaps remain in the available evidence in regard to efficacious and/or effective interventions to improve enrollment to cancer clinical trials. It is essential to address these gaps in the evidence to fulfill the intent of the NIH Revitalization Act. Only a small proportion of cancer patients are enrolled in cancer clinical trials and recent evidence indicates that racial and ethnic minorities, adolescents, the elderly, rural populations and individuals of low socioeconomic status in general, are underrepresented in NCI-funded cancer clinical trials. ^68^ We undertook a systematic review to: 1) assess existing evidence regarding barriers and promoters of participation in cancer clinical trials; 2) understand the influence of physicians' attitudes on the accrual process; and 3) gain insight into research strategies to further develop the evidence in support of interventions to improve accrual to cancer clinical trials. While African American women are not underrepresented in cancer clinical trials, we examined the evidence from that population, as it may be relevant to barriers and promoters of enrollment of African American men to cancer clinical trials.

## Questions 1 and 2. Methods to Study Recruitment Strategies

The available evidence is limited by the methods that have been used to date to study barriers and promoters of accrual to cancer clinical trials. A large proportion of the eligible studies were developed by convenience, i.e., as a way to describe investigators' experience with recruitment of underrepresented populations. The available literature included some well-designed qualitative as well as quantitative studies, including controlled clinical trials. However, the methodological limitations of the available studies leave serious gaps in knowledge and information about efficacious and effective strategies to improve participation of underrepresented populations in cancer clinical trials. These gaps must be addressed in the context of well-designed studies that are informed by the accumulated evidence.

One component missing in the literature is an agreement on what constitutes a “success measure” in terms of enrollment. The lack of agreed upon measures of success may be a key determinant of the lack of representation of certain population subgroups in accrual to cancer clinical trials. Several of the available studies offer excellent examples of approaches to characterize accrual data in a meaningful way in relation to a specific population. One approach is to obtain proportional representation relative to the U.S. population. ^32^ , ^61^ Another is to include a study population that features enrollment of population subgroups in proportion to the relative cancer incidence in each of the subgroups. In certain instances, investigators may also over-sample certain underrepresented populations in an effort to enable meaningful subgroup analyses of underrepresented groups (e.g., the proportion necessary for subgroup analysis). The planning, design, implementation, and evaluation of a recruitment strategy are integral to the successful conduct of a clinical trial. Therefore, investigators should give careful thought to success measures for recruitment of underrepresented populations, and avoid setting such measures arbitrarily. Additionally, researchers should evaluate and report recruitment results for underrepresented groups more frequently. Such reports should not be based on the aggregate experience from multiple trials, but they should be based on the recruitment strategies for individual cancer clinical trials. Using better measures of success will help investigators improve the generalizability of cancer trial results to many different populations. It will also help identify effective recruitment strategies for underrepresented populations. Moreover, success in recruitment of these populations may provide novel insights into risk factors and the natural history of disease through hypothesis-driven subgroup analyses.

## Questions 3, 4, 5, and 6. Barriers and Promoters of Participation in Cancer Clinical Trials

We developed a conceptual framework to guide our analysis of barriers and promoters of participation of underrepresented populations in cancer clinical trials. Our approach takes account of the fact that in order to participate in a clinical trial, an individual must be aware of the trial, have the opportunity to participate, and be willing to accept participation. The barriers and promoters span the continuum from awareness to acceptance, and they differ depending on the population and whether recruitment is to a treatment trial or to a prevention trial. Moreover, within cancer treatment trials, the barriers may differ when comparing early-phase trials to phase III, controlled clinical trials; however, we did not address this question because very few of the eligible studies distinguished between trial phases. While a number of publications have contributed important evidence regarding key barriers and promoters of participation in cancer clinical trial, the evidence remains limited. Based on our systematic review, the most frequently reported barriers across multiple underrepresented populations are: 1) mistrust of researchers and the medical system ^44^ , ^46^ , ^53^ , ^62^ , ^74^ , ^79^ – ^82^ , ^88^ – ^94^ , ^97^ ; 2) the perceived harms of participation in a cancer clinical trial ^46^ , ^50^ , ^53^ , ^79^ , ^81^ , ^82^ , ^89^ , ^91^ , ^92^ , ^94^ , ^97^ ; 3) the availability of transportation ^42^ , ^44^ , ^46^ , ^53^ , ^74^ , ^82^ , ^84^ , ^95^ , ^97^ ; 4) lack of education about clinical trials ^46^ , ^50^ , ^53^ , ^74^ , ^79^ , ^80^ , ^91^ – ^94^ ; and 5) the time commitment required for participation in a trial. ^42^ , ^47^ , ^53^ , ^79^ , ^81^ , ^91^ , ^93^ , ^97^ The most frequently reported promoters are: 1) patient ^80^ – ^82^ , ^93^ , ^94^ , ^97^ and provider incentives ^44^ , ^53^ , ^92^ ; 2) altruism ^50^ , ^53^ , ^72^ , ^81^ , ^82^ , ^89^ ; and 3) culturally relevant education about trials. ^88^ , ^92^ – ^94^ Consistent with our conceptual framework, these documented barriers and promoters intervene at the level of awareness about clinical trials, the opportunity to participate, and decision-making about participation in a trial.

Overall, the eligible studies identified 118 distinct barriers to accrual to cancer clinical trials, including 97 barriers to accrual to therapeutic trials, 18 barriers to accrual to prevention trials, and 32 barriers to accrual to both therapeutic and prevention trials. The studies reported included seven barriers to awareness of cancer clinical trials, 80 barriers to the opportunity to participate in a cancer trial, and 40 barriers to acceptance of enrollment. Among these, 63 barriers were relevant at the patient level, 31 at the provider level, 20 at the study design level and seven at the healthcare systems level. The available evidence suggests that barriers that reduce the opportunity to participate in a trial are the most frequent factors limiting enrollment to both cancer prevention and treatment trials, especially for the elderly and racial and ethnic minority populations. The barriers that limit accrual opportunities include study design barriers such as age, exclusion criteria (e.g., comorbidity and functional status), lack of transportation, and lack of adequate health insurance. The high frequency of opportunity barriers signals the need for interventions directed to this type of barrier.

Despite an extensive list of documented promoters of participation, we were able to identify only five studies that compared two or more interventions to improve enrollment to cancer clinical trials. These included one well-designed randomized controlled trial comparing multiple intervention strategies for accrual to the Prostate, Lung, Colorectal and Ovarian (PLCO) cancer screening trial. ^43^ In that study, we learned that a face-to-face recruitment strategy is superior to other, less intensive recruitment strategies in the context of the screening trial. However, the available evidence on efficacious strategies to improve participation in cancer clinical trials remains woefully inadequate.

The nature and extent of the barriers and promoters of accrual differ across the underrepresented populations. For example, while the elderly have access to Medicare, many clinical trials remain functionally inaccessible to this population, because of study design barriers, including age restrictions, as well as provider fears about drug toxicity, that in many instances may be unsubstantiated. ^104^ For adolescents, ^60^ , ^72^ the major barrier is the lack of accessible trials; and for rural populations, transportation is a major barrier. ^46^ , ^53^ For African-American ^32^ , ^41^ , ^43^ , ^47^ , ^50^ , ^58^ , ^62^ , ^64^ , ^66^ , ^69^ – ^71^ , ^74^ , ^75^ , ^79^ – ^81^ , ^85^ , ^86^ , ^88^ – ^94^ , ^97^ and Latino/Hispanic populations ^32^ , ^41^ , ^42^ , ^62^ , ^66^ , ^74^ , ^93^ there are identifiable barriers through the continuum from awareness to acceptance of participation. However, we found no available evidence on barriers and promoters of enrollment to cancer clinical trials for the Asian and Pacific Islander population, and only one for the American Indian and Alaska Native population. ^93^ Strategies for acquiring evidence to improve participation of underrepresented populations in cancer clinical trials must be informed by this diversity of barriers and promoters, and gaps in available evidence. Moreover, because of the overlap across the identified underrepresented populations and the geographic dispersion and cultural heterogeneity within each of the underrepresented populations, interventions to improve accrual to cancer clinical trials will need to be tailored to the cultural background of the targeted population and grounded in the local reality.

Overall, the mixed results of the interventions mentioned in these studies denote a continuing need for future evaluations of additional recruitment interventions, including clinical trials that compare the relative efficacy of promising interventions to improve accrual. This lack of consistency also reflects the limitation of available studies on specific populations in varying locations.

So, given the extensive list of barriers and promoters and the heterogeneity of the underrepresented populations, where do we begin? Clearly, it would be difficult to address each of the types of identified barriers individually, considering that each individual targeted for enrollment is likely to present multiple barriers to participation. Since the available evidence indicates that certain barriers may be universal, strategic interventions directed at some of the most frequent barriers may indeed be efficacious, effective and cost-effective, to improve cancer clinical trial enrollment. However, investigators must approach this issue with caution, given the uncertainty regarding the available evidence. Future research studies should give consideration to system-level interventions to address multiple barriers and promoters, with tailoring based on known, culturally specific, as well as patient-identified barriers. Several of the eligible studies recommended the use of personnel who are known to the community, in efforts to improve accrual to cancer clinical trials. Such individuals can be trained to promote awareness about cancer clinical trials in the community and to identify and solve barriers for individual patients in collaboration with the research team. The efficacy and cost-effectiveness of this approach needs to be evaluated further as a comprehensive solution for barriers to accrual to cancer clinical trials. In addition, the research designs should emphasize interventions that have a high likelihood of institutionalization, through their integration into the routine conduct of cancer clinical trials in comprehensive cancer centers, cancer research centers, and in the wider community. Indeed, the evaluation of the relative cost-effectiveness of different intervention strategies to improve accrual to cancer clinical trials is a serious gap that will need to be addressed in future studies.

For several of the eligible publications, the primary outcome variable in regard to trial accrual was behavioral intention, rather than actual participation in a cancer clinical trial. ^50^ , ^53^ , ^71^ – ^75^ , ^77^ , ^79^ – ^85^ , ^88^ – ^95^ Primary prevention, chemoprevention and screening trials target individuals who do not have disease, and studies of attitudes and behavioral intention toward participation in clinical trials have been used in preparation for both cancer prevention trial, and for the implementation of educational campaigns to improve accrual to clinical trials. The literature provides few examples of translation of the results of studies of behavioral intention to participate in clinical trials into studies of accrual to therapeutic trials. It remains unclear whether behavioral intention expressed by individuals at risk for cancer is a good predictor of actual participation in cancer treatment trials. This is particularly salient when viewed within the context of the change in perceived risks to cancer and the immediacy of the perceived risks and benefits of trial participation following the diagnosis of cancer. To develop the evidence needed to improve accrual strategies for cancer therapeutic trials, investigators will need to use studies of behavioral intention to prepare and refine recruitment intervention strategies that would eventually be applied to patients, and emphasize studies of accrual to actual trials.

The evidence suggests that special attention needs to be given to the barriers to participation in cancer clinical trials at the physician level. Clinicians form relationships with patients before they are diagnosed with cancer and they play an influential role in advising patients regarding participation in a trial. However, they often have limited awareness about opportunities to participate in trials, the trials often do not make sense to them from a fiscal point of view, and for elderly patients, some providers have serious concerns about the risks of participation in cancer clinical trials. Like cancer patients and individuals at risk for cancer, healthcare providers base their decisions on the balance of risks and benefits of trial participation, as well as their individual and organizational interests. While several studies have suggested the use of provider incentives ^44^ , ^53^ , ^92^ as a strategy for improving trial accrual, this idea has not received the appropriate level of attention in the available evidence. Here again, given the heterogeneity of clinical practice contexts, intervention strategies must be adapted to this context and have a high likelihood of being sustainable.

## Limitations

This systematic review addresses barriers and promoters of participation to cancer clinical trials among populations that have been underrepresented in NCI-funded cancer clinical trials, namely, the elderly, adolescents, African Americans, Latinos/Hispanics, American Indians/Alaska Natives, rural populations and populations of low socioeconomic status in general. There is extensive overlap across these populations, and the population descriptions in the available studies may not always have captured the extent of such overlap, in terms of race/ethnicity, residence, socioeconomic status, or even age.

Our search strategy included strict eligibility criteria, and it is possible that some relevant evidence was not included in the review. We found several articles that did not meet our initial eligibility criteria, but that contained important information regarding barriers and promoters of accrual to cancer clinical trials. ^76^ , ^82^ , ^83^ , ^87^ , ^96^ For this reason, although the eligible articles were initially limited to U.S.-based studies, we included some relevant evidence from non-US based studies.

We found some excellent examples of well-designed studies of enrollment to cancer screening programs, ^102^ , ^103^ , ^104^ but the systematic review was limited to studies about recruitment of patients into cancer clinical trials. Nevertheless, we believe that some of the strategies that have been used in those programs may be relevant, especially to enrollment strategies for cancer prevention and screening trials.

Within cancer treatment trials, the barriers may differ when comparing early-phase trials to phase III, controlled clinical trials. However, we did not find enough evidence to specifically address this question.

We have pointed out some of the limitations of the available evidence in regard to: 1) representativeness; 2) justification of study methods; 3) reliability and validity of data collection methods; 4) the potential for bias/confounding; and 5) data analysis. We used a standardized approach to generate the body of evidence that is presented in this review, and although individually some of the studies limit our ability to reach firm conclusions, the sum of the evidence and its consistency across multiple studies allow us to formulate some recommendations for future research.

## Conclusions

The results of many of the studies that we reviewed necessitate cautious interpretation, due to limitations of the study designs and settings, and the limited quality of a large proportion of the available publications. However, the available studies have generated, and in a few instances tested, hypotheses about determinants of accrual to cancer clinical trials. In addition, they have provided evidence for a large number of barriers and promoters of participation, some barriers and promoters being consistent across multiple studies and across underrepresented populations.

Our search yielded limited information on certain populations, most notably the Asian/Pacific Islander, American Indian/Alaska Native, Latino/Hispanic, rural, and adolescent populations. This limits the depth of possible recommendations for these populations. Similarly, there is a continuing need for evidence of interventions that work for African-American men. Moreover, the evidence base needs to address how sociodemographic and cultural norms, values, and beliefs modify the known barriers. This is strongly suggested by the available evidence, but it is not defined.

We found very few studies comparing two or more strategies in regard to their efficacy to increase accrual of underserved populations to cancer clinical trials. ^41^ , ^43^ , ^45^ , ^52^ , ^62^ This is an important gap in the evidence base that must be overcome.

Overall, the grade of the evidence on barriers and promoters of accrual of underserved populations to cancer clinical trials is low. However, the consistency of some of the barriers and the sheer number of barriers suggest the need for evidence-based interventions to address multiple barriers to accrual to cancer clinical trials.

We recognize that even if members of underrepresented populations do participate in cancer clinical trials, and reporting and recruitment are adequate, the benefits of clinical trial knowledge may not translate into improved cancer outcomes for these populations due to other factors. If systemic inequities in the healthcare delivery system persist, including in access to high quality care, the availability of perfect research data may not benefit underrepresented populations so much as other populations. ^5^ Therefore, recruitment efforts to cancer clinical trials must interface with other ongoing initiatives designed to address cancer health disparities through discovery, development, and delivery, and to overcome the critical disconnect between discovery and development on the one hand, and delivery of cancer care on the other.

## Recommendations and Research Opportunities

- Much of the available body of evidence was developed as “evidence by convenience” in the context of recruitment difficulties, or in retrospective analyses of recruitment of underrepresented populations across multiple clinical trials. There is a need for well-designed, controlled studies of strategies to improve accrual to cancer prevention and treatment trials. These studies should be hypothesis-driven, and include defined measures of success. They should also meet the usual standards of the NIH peer review process.
- Investigators should give careful thought to success measures for recruitment of underrepresented populations, and they should avoid setting such measures arbitrarily. Additionally, researchers should evaluate and report recruitment results for underrepresented groups more consistently.
- More attention should be focused on issues of trial design. If studies are not designed to address problems that are relevant to patients in underserved communities, then even the best recruitment strategies will be ineffective. Similarly, trials that exclude patients with chronic conditions will preferentially exclude the elderly, members of minority groups, and patients with lower socioeconomic status, because they are more likely to have chronic conditions. Hence, recruitment efforts must proceed hand-in-hand with initiatives to design relevant and pragmatic trials.
- Because of many underrepresented populations' mistrust of researchers and of research institutions, research efforts to improve participation of underrepresented populations in cancer clinical trials should be developed within the framework of community-based participatory research, with community involvement through all phases of the research.
- The need remains for community-based studies to understand barriers to accrual in the community, including attitudes toward clinical trial participation. Whenever possible, such studies should be linked to the implementation of cancer clinical trials, and include actual recruitment as a major outcome. For example, several studies have suggested culturally relevant education as a strategy for improving accrual to cancer clinical trials. There is a need to further investigate the efficacy of culturally relevant education as a strategy to improve accrual to cancer prevention trials, and treatment trials.
- There is an urgent need to understand why participation of the Asian / Pacific Islander, and American Indian/Alaska Native populations in cancer clinical trials is minimal to non-existent. Studies of barriers and promoters of their participation should be linked to opportunities to participate. New research initiatives in this area may require several years before they are fruitful in terms of trial enrollment results.
- Similarly, there is a continuing need to better understand and improve upon strategies for recruitment of African American males and Latinos/Hispanics into cancer clinical trials. Ideally, such studies should include documentation of existing barriers within a population as a basis for tailored interventions across the spectrum of barriers and promoters, including awareness, opportunity and decision-making.
- There is a need for further investigation of effective communication strategies, including investigations on the best approach to deliver information about clinical trials, both at the community level and at the point of interaction with the potential participant.
- In communities lacking established efforts to promote awareness about clinical trials, sufficient time should be allowed for relationships to be built with community members, including community-based providers, before accrual can begin. The period for building such relationships may take several years, but it would vary depending on the community and the existing relationships prior to an intervention.
- Some interventions (e.g., media-based strategy for Latina/Hispanic women) have been shown to be effective in increasing accrual to clinical trials. Such interventions should be replicated, for use in recruitment to different types of cancer trials, and where appropriate, the results should be disseminated widely.
- To advance the evidence regarding efficacious strategies for improving enrollment to cancer clinical trials, recruitment intervention studies will need to be linked to one or more clinical trials, depending on sample size requirements. The studies should include collection of baseline information regarding prevalent risk factors in the study population. Systematic data collection about barriers and promoters of trial participation should be linked to concrete plans for designing interventions to address such barriers. Moreover, the next generation of studies of barriers and promoters of accrual should be multidisciplinary, including the involvement of community-based participatory researchers, social and behavioral scientists, as well as health economists.
- There are many barriers to care, and it is unlikely that piecemeal strategies to address these barriers will be effective to promote participation in cancer clinical trials. There is a need for a cost-effective strategy to address barriers to care on multiple levels, and in a manner that can be integrated into the context of the healthcare system and of the research team. To facilitate the integration of recruitment interventions into healthcare systems, especially the research team, a study should compare the efficacy of a recruitment intervention specialist to that of usual, opportunistic recruitment practices. The recruitment intervention specialist would be a professional or paraprofessional staff member who is appropriately trained to promote awareness about clinical trials in the community and to help patients overcome barriers to opportunity. Ideally, the recruitment intervention specialist would be indigenous to, or at least have extensive familiarity with, the community targeted by the recruitment effort. Thus, this role would be analogous to that of a patient navigator for clinical trials, and its cost-effectiveness should be investigated.
- Research to improve enrollment of underrepresented populations in cancer clinical trials must interface with other ongoing initiatives designed to address cancer health disparities through discovery, development, and delivery, and to overcome the critical disconnect between discovery and development on the one hand, and delivery of cancer care on the other.
- Substantial resources will need to be dedicated to research efforts to build upon the existing evidence on strategies for improving enrollment of underrepresented populations in cancer clinical trials. Many of the initiatives that contributed to the available evidence were probably not funded. NCI should dedicate adequate funds for well-designed studies of barriers and promoters of accrual to cancer clinical trials.