# Results

## Results of Literature Search and Abstract Review Process

Results from the search and the abstract review process were maintained in a database developed in ProCite. A summary of the results of the search and review process is provided in Figure 2.

Of the 4451 citations retrieved by the search methods, 341 were duplicates leaving 4110 for title review. Of these, 1089 were reviewed at the abstract level. Two hundred eighteen articles were identified as eligible for full article review through the abstract review process.

Because many articles had more than one reason to be excluded the abstract reviewers did not need to agree on the main reason for applied at the abstract level. The most frequent reason for exclusion was that the article did not report a controlled trial or discuss recruitment to a controlled trial (used by one or both reviewers to delete 460 abstracts). The next most frequent reason for exclusion was that the article contained no original data (used by one or both reviewers to delete 173 abstracts).

## Results of Article Review Process

From the abstract review process, 218 citations were identified for inclusion in the article review phase. At the article review level 151articles (70 percent) were excluded. The most frequent reasons for exclusion were that the article did not address an underrepresented population (69 articles, 45 percent), the article did not report on a controlled trial (36 articles, 24 percent), or there was no subgroup analysis (16 articles, 11 percent). A listing of excluded articles with the reasons for exclusion is included in this report.

Of the 67 articles included in this report, Key Question 1 was addressed by 13 articles, and Key Question 2 was addressed by 23 articles. Both Key Questions 3 and 4 were addressed by small numbers of articles (one and four respectively). For this reason, and the similarity of questions, the results of these two questions were combined (five total). Key Question 5 was addressed by 45 articles with questions 5a and 5b addressed by 30 and three articles respectively. Key Question 6 was addressed by 10 articles.

## Key Question 1: What Methods Have Been Used to Study Strategies to Recruit Underrepresented Populations into Cancer Prevention and Treatment Trials?

### Identification of Relevant Articles

As indicated in Figure 2, we found 13 studies that were relevant to this question. Details about these studies are shown in Table 1, and Evidence Tables 1-1, 1-2, and 1-3 in Appendix F.^b^

Note: Appendices cited in this report are provided electronically at: http://www.ahrq.gov/clinic/epcindex.htm

### Study Characteristics

All 13 studies were of U.S. origin, and most were based in a community setting. ^41^ – ^49^ Studies by Advani et al. and Mauer et al. ^50^ , ^51^ were hospital-based, with Advani et al. involving outpatients and Mauer et al. involving inpatients. One study ^52^ was set in the workplace or workers' homes. The specific setting for one study was unclear. ^53^ The reported target population for all of the studies was patients/participants except one study ^44^ where the target population was patient /participants and physicians. Three studies ^45^ , ^46^ , ^49^ targeted physicians only. The reported study designs in all studies varied. A randomized controlled trial was the reported study design for two studies. ^43^ , ^52^ One study was quasi-experimental, ^41^ and two studies compared two or more interventions. ^42^ , ^46^ Descriptive study designs were used in four studies. ^44^ , ^47^ – ^49^ One study used a survey design, ^50^ and another employed a qualitative design. ^53^ One used a case study design. ^51^

These studies dealt with a range of cancers. A few investigated trials for a specific cancer; for example, breast cancer was specified in three studies, ^46^ , ^47^ , ^50^ and lung cancer was specified in three. ^43^ , ^48^ , ^52^ The balance of the studies dealt with multiple types of cancer. Two reported a general focus that included all cancers. ^53^ One investigated trials for any cancer type where there was an active protocol. ^44^

Four studies did not report the dates on which recruitment into the study started or ended. ^49^ , ^50^ , ^52^ , ^53^ The recruitment ending date for one of the studies was reported as ongoing. ^45^ All of the studies investigated the effectiveness of methods or the delineation of barriers to recruitment of individuals into trials (Evidence Table 1-1, see Appendix F).

### Target Population Characteristics

Of the 13 eligible studies, six reported mean age, ^42^ , ^43^ , ^46^ , ^47^ , ^52^ , ^53^ which ranged from 43 years to 62 years (see Evidence Table 1-2 in Appendix F). Within each of these studies the actual age range of participants was quite wide. For example, Brewster et al. reported a within-study range of 17 to 78 years of age. ^42^ Five studies reported an age range. ^42^ , ^43^ , ^48^ , ^49^ , ^53^ The reported age range in four of these studies was narrower than it was for Brewster et al. ^42^

Only eight studies reported the gender of the participants. ^41^ – ^43^ , ^46^ , ^48^ , ^49^ , ^52^ , ^53^ Four studies reported that the majority of participants were male. ^43^ , ^46^ , ^50^ , ^52^ The studies did not report usable information about the income or education levels of participants.

Information regarding the racial or ethnic distributions of the participants was available for only a few of these studies. Four studies reported that 6 percent, 100 percent, one percent, and 100 percent, respectively, of participants were African American. ^41^ , ^43^ , ^47^ , ^54^ Sears et al. reported that 9 percent of participants were Asian/Pacific Islanders, ^47^ and Advani et al. reported that 33 percent of its participants were American Indian. ^50^ Sears et al. reported that 85 percent of participants in their study were Caucasian. ^47^ In other studies, Advani et al and Randall-David et al. reported 67 percent and one percent of participants as Caucasian. ^50^ , ^53^ Brewster et al. and Berman et al. reported that one percent of their participants were Latino/Hispanic. ^41^ , ^42^ None of the studies reported having any adolescent participants. Ford et al., Zhu et al., and Thornquist et al. reported that the proportions of their participants who were elderly were 100 percent, one percent, and 25 percent, respectively. ^43^ , ^49^ , ^48^ Over one-third (38 percent) of the participants in the study by Ford et al. reported low socioeconomic status. ^43^ Approximately 64 percent of the participants in the study by Advani et al. were from a rural area. ^50^ Three other studies reported that one percent of their participants were from rural areas. ^46^ , ^51^ , ^53^

### Recruitment Methods Findings

All but two of the studies defined successful recruitment into cancer-related controlled trials as actual participation of the targeted group ^50^ , ^53^ (Evidence Table 1-3, see Appendix F), and none of the studies set a priori recruitment goals. Eight of the studies reported recruitment start and end dates, ^41^ – ^44^ , ^46^ – ^48^ , ^51^ with the average reported time spent on recruitment being 33 months. Advani et al. defined successful recruitment as participants' willingness to participate in the study and not their actual participation. ^50^ We defined “methods” broadly as methods used to a) study recruitment, b) design the studies, c) identify the target populations, and d) recruit individuals into the clinical trials. Seven studies did not report the method used to design their recruitment strategies. ^43^ , ^44^ , ^47^ , ^48^ , ^51^ , ^52^ The primary outcomes of the studies varied and could be organized into primary, secondary, or tertiary categories. Linnan et al. and Zhu et al. were primary prevention projects. ^49^ , ^52^ One study was a survivorship/recurrence-prevention project, ^45^ and two were chemoprevention studies. ^44^ , ^48^ Each of the 13 studies initially mailed letters to recruit participants as part of the overall recruitment strategy. In addition to these mailings, telephone calls and fliers or posters strategically placed around the worksite or community were used in an attempt to recruit participants into the studies. One study advertised in community and regional newspapers that served as an important source of information for the area's Spanish speaking population. ^42^ These advertisements were printed in both English and Spanish. This study also used the local Spanish language television station, faith-based organizations, mental health facilities, and free clinic facilities in an attempt to get people to participate. One study used third party insurers to enlist participants. ^48^ Four studies also enlisted the assistance of physicians to recruit participants into their project. ^44^ – ^46^ , ^48^ Incentives, both monetary and material, were used in Paskett et al. ^45^ One study enlisted the aid of local businesspersons to help in the recruitment of participants. ^43^ Finally, none of the studies reported having set a goal for recruiting a specific percentage of participants before the start of the study.

## Key Question 2: What Measures of Success Have Been Used to Evaluate the Efficacy and/or Effectiveness of Strategies for Recruitment of Underrepresented Populations into Cancer Prevention and Treatment Trials?

### Identification of Relevant Articles

As indicated in Figure 2, we found 23 studies that were relevant to this question (see Table 2). Details about these studies are shown in Evidence Tables 2-1, 2-2, and 2-3, Appendix F.

Table 2 Studies about Measures of Success used to Evaluate the Effectiveness of Strategies for Recruitment of underrepresented Populations into Cancer Prevention and Treatment Trials (Key Question 2)

Author, Year | Country | Mean Age, y (Range) | % Male | % Under-represented group(s) | Study Setting | Target Population | Study Design | Type of Cancer Studied | Was Recruitment Goal Stated a Priori (Y/N). If yes, what was goal (in %)? | Recruitment Success Measure | For Which Underserved Group was Measure of Success Used?
Treatment Trials
Benson, 1991 | U.S. | NR | NR | 10% AA; 6% Lat/Hisp; 51% elderly | Clinical Trials Cooperative Group (1839 hospitals, 194 universities) | Patients/ Participants | Cross-sectional; Retrospective | All | NA | Disease-specific proportion in U.S. | AA; Lat/Hisp
Goodwin, 1988 | U.S. | 53 | NR | 15% elderly | SWOG | Patients/ Participants | Cross-sectional; Retrospective | All | NA | Researcher set: New Mexico non-SWOG cancer trials proportion of underserved groups | Elderly
Hunter, 1987 | U.S. | NR | 43 | 4% AA; 3% Lat/Hisp | Hospital inpatient; Hospital outpatient; | Patients/ Participants | Cross-sectional; Retrospective | All | NA | Disease-specific proportion in U.S.: Compared CCOP participation to SEER data from 1973-1977 | AA; Elderly
Kaluzny, 1993 | U.S. | NR | NR | | Community; Hospital outpatient; Group practice | Patients/ Participants; Physicians | Descriptive | All | NA | Researcher set: Proportion of minority-based CCOP eligible patients compared to annual proportion of CCOP eligible patients who entered trials from 1985-89 | AA; Lat/Hisp
Kemeny, 2003 | U.S. | 48 (young group), 74 (older group) | 0 | 50% elderly | Community | Patients/ Participants | Case-control | Breast | NA | Researcher set: Proportion underserved offered a cancer trial | Elderly
Kladbunde, 1999 | U.S. | NR | 29 | 29% AA | CCOP, Hospitial inpatient | Patients/ Participants | Retrospective | All | NA | Research institution proportion | AA
Lewis, 2003 | U.S. | | | 32% elderly | NCI cooperative groups | Patients/ Participants | Cross-sectional; Retrospective | All | NA | Disease-specific proportion in U.S. | Elderly
Maurer, 2001 | U.S. | NR | | 100% rural | Hospital inpatient | Patients/ Participants | Case series | Breast, colon, rectum, lung, prostate | No elderly goal, Yes-rural goal; 40% of incident cancer cases & 54% would be eligible | Researcher set: proportion underserved based upon elements from another study for rural and proportion underserved participated in trial for elderly | Elderly, rural
Murthy, 2004 | U.S. | NR (30–57) | 32 | 9% AA; 2% Asian/PI; 3% Lat/Hisp; 32% elderly | Hospital inpatient; Hospital outpatient | Patients/ Participants | Cross-sectional; Retrospective | Breast, colorectal, lung, prostate | NA | Disease-specific proportion in U.S. | AA; Asian/ PI; Lat/Hisp; Elderly
Paskett, 2002 | U.S. | 47 | 87 | 100% rural | Community | Physicians | CCT | Breast , colorectal | No | Researcher set: Proportion underserved enrolled pre and post intervention | Rural
Trimble 1994 | U.S. | NR | NR | 100% elderly | All NCI-sponsored trials in 1992 | Patients/ Participants | Descriptive; Retrospective | Lung, prostate, colorectal, pancreas, leukemia, ovarian, breast | NA | Disease specific proportion in U.S. | Elderly
Yee, 2003 | Canada | NR | NR | 22% elderly | Canada NCIC CTG treatment trials & U.S. SWOG treatment trials | Patients/ Participants | Cross-sectional; Retrospective | All | NA | 1) Disease-specific proportion in Canada. 2) Researcher set: proportion underserved compared to U.S SWOG cancer treatment trial rates. | Elderly
Prevention Trials
Berman, 1998 | U.S. | NR | 49 | 85% Lat/Hisp; 15% AA | Community | Patients/ Participants | Quasi-experimental | Smoking cessation | No | Geographic representation: proportion underserved group in school district. | Lat/Hisp, AA
Brewster, 2002 | U.S. | 43 (17–78) | 0 | 78% Lat/Hisp; 39% low annual income | Community; Hospital outpatient | Patients/ Participants | CCT | Cervical | No | Researcher set: Proportion underserved that agreed to participate in study | Lat/Hisp
Ford, 2004 | U.S. | 63 (55–74) | 100 | 100% AA; 100% elderly; 38% low SES | Community | Patients/ Participants | RCT | Prostate, lung, colorectal | No | Researcher set: 1)Proportion enrolled compared to enrollment in the standard recruitment arm and 2)proportion enrolled in another geriatric study | AA
Linnan, 2002 | U.S. | 43 | 53 | 6% Lat/Hisp; 27% low annual income | Work site; Workers homes | Patients/ Participants | RCT | Lung | NA | Researcher set: Proportion underserved eligible for trial | Low SES; persons with high school education or less
Moinpour, 2000 | U.S. | NR (51–91) | 100 | 4% AA; 3% Lat/Hisp | Hospital outpatient; NCI Compre-hensive Cancer Center | Patients/ Participants; Researchers | Descriptive | Prostate | Yes; 8% AA | Geographic representation: U.S. Proportion underserved | AA
Schiffman, 2000 | U.S. | 27 (18–81) | NR | 31% AA; 2% AIAN; 3% Asian/PI; 5% Lat/Hisp | Community; Group practice | Patients/ Participants | Descriptive | Cervical | No | Researcher set: Proportion underserved enrolled in the trial | AA
Thornquist, 1991 | U.S. | NR (45–74) | 53 | 23% elderly | Community | Patients/ Participants | Descriptive; Retrospective | Lung | No | Researcher set: Wanted enough elderly participants to evaluate them in study. Also wanted equal participation in 5-year age groups. | Elderly
Zhu, 2000 | U.S. | NR (65–85+) | 0 | 100% AA; 100% elderly; 91% low annual income | Community | Physicians | Qualitative | Breast | No | Researcher set for African-American elderly women: Authors noted participation rates were high, compared to other study with participation rate 20–48% | AA; Elderly
Both Prevention and Treatment Trials
Alexander, 2000 | U.S. | NR | 41 | 1.9% Asian/PI, 26% elderly | All NCI-sponsored trials from 1994 to 1998 | Patients/ Participants | Cross-sectional; Retrospective | All | NA | Disease-specific proportion in U.S. for Asian/PI; Researcher set for elderly: proportion younger Asian/PIs in the NCI-supported treatment trials | Asian/ PI; elderly
Krailo, 1993 | U.S. | NR (0–19) | NR | 33% adolescent | Hospital inpatient; Hospital outpatient | Patients/ Participants | Cross-sectional; Retrospective | All | NA | Disease-specific proportion in county: proportion underserved with cancer in county | Adolescents
Simon, 2004 | U.S. | 55 | 0 | 32% AA | NCI Compre-hensive Cancer Center | Patients/ Participants | Descriptive | Breast | No | Disease-specific proportion: proportion underserved group with cancer(taken from the SEER database) in Detroit | AA; Elderly

AA = African American

CCOP = Community Cooperative Oncology Program

CCT = Concurrent controlled trial

CTG = Clinical Trials Group

Lat/Hisp = Latino/Hispanic

NA = not applicable

NCI = National Cancer Institute

NCIC = Cancer Institute of Canada

NR = Not reported

PI = Pacific Islander

SEER = Surveillance, Epidemiology, and End Results Program

SES = Socioeconomic status

SWOG = Southwest Oncology Group

### Study Characteristics

All studies except one were from the United States. ^54^ Twelve of the studies were reviews of multiple cancer clinical trials and, therefore, had multiple study settings. ^44^ , ^55^ – ^65^ Nine of the studies occurred in a community setting ^41^ – ^44^ , ^46^ , ^48^ , ^49^ , ^66^ , ^67^ and seven involved a hospital center ^42^ , ^44^ , ^51^ , ^58^ – ^60^ , ^63^ . Twenty studies targeted patients/participants for the recruitment intervention ^41^ – ^44^ , ^48^ , ^51^ , ^52^ , ^54^ – ^61^ , ^63^ – ^67^ , two studies targeted physicians, and one study targeted patients/participants and researchers. ^62^ Most of the study designs to evaluate recruitment success were descriptive ^48^ , ^54^ – ^61^ , ^63^ , ^65^ presenting recruitment results of a retrospective review of multiple cancer trials (n=11), ^48^ , ^54^ – ^61^ , ^63^ , ^65^ descriptive studies of enrollment into a cancer clinical trial (n=4), ^44^ , ^62^ , ^64^ , ^67^ or a description of enrollment into a cancer trial using a survey, qualitative, or quasi-experimental study design (n=2). The rest of the study designs were two controlled clinical trials, ^42^ , ^46^ two randomized controlled trials, ^43^ , ^52^ a case-control study, ^66^ and a case series. ^46^

Nine studies evaluated recruitment into any cancer trial ^44^ , ^54^ – ^61^ ; the remaining studies evaluated recruitment success for trials on breast cancer (n=6), ^46^ , ^49^ , ^51^ , ^63^ – ^65^ colorectal cancer (n=5), ^43^ , ^46^ , ^51^ , ^63^ , ^65^ prostate cancer (n=5), ^43^ , ^51^ , ^62^ , ^63^ , ^65^ lung cancer (n=5), ^48^ , ^51^ , ^52^ , ^63^ , ^65^ or cervical cancer (n=2). ^42^ , ^67^ Sixteen of the studies evaluated recruitment or reviewed active trial enrollment during the 1990s. ^41^ – ^44^ , ^46^ , ^51^ , ^54^ , ^55^ , ^56^ , ^59^ , ^61^ – ^65^ , ^67^ Three studies reported that recruitment/enrollment began in the 1980s, ^48^ , ^58^ , ^60^ one in the 1950s ^57^ ; three did not report when recruitment began. ^49^ , ^52^ , ^66^ The studies evaluating recruitment success were cancer treatment trials alone (n=14), ^44^ , ^46^ , ^51^ , ^54^ , ^56^ – ^59^ , ^61^ – ^66^ cancer prevention trials alone (n=7), ^41^ – ^43^ , ^48^ , ^49^ , ^52^ , ^67^ or involved treatment and prevention trials (n=2) ^55^ , ^60^ (see Evidence Table 2-1 in Appendix F).

### Target Population Characteristics

For the eligible studies reporting mean age, the majority of the participants were middle-aged adults with a mean age between 40 to 60 years old. ^42^ , ^46^ , ^52^ , ^57^ , ^64^ , ^66^ The age range when documented was mostly between 40 and 80 years. ^42^ , ^43^ , ^48^ , ^49^ , ^62^ , ^63^ Three studies evaluating cervical cancer, smoking cessation and adolescent participation in clinical trials had a lower mean age from 20 to 40 years. ^41^ , ^60^ , ^67^ The gender distribution varied across studies from 0 to 100 percent male. Four studies reported information on low socioeconomic status or low annual income (less than $30,000 per year) ^42^ , ^43^ , ^52^ , ^49^ while four studies reported having greater than 45 percent of participants with a high school education or less. ^41^ , ^49^ , ^52^ , ^66^

In these studies, we found that the percentage of study subjects who were in underrepresented groups varied widely: elderly (ranged from 15 to 100 percent with the majority ranging from 20 to 50 percent), ^43^ , ^48^ , ^49^ , ^54^ , ^56^ , ^57^ , ^61^ , ^63^ , ^65^ , ^66^ African Americans (ranged from 4 to 100 percent with the majority between 4 to 30 percent), ^41^ , ^43^ , ^49^ , ^56^ , ^63^ , ^64^ , ^67^ Latinos/Hispanics (ranged from 3 to 85 percent with the majority ranging from 3 to 6 percent), ^41^ , ^42^ , ^52^ , ^56^ , ^58^ , ^63^ , ^67^ Asian /Pacific Islanders (ranged from 2 to 3 percent), ^63^ , ^67^ American Indians/Alaska Natives (0 to 2 percent), ^67^ rural (100 percent in both articles evaluating rural populations), ^46^ , ^51^ adolescents (ranged from 21 to 33 percent), ^60^ and low socioeconomic status/low annual income (27 to 91 percent with the majority between 27 to 39 percent) ^42^ , ^43^ , ^51^ , ^52^ (see Evidence Table 2-2 in Appendix F).

### Recruitment Goals and Measures of Success

All studies defined recruitment as actual participation in a cancer trial. Only two articles reported having a specific recruitment goal for the underrepresented group prior to enrollment in the study. One was a goal for the rural population based on the recruitment results of a prior study, ^51^ and the other was a goal for African American men 55 years old or older based on geographic representation (i.e. percent African American elderly men in the U.S.). ^62^ The study by Maurer et al on rural populations met this recruitment goal while the Moinpour et al. study on African Americans did not, recruiting 4 percent instead of 8 percent. ^51^ , ^62^

Recruitment success was defined differently depending on the study. To better evaluate the recruitment success measures, we grouped them into four different categories: 1) geographic proportion underrepresented (i.e., proportion of U.S. population in an underrepresented group); 2) disease-specific proportion underrepresented (i.e., proportion underrepresented with cancer or a specific type of cancer in a geographic area such as the U.S.); 3) proportion underrepresented selected by the researcher for various reasons (e.g., statistical power, convenience, or data from prior studies); and 4) research institution's proportion underrepresented (i.e., proportion of population in the institution that was in an underrepresented group).

Most of the studies defined recruitment success as equaling the proportion underrepresented that was selected by the researcher for various reasons such as convenience (n=13), ^42^ – ^44^ , ^46^ , ^48^ , ^49^ , ^51^ , ^52^ , ^54^ – ^55^ , ^57^ , ^66^ , ^67^ or as the disease-specific proportion underrepresented (n=9). ^54^ – ^56^ , ^58^ , ^60^ , ^61^ , ^63^ – ^65^ The rest of the studies defined recruitment success based on the geographic proportion underrepresented (n=2), ^41^ , ^62^ or the institution's proportion underrepresented at a research institution (n=1). ^59^

When examining the 12 articles on cancer treatment trials, recruitment success was mainly defined as being equal to the proportion set by the researcher, ^44^ , ^46^ , ^51^ , ^54^ , ^57^ , ^59^ , ^66^ or the U.S. disease-specific proportion underrepresented. ^54^ , ^56^ , ^58^ , ^59^ , ^61^ , ^63^ For the eight articles on cancer prevention trials alone, recruitment success was defined mainly as being equal to the proportion set by the researcher. ^42^ , ^43^ , ^48^ , ^49^ , ^52^ , ^67^ For the 3 studies that evaluated both prevention and treatment trials, the disease-specific proportion underrepresented was the major success definition used. ^55^ , ^58^ , ^64^

Christian and Trimble in an article that did not meet our strict eligibility criteria (it contained no original data), reviewed data from the cancer therapy evaluation program that reports the NCI cancer clinical trials by race (American Indian/Alaska Native, Asian/Pacific Islander, African American, and Latino/Hispanic). They used the data from the 2000 U.S. census as a comparison, thereby providing another example of geographic representation as a measure of success. ^73^

A priori recruitment goals were rarely specified for underrepresented groups when evaluating recruitment success of cancer clinical trials. Additionally, the trials had no standard measure of recruitment success. The majority of recruitment success measures were defined either as the proportion set by the researcher, often arbitrarily, or the disease-specific proportion of underrepresented. This was true across all underrepresented groups and regardless of whether the study addressed cancer treatment, prevention, or both. Very few studies evaluated recruitment success in underrepresented groups especially those with low socioeconomic status, Asian/Pacific Islanders, adolescents, and rural populations (less than three studies in each group). No study reported recruitment success measures for American Indian/Alaska Natives (see Evidence Table 2-3 in Appendix F).

## Key Question 3: Which Recruitment Strategies Have Been Shown to be Efficacious and/or Effective in Increasing Participation of Underrepresented Populations in Cancer Treatment Trials?

## Key Question 4: Which Recruitment Strategies Have Been Shown to be Efficacious and/or Effective in Increasing Participation of Underrepresented Populations in Cancer Prevention Trials?

### Identification of Relevant Articles

As indicated in Figure 2, we found 5 studies that were relevant to these questions. ^42^ , ^43^ , ^46^ , ^52^ , ^62^ Details about these studies are shown in Tables 3 and 4, and Evidence Tables 3/4-1, 3/4-2, 3/4-2, 3/4-4, and 3/4-5 in Appendix F.

Table 3 Summary of Study and Target Population Characteristics on the Efficacy or Effectiveness of Recruitment Strategies for Increasing Participation of Underrepresented Populations in Cancer Prevention and Treatment Trials (Key Questions 3 and 4)

Author, Year | Study Setting | Study Design | Cancer Studied | Target Population | Study Subgroup | Sample Size | Mean Age, y | Mean Education, y | % male | % AA | % Cauc | % Lat/Hisp
Brewster, 2002 | Community; Outpatient hospital | CCT | Cervical | Participants | Clinic registry | 405 | 44 | < HS graduate (54.7%) | 0 | 0 | 27 | 73
| | | | | Media campaign | 535 | 42 | < HS graduate (48.5%) | 0 | 0 | 17 | 83
Ford, 2004 | Community; Faith-based organization | RCT | Prostate, Lung, Colorectal | Participants | AA, Arm A | 3,079 | NR | NR | 100 | 100 | 0 | 0
| | | | | AA, Arm B | 3,075
| | | | | AA, Arm C | 2,949
| | | | | AA, Arm D | 3,297
Linnan, 2002 | Community | RCT | Lung | Participants | Passive employee contact | 891 | 41 | ≤HS graduate (50.4%) | 53 | NR | 90 | 5
| | | | | Active employee contact | 1,015 | 44 | ≤HS graduate (39.5%) | 53 | NR | 95 | 2
Moinpour, 2000 | Outpatient hospital | RCT | Prostate | Participants; Researchers | AA, Site A, 1995 | NR | NR | NR | 100 | NR | NA | NR
| | | | | AA, Site A, 1996
| | | | | AA, Site B, 1995
| | | | | AA, Site B, 1996
| | | | | AA, Site C, 1995
| | | | | AA, Site C, 1996
| | | | | AA, Site D, 1995
| | | | | AA, Site D, 1996
| | | | | Lat/Hisp, Site E, 1995
| | | | | Lat/Hisp, Site E, 1996
Paskett, 2002 | Community | CCT | Breast, Colorectal | Physicians | South Carolina 1993 | 72 | 44 | NR | 92 | NR | NR | NR
| | | | | North Carolina 1993 | 124 | 49 | NR | 84 | NR | NR | NR
| | | | | South Carolina 1996 | 62 | 45 | NR | 85 | NR | NR | NR
| | | | | North Carolina 1996 | 102 | 49 | NR | 87 | NR | NR | NR

AA = African American

Cauc = Caucasian

CCT = Concurrent controlled trial

HS = High School

Lat/Hisp = Latino/Hispanic

NR = Not reported

RCT = Randomized controlled trial

Table 4 Summary of Outcome Point Estimates on the Efficacy or Effectiveness of Recruitment Strategies for Increasing Participation of Underrepresented Populations in Cancer Prevention and Treatment Trials (Key Questions 3 and 4)

Author, Year | Descriptor of Point Estimate %, OR, difference) | Point Estimate (value) | Measure of Spread / Significance ( 95% CI, P value) | Author Conclusion
Brewster, 2002 | OR of women presenting to clinic (media campaign vs. clinic registry) | 3.0 | 2.38 - 3.78 | Media campaign recruitment yielded better recruitment results compared to the clinic registry recruitment strategy.
| OR of women screened by telephone (media campaign vs. clinic registry) | 3.0 | 2.52 - 3.51
Ford, 2004 | Difference of enrollment between Arm C vs. Arm D (%) Arm C = intervention included enhanced mailing process and church-based sessions Arm D = control group which received standard recruitment procedures | 1.0 | P = .02 | Arm C, the most intensive of the arm interventions, yielded higher enrollment compared to the control (Arm D) and other intervention arms (Arms A and B).
Linnan, 2002 | Difference of enrollment between passive employee contact and active employee contact (%) | 36.6 | P < .0001 | Active recruitment had lesser reach, higher enrollment, and smaller attrition rate. Passive recruitment had wider ethnic and financial diversity. No significant differences in organizational factors comparing active and passive recruitment.
Moinpour, 2000 | Change in Site A enrollment from 1995 to 1996 (%) | 0.3 | NR | It was difficult to evaluate effectivenes of minority recruitment strategies since the strategies were used at the final period of accrual.
| Change in Site B enrollment from 1995 to 1996 (%) | 0.5 | NR
| Change in Site C enrollment from 1995 to 1996 (%) | 2.8 | NR
| Change in Site D enrollment from 1995 to 1996 (%) | 0.6 | NR
| Change in Site E enrollment from 1995 to 1996 (%) | 0.5 | NR
Paskett, 2002 | Change in enrollment of breast cancer patients from 1991 to 1996, North Carolina (%) | 9.0 | NR | No improvement in enrollment of cancer patients into cancer clinical trials was observed after intervention.
| Change in enrollment of colorectal cancer patients from 1991 to 1996, North Carolina (%) | 1.0 | NR
| Change in enrollment of breast cancer patients from 1991 to 1996, South Carolina (%) | 44.0 | NR
| Change in enrollment of colorectal cancer patients from 1991 to 1996, South Carolina (%) | 5.0 | NR

CI = Confidence interval

OR = Odds ratio

In reviewing the current literature on effective and/or efficacious recruitment strategies in improving participation of underrepresented populations in cancer clinical trials, we found a total of five eligible articles. Four articles examined recruitment strategies of underrepresented populations into cancer prevention trials, ^42^ , ^43^ , ^52^ , ^62^ and the fifth article examined strategies of recruiting underrepresented populations into cancer treatment trials. ^46^

The settings of the studies ranged from participants' homes and community environments ^42^ , ^43^ , ^46^ , ^52^ to community-based clinics and research sites ^42^ , ^62^ (Evidence Table 3/4-1 see Appendix F). Three studies focused on recruitment of underrepresented populations at the participant level; ^42^ , ^43^ , ^52^ one study evaluated the recruitment of underrepresented populations through participants and physicians ^62^ and one evaluated recruitment of underrepresented population through physicians ^46^ (Evidence Tables 3/4-1 and 3/4-2 in Appendix F). The underrepresented populations examined included blue-collar workers in manufacturing companies, African-American and Latino/Hispanic men, Latina/Hispanic women in southern California, and cancer patients in rural counties of North and South Carolina. All five studies used randomized or non-randomized controlled trials to evaluate the efficacy or effectiveness of interventions to promote recruitment to cancer clinical trials (Evidence Table 3/4-3, Appendix F).

### Quality of Studies

The studies on Key Questions 3 and 4 varied in their limitations as summarized in Quality Evidence Table 3/4-4 in Appendix F. We specifically examined each article based on representativeness, bias and confounding, recruitment description, outcomes and follow-up, statistical quality and interpretation, and conflict of interest.

Linnan's study reported a good amount of detail on the description of the study setting and participant characteristics, inclusion and exclusion criteria, and recruitment methods. However, the authors did not adequately discuss their statistical analyses, address methods to account for bias and confounding such as randomization or blinding, state any information about definition of successful recruitment or recruitment barriers and promoters, or report their source of funding. ^52^

Brewster's study overall was considered to be of fair quality. The authors described in great detail the setting and population, inclusion and exclusion criteria, key participant characteristics, information about non-participants, and statistical analyses. In addition, the researchers explained differences between the two recruited populations and the recruitment description. However, the authors did not provide adequate information about the definition of successful recruitment or recruitment barriers and promoters, or about their source of funding. ^42^

While Paskett's study provided some details about the setting and population, and reported their source of funding, it was also of fair quality, due to the lack of information in certain areas. The researchers did not provide adequate information on participant characteristics or their recruitment methods, address issues of randomization or blinding, explain their statistical analyses, define recruitment success, or report reasons for withdrawal. ^46^

In a good quality study, Ford and colleagues described in great detail the study setting, inclusion and exclusion criteria, participant characteristics, recruitment description, outcomes and follow-up, statistical analyses, and the source of funding. However, the researchers did not explain their randomization methods or how they addressed blinding. ^43^

Moinpour's study was not graded due to the lack of information. ^62^

### Results of Studies

The results of the interventions varied from no observed improvement ^46^ to an increase in recruitment into cancer clinical trials ^42^ , ^43^ , ^52^ (Tables 3 and 4, and Evidence Table 3/4-4 in Appendix F). Two studies examined enrollment differences between two or more intervention methods. ^42^ , ^52^ Two other studies compared enrollment differences between interventions and a control group. ^43^ , ^46^ These control groups featured either no intervention ^45^ (usual medical care from physicians) or a standard recruitment “intervention” of mailed letters and telephone contact. ^43^ However, whether various interventions had a true effect (null, positive, or negative) was somewhat unclear. Some authors cautioned that their results could be due to factors such as changes in recruitment strategy during the duration of the intervention. To get a clearer picture, we discuss the five studies in detail.

Linnan et al. investigated the differences between passive and active recruitment into a home-based cancer prevention randomized trial among employees. ^52^ In the passive employee contact arm, the research team contacted the employees from a list of employee names and telephone numbers provided by the company. In the active employee contact arm, employees actively signed up to participate. The research team examined differences in enrollment, reach, and attrition along with organizational factors and behavioral risk factors between the two recruitment arms. Compared to the active employee contact, the passive employee contact reached a higher proportion of employees (74.5 percent vs. 24.4 percent) and had a higher attrition rate (46 percent vs. 29.9 percent). However, the active employee contact arm enrolled a larger proportion (77.5 percent vs. 40.9 percent, P<0.0001). Besides having a higher proportion of smokers and higher consumption of high-fat diets in passive employee contact arm, no significant differences were observed in other behavioral or organizational factors. While lower enrollment and higher attrition were observed in the passive recruitment arm, the passive method enrolled a more diverse group of participants than did the active recruitment method. The authors concluded that with the differences observed, the results provided insight into the advantages and disadvantages that researchers may encounter when designing and implementing recruitment strategies. They also noted that these different recruitment methods might not necessarily apply to all types of work sites.

Brewster et al. examined differences in recruitment into cancer prevention clinical trials between a clinic registry method and a media campaign targeting Latina/Hispanic women. ^42^ In the clinic registry method, all women who had visited clinics as patients or a guardian were identified from the clinic registries. In the media recruitment strategy, the study was advertised in flyers placed in local community businesses, and advertised in community and regional newspapers in English and Spanish. Women who called in response to these announcements were screened for eligibility and subsequently scheduled if eligible. Compared to the clinic registry method, the media recruitment method resulted in a significantly larger proportion of women screened as a result of the media-based strategy were eligible (81 percent vs. 75 percent, p <0.001), and were more likely to give telephone consent to participate (83 percent vs. 65 percent, p <0.001). The odds of presenting to the clinic were three times higher for women recruited by the media campaign than for those recruited via the clinic registry (odds ratio [OR] = 3.00; 95% confidence interval [CI] 2.38 to 3.78). In addition, of the women who were screened by telephone, recruitment was nearly three times more successful via the media campaign than via the clinic registry (OR = 2.97; 95% CI 2.52 to 3.51). The authors concluded that the media campaign method was more advantageous than the clinic registry in recruiting women. The media campaign also recruited a larger number of Latina and uninsured women into the study.

Paskett et al. examined the effect of an intervention program aimed at physicians and community to increase the number of rural patients with breast cancer or colorectal cancer in clinical trials. ^44^ The intervention program consisted of the installation of a rapid tumor-reporting system to improve data quality and to expedite the receipt of information on cancer patients to physicians, a nurse facilitator who would notify physicians of clinical trials, a quarterly newsletter mailed to physicians about cancer treatment and clinical trials, and a health educator who trained lay health educators and provided community-based information about cancer screening, treatment, and clinical trials.

Five counties in North Carolina received an intervention program while five counties in South Carolina served as controls where usual medical care was practiced. Data collection on clinical trail enrollment was obtained from medical record data and to evaluate the enrollment differences between the North Carolina counties and South Carolina counties. As noted in Evidence Table 3/4-4, the percentage of breast and colorectal cancer patients from North and South Carolina recruited into cancer clinical trials changed in the five-year span between 1991 and 1996. In North Carolina, 15 percent (n = 24) of breast cancer patients and 4 percent of colorectal cancer patients were enrolled in clinical trials in 1991 while 6 percent (n=14) of breast cancer patients and 5 percent of colorectal cancer patients were enrolled in 1996. In South Carolina, 6 percent (n = 6) of breast cancer patients and 5 percent of colorectal cancer patients were enrolled in 1991 while 50 percent (n = 16) breast cancer patients and no colorectal cancer patients were enrolled in 1996. The authors ultimately concluded that the rates of enrollment into clinical treatment trails did not improve significantly in the intervention communities.

However, the available data remain open to interpretation despite the varied changes in percentage of enrolled patients from 1991 to 1996 in each region. The reported numbers and percentage of enrolled breast cancer patients in North and South Carolina were presented for both 1991 and 1996, but only the percentage of enrolled colorectal cancer patients was given for each area. The number of colorectal cancer patients in North and South Carolina were given as one aggregate number. Thus, without the definitive numbers distinguishing colorectal cancer patients in North Carolina from those in South Carolina, it is unknown whether the reported percentages of enrolled colorectal cancer patients in 1991 and 1996 in both regions indicate an increase or decrease in enrolled patients into cancer clinical trials. In addition, the authors noted incomplete data on breast cancer cases in South Carolina in 1996 were obtained thus dictating caution in making comparisons.

Moinpour et al. reported the results of a randomized trial in increasing participation of minorities. ^62^ Minority recruitment strategies were designed and implemented in five pilot sites: African Americans in four sites and Hispanics in one site. While each site had a minority recruiter who was given requirements and a set of tasks, the specific details of the minority recruitment interventions for each site were not given. The overall impact was minimal, according to the percentage of people recruited among the five sites before and after the implementation of the recruitment strategies. Four of the sites reported a decrease in percent enrolled (-0.3 percent, -0.5 percent, -2.8 percent, -0.6 percent) while only one site reported an increase in percent enrolled (+0.5 percent). Statistical significance of these results was not reported. The authors indicated that evaluation of the effectiveness of these strategies was difficult because execution of these interventions occurred near the end of the recruitment period.

Ford et al. examined recruitment differences among African Americans into cancer screening trials who were randomized into either three increasingly intensive intervention arms or a control group. ^43^ The control group utilized a standard method of recruitment such as a standard recruitment letter, African American or Caucasian interviewers for eligibility screening, baseline information collection via mailed packets, and reminder phone calls and mailings for completion of the mailed packets (Arm D). The basic intervention arm (Arm A) attempted to reduce potential sociocultural and individual barriers through the use of an enhanced recruitment letter and eligibility screening by African American-only interviewers. The second increasingly-intensive intervention arm (Arm B) did not use mailed packets for baseline information collection but telephone interviews to facilitate ease of participation in addition to the enhanced recruitment letter. The third, and most intensive, intervention arm (Arm C) did not use a mailing packet or telephone interview but a church-based project site to gather baseline information in addition to the enhanced recruitment letter and eligibility screening telephone call by an African American. The authors reported significantly higher enrollment yield (3.9 percent) in the most intensive church-based intervention arm (Arm C), compared to the other two intervention arms (2.5 percent [Arm A] and 2.8 percent [Arm B]) or the control group (2.9 percent [Arm D]) (p <0.01).

### Grading of the Total Body of Evidence

Overall, the mixed results of the interventions mentioned in these studies denote a continuing need for trials that evaluate additional interventions (Table 8). The studies were limited to specific populations in certain locations. Also, very few studies were available to answer our proposed questions. The available information necessitates cautious interpretation due to limitations in the quality of the studies as summarized in Evidence Table 3/4-4 (see Appendix F).

## Key Question 5: What are the Documented Barriers and Promoters of Participation of Underrepresented Populations in Cancer Prevention and Treatment Trials?

We sought to identify the documented barriers and promoters of participation for underrepresented populations in cancer prevention and treatment trials; to assess whether these barriers and promoters differ by age, gender, socio-economic status or race/ethnicity; and whether they vary by cultural factors. We abstracted data from each of the eligible studies, and according to our conceptual framework (see Figure 1), we organized the barriers and promoters of enrollment, based on their likely effect on awareness about clinical trials, the opportunity to participate in a trial, and decision-making about whether or not to participate in a trial. Some of the barriers and promoters (e.g., lack of cultural competence) had the potential to affect multiple domains of the framework, e.g., both awareness and the opportunity to participate. We subdivided the identified barriers into the patient-, provider- and healthcare system level barriers. In addition, to the extent feasible we analyzed the eligible studies based on the type of trial(s) to which accrual was studied, namely, therapeutic trials, mixed trials (therapeutic and prevention), and prevention trials. We subdivided prevention trials into chemoprevention trials, smoking cessation trials, and screening trials. Primary prevention trials other than smoking cessation were not included in this systematic review.

### Study Characteristics

Our search yielded 45 eligible studies that were conducted in a variety of settings ^32^ , ^41^ – ^44^ , ^46^ – ^48^ , ^50^ , ^53^ , ^58^ , ^60^ – ^62^ , ^64^ , ^66^ , ^69^ – ^97^ including in the community (n = 25), ^41^ – ^44^ , ^46^ – ^48^ , ^53^ , ^66^ , ^70^ , ^71^ , ^73^ , ^75^ , ^77^ , ^79^ , ^80^ , ^81^ , ^83^ , ^86^ , ^88^ – ^90^ , ^92^ – ^94^ hospital inpatient and outpatient settings (n = 22), ^42^ , ^44^ , ^50^ , ^58^ , ^60^ , ^62^ , ^64^ , ^69^ , ^70^ , ^72^ – ^74^ , ^76^ , ^78^ , ^87^ , ^89^ , ^85^ , ^87^ , ^91^ , ^95^ , ^96^ , ^97^ a study based on recruitment logs of clinical trials groups (n = 1), ^62^ and databases consisting of all NCI-funded clinical trials (n = 2). ^32^ , ^61^ Most of the studies used patients/research participants as the primary respondents, ^32^ , ^41^ – ^44^ , ^47^ , ^48^ , ^50^ , ^53^ , ^69^ – ^81^ , ^83^ , ^85^ – ^87^ , ^89^ , ^90^ , ^93^ , ^94^ , ^96^ , ^97^ while a few included interviews of healthcare professionals, including physicians, clinical research associates and data managers. ^44^ , ^46^ , ^62^ , ^66^ , ^79^ , ^80^ , ^87^ , ^84^ , ^88^ , ^91^ , ^92^ , ^95^ Among the underrepresented populations in cancer clinical trials, the available studies targeted African Americans primarily (n = 27) ^32^ , ^41^ , ^43^ , ^47^ , ^50^ , ^58^ , ^62^ , ^64^ , ^66^ , ^69^ – ^71^ , ^74^ , ^75^ , ^79^ – ^81^ , ^85^ , ^86^ , ^88^ – ^94^ , ^97^ and some of these focused exclusively on women (n = 5) ^47^ , ^73^ , ^74^ , ^86^ , ^93^ or men (n = 4). ^43^ , ^62^ , ^85^ , ^94^ The available studies also targeted other under-represented populations: Latinos / Hispanics (n = 7) ^32^ , ^41^ , ^42^ , ^62^ , ^66^ , ^74^ , ^93^ ; American Indian/Alaska Natives (n = 2) ^32^ , ^53^ , , ^93^ ; the elderly (n = 14) ^32^ , ^43^ , ^48^ , ^61^ , ^66^ , ^75^ – ^78^ , ^83^ , ^84^ , ^87^ , ^95^ , ^96^ ; adolescents (n = 3) ^60^ , ^72^ , ^73^ ; rural populations (n = 2) ^52^ , ^53^ ; and Asian/Pacific Islanders (n = 2). ^32^ , ^91^ While a large proportion of the available studies included low socioeconomic status (SES) populations, only one did so by design ^43^ ; and the studies generally reported low SES in association with minority status. The designs of the eligible accrual studies were predominantly descriptive and/or qualitative, but also included case-control studies (n = 2) ^50^ , ^66^ as well as controlled trials (n = 6) ^42^ , ^43^ , ^46^ , ^47^ , ^62^ , ^78^ (both randomized and non-randomized). The studies provided evidence on enrollment to therapeutic trials (n = 29), ^32^ , ^44^ , ^46^ , ^47^ , ^50^ , ^53^ , ^58^ , ^60^ , ^61^ , ^64^ , ^66^ , ^69^ , ^70^ , ^72^ , ^73^ , ^75^ – ^79^ , ^81^ – ^84^ , ^91^ , ^93^ – ^96^ prevention trials (n = 11), ^41^ – ^43^ , ^48^ , ^62^ , ^71^ , ^74^ , ^85^ , ^86^ , ^87^ , ^90^ both (n = 5). ^80^ , ^88^ , ^89^ , ^92^ , ^97^

Participation in a therapeutic trial typically involves accrual to a pre-randomization (or run-in) phase, followed by randomized allocation of eligible subjects to the treatment arms. While most of the eligible studies addressed barriers to enrollment, few examined barriers to randomization of those enrolled in clinical trials. This report focuses on barriers and promoters of enrollment (see Evidence Table 5-3 in Appendix F), and it does not address barriers to retention of underrepresented populations in cancer clinical trials. Moreover, most of the available studies did not provide evidence on barriers to participation in early phase versus phase III cancer clinical trials. Therefore, we did not make a distinction between these two types of trials in the review.

### Target Population Characteristics

Tables 5 and 6 present selected characteristics of participants in eligible studies. The search strategy yielded 40 U.S.-based studies. In addition, because of the modest number of U.S.-based studies, we also included 5 non-U.S.-based studies ^76^ , ^87^ , ^83^ , ^87^ , ^96^ that featured evidence of interest to this systematic review, including a study about the perspective of clinical research associates. ^87^ The sample size varied among the studies, from 23 to 59,300, and in two studies, it was not reported. The reporting of age was not consistent across the studies, and it included reports of the mean age (n = 8), ^41^ , ^46^ , ^47^ , ^64^ , ^66^ , ^74^ , ^79^ , ^81^ an age range (n = 18), ^32^ , ^44^ , ^48^ , ^60^ , ^69^ , ^70^ , ^73^ , ^75^ – ^77^ , ^83^ , ^84^ , ^86^ , ^87^ , ^90^ , ^91^ , ^95^ , ^96^ or both (n = 7), ^42^ , ^43^ , ^53^ , ^71^ , ^72^ , ^89^ , ^97^ however some (n = 12) ^50^ , ^58^ , ^61^ , ^62^ , ^78^ , ^80^ , ^87^ , ^85^ , ^88^ , ^92^ – ^94^ did not provide age information. Similarly, only some studies reported the income levels of the participants (n = 5). ^42^ , ^50^ , ^75^ , ^89^ , ^90^ The proportion of males ranged from 0 to 100 percent, depending on the type of cancer trial (e.g., cervical cancer vs. prostate cancer) to which recruitment efforts were directed. Few of the studies reported the participation of American Indian/Alaska Natives, Asian/Pacific Islanders, adolescents or rural dwellers. ^52^ , ^53^ , ^60^ , ^72^ , ^73^ , ^84^ , ^91^ , ^93^ More studies addressed barriers to accrual of African Americans (n = 27) than of any other racial/ethnic group. Among African Americans, there were four studies of barriers to accrual in males, and five in females.

Table 5 Summary of Studies Investigating the Barriers and Promoters of Participation of Underrepresented Populations in Cancer Treatment Trials (Key Question 5)

Author, Year | Pop. (N) | Setting | Type of Cancer | Method | Barriers Associated with Decrease in Reported Enrollment | | | Promoters Associated with Increase in Reported Enrollment
| | | | | Awareness | Opportunities | Decision-Making | Awareness | Opportunities | Decision-Making
Adams-Campbell, 2004 | AA (235) | Hospital inpatient; Hospital outpatient | Breast, colorectal, head and neck, lung, prostate | Tumor registry review | | Study Design Barriers: Comorbidity exclusion; Functional status; Diagnostic test result cut-off; Lack of available protocols
Advani, 2003 | AA, Whites (218) | Hospital outpatient | Solid or hematologic malignancy (excluding melanoma) | Case-control | Patient Barriers: Lack of education about trials* | Patient Barriers: Distance to clinic* | Patient Barriers: Perceived harms of trial participation*; Chance of side-effects* | | Patient Promoters: Younger age* | Patient Promoters: Altruism*; Perceived benefits of trial participation
Barofsky, 1979 | AA (76) | Community Hospital inpatient | Histologically confirmed soft-tissue or osteosarcoma | Qualitative: Semi-structured interviews | | | | | Patient Promoters: Being male*
Broome, 2001 | Adol (34) | Community Hospital inpatient; Hospital outpatient | Hematological malignancy or solid tumors | Qualitative: interviews | | | | | | Patient Promoters: Chance for better treatment; altruism
Broome, 2003 | Adol (34) | Hospital inpatient | Ewing's sarcoma, or hematological malignancy | Qualitative: Semi-structured interviews | | | | | | Patient Promoters: Family considerations; Trust; communication; and love of parents
Brown, 2003 | AA, Whites (438) | Community | NR | Cross-sectional; Descriptive (telephone surveys) | | Patient Barriers: African American older age*; Lower income* | | | Patient Promoters: Male gender*
Chen, 2000 | Elderly (68) | Hospital inpatient | Aggressive Histology Lymphoma | Hospital registry review; Retrospective | | Study Design Barriers: Comorbidity exclusion; Functional status; Previous cancer | Patient Barriers: Patient refusal
| | | | | | | Provider Barriers: Physician choice
Comis, 2003 | Elderly (887) | Community | NR | Cross-sectional; Descriptive (Telephone interview) | | Patient Barriers: Age
Diener-West, 2001 | Elderly (4,191) | Hospital inpatient; Hospital outpatient; Group practice; Solo practice | Eye | RCT | | Patient Barriers: Age*; Living near treatment center* | | | Study Design Promoters: Large tumor size*
Fouad, 2000 | AA (103) | Community | NR | Qualitative: Focus groups / key informant interviews | Patient Barriers: Lack of education about trials | Patient Barriers: Time commitment; Indirect costs; Lack/ inadequate health insurance | Patient Barriers: Mistrust of research and medical system; Blood draw; Radiation involvement; Past experiences | Provider Promoters: Education programs for community physicians; Involvement of providers in prevention trials | Study Design Promoters: Easy to read consent forms, Using recruiters who are known to community | Patient Promoters: Benefit to family; Benefit to church
| | | | | | Provider Barriers: Provider attitudes | Provider Barriers: Skepticism about low-income patients' ability to participate; Concern that their patients would be randomized
| | | | | | Study Design Barriers: Length of study/visit structure; Complexity of forms
Fouad, 2001 | AA | Community | NR | Qualitative: Focus groups / Key Informant Interviews | Patient Barriers: Lack of education about trials; Lack of knowledge about origins of cancer; Culturally relevant education about clinical trials | Patient Barriers: Job issues; Indirect costs | Patient Barriers: Mistrust of research and medical system; Cultural barriers; Perceived harms of trial participation | Patient Promoters: Adequate knowledge about the study; Workshops on trials | Patient Promoters: Provide transportation; Flexible scheduling | Patient Promoters: Provide childcare; Incentives (free meals); Trust
Green, 2000 | AA (103) | Community | NR | Qualitative: Focus groups | | Patient Barriers: Time commitment | Patient Barriers: Mistrust of research and medical system; Family considerations; Perceived harms of trial participation; Radiation involved in treatment | | | Patient Promoters: Altruism*; Incentives*; No cost treatment*
Grunfeld, 2002 | CRAs (29) | Hospital inpatient | NR | Qualitative: Semi-structured interviews | | Patient Barriers: Transportation; Language barrier; | Patient Barriers: Mistrust of researcher and medical system; Perceived harms of clinical trial participation; Physician expertise; Physician discouragement | | | Patient Promoters: Incentives (financial or other); Trial beneficial to them; Hope for care; Receive extra care; Benefit future generations
| | | | | | Provider Barriers: Provider attitudes; Communication / method of presentation | Provider Barriers: Physician beliefs about patient preference
| | | | | | Study Design Barriers: Excessive requirements of study
Hunter, 1987 | AA, Whites (17,773) | Group practice; Hospital inpatient | Any | Descriptive; Qualitative; Retrospective | | Patient Barriers: Treatment toxicity; Costs | Patient Barriers: Experimentation
| | | | | | Study Design Barriers: Comorbidity exclusion; Age exclusion; Functional status/Poor performance | Provider Barriers: Physicians' preference for specific treatment or alternative therapy
Kaluzny, 1993 | NR | Community Hospital outpatient; Group practice | NR | Descriptive; Qualitative | Patient Barriers: Limited education or low literacy | Patient Barriers: Transportation; Language barriers; Socio-economic conditions | Patient Barriers: Mistrust of researchers; Fear; Family considerations; Job issues; Indirect costs | | Provider Promoters: Incentives
| | | | | | Provider Barriers: Mistrust of researchers; Provider attitudes; time available per patient; Lack of interest in protocols; Lack of support staff
| | | | | | Study Design Barriers: Comorbidity; Length of study/ visit structure; Late stage disease;
| | | | | | Healthcare System Barriers: Lack of dissemination of study opportunities to provider/patient; Lack of language services; lack of support staff to facilitate protocol
Kemeny, 2003 | Elderly women vs. Younger women (154) | Community | Breast | Case-control | | Patient Barriers: Age*; Disease stage*; Number of comorbidities*
| | | | | | Provider Barriers: Toxicity of treatment; Thought patient ineligible; Patient comorbidity;
Kemp, 1984 | Population in Great Britain - Elderly (1,022) | Community | Breast, bone | Descriptive; Cross-sectional | | | | | | Patient Promoters: Less control over health decisions
Kornblith, 2002 | Elderly (156) | Hospital inpatient | Breast | Cross-sectional; Descriptive (Questionnaire targeting physicians) | | Patient Barriers: Transportation; Lack/ inadequate health insurance; Toxicity of treatment; Comorbidity; Patient unable to understand trial | | | Provider Promoters: Provider attitudes; Communication/ method of presentation
| | | | | | Study Design Barriers: Comorbidity exclusion; Life expectancy
Krailo, 1993 | Adol (2,788) | Hospital inpatient; Hospital outpatient | All | Hospital registry review, Qualitative | | Study design Barriers: Age; Treatment policies; Lack of available protocols
Lewis, 2003 | Elderly (59,300) | NCI cooperative groups | NR | Cross-sectional; Descriptive; Retrospective (Secondary analysis of national databases) | | Patient Barriers: Protocol exclusions | | | Study design Promoters: Life expectancy
| | | | | | Study Design Barriers: Comorbidity exclusion; Functional status; Diagnostic test cut-off
McCaskill-Stevens, 1999 | AA (89) | Community | All | Qualitative (Discussion, questionnaires of physician) | Provider Barriers: Lack of physician awareness of trials | Patient Barriers: Poverty/cost to patient | Patient Barriers: Mistrust of research and medical system; Fear; Cultural barriers | Patient Promoters: Culturally relevant education about clinical trials
| | | | | Healthcare System Barriers: Lack of dissemination of study opportunities to provider/patient | Provider Barriers: Insufficient resources | Provider Barriers: Mistrust of researchers; Lack of proven therapy
| | | | | | Study Design Barriers: Length of study/visit structure
| | | | | | Healthcare System Barriers: Lack of minority personnel/ investigators
Millon-Underwood, 1993 | AA (220) | Community | NR | Descriptive; Cross-sectional | | | Patient Barriers: Mistrust of medical research; Perceived harms of trial participation | | | Patient Promoters: Hope; Altruism; Perceived efficacy
Outlaw, 2000 | AA (56) | Hospital inpatient | NR | Qualitative: Surveys of physicians and data managers | | Patient Barriers: Language barriers; Lack of education about trials; Culturally relevant education about clinical trials; Lack of access to healthcare | Patient Barriers: Mistrust of medical research; Fear; Cultural barriers; Indirect costs; Religious/ spiritual beliefs; Perceived harms of trial participation; Lack of comfort with high technology care; Lack of family support; Perceived discrimination
| | | | | | Provider Barriers: Provider attitudes; Lack of support staff; Time required; Concern in patient's age/frailty; Lack of minority providers | Provider Barriers: Mistrust of researchers; Discomfort
| | | | | | Study Design Barriers: Complexity of clinical trials; disease stage
Paskett, 2002 | Rural (360) | Community | Breast, colorectal | CCT | Patient Barriers: Lack of education about trials | Patient Barriers: Transportation; Costs; Lack//inadequate health insurance | Patient Barriers: Mistrust of research & medical system,; Perceived harms of trial participation; Unfamiliar physician; Discomfort
| | | | | | Provider Barriers: Logistical burden, Cost to patient, Established referral patterns; Perceived treatment risk
| | | | | | Study Design Barriers: Eligibility
Pinto, 2000 | AA (73) | Community | NR | Qualitative: Focus groups with physicians | Patient Barriers: Lack of education about trials | Patient Barriers: Physicians do not offer trials; Cost | Patient Barriers: Mistrust of medical research; Fear; Cultural barriers, Perceived harms of participation | | Patient Promoters: Culturally relevant education about clinical trials
| | | | | Provider Barriers: Lack of provider awareness about trial; | Provider Barriers: Lack of time; Provider attitudes | Provider Barriers: Mistrust of researchers; Cultural barriers; Racial bias | | Provider Promoters: Incentive (financial or other)
| | | | | Healthcare System Barriers: Lack of dissemination of study opportunities to provider/ patient; | Study Design Barriers: Comorbidity exclusion, Length of study/visit structure, Protocols too complex; Randomization
| | | | | | Healthcare System Barriers: Lack of cultural competence among provider and/or staff; Lack of access to institution conducting trial
Randall-David, 2001 | Rural (37) | Community | All | Qualitative: Focus groups | Patient Barriers: Lack of education about trials | Patient Barriers: Transportation; Time commitment | Patient Barriers: Mistrust of medical research; Fear; Lack of knowledge about origins of cancer; Family considerations, Religious/spiritual beliefs; Perceived harms of trial participation | | Patient Promoters: Incentives (reimburse-ment) | Patient Promoters: Altruism; Perceived benefit of trial participation
| | | | | Healthcare System Barriers: Lack of dissemination of study opportunities to provider/patient | Provider Barriers: Communication/ method of presentation | Provider Barriers: Mistrust of researcher
Roberson, 1994 | AA, AIAN, Lat/ Hisp (28) | Community | NR | Qualitative: Surveys | Patient Barriers: Lack of education about trials; Lack of information/ awareness | Patient Barriers: Time commitment; Language barriers; Cultural barriers; Access to information | Patient Barriers: Mistrust of medical research; Fear; Do not like to get involved | | Patient Promoters: Culturally relevant education about trials | Patient Promoters: Incentives; Perceived benefits of trial participation
Robinson, 1996 | AA men (46) | Community | Prostate | Qualitative: Focus groups | Patient Barriers: Lack of knowledge of origins of cancer | Patient Barriers: Lack of education about clinical trials | Patient Barriers: Mistrust of research and medical system, Fear, Perceived harms of trial participation; Concerns about randomization | | Patient Promoters: Culturally relevant education about trials | Patient Promoters: Incentives; Perceived benefits of trial participation
| | | | | Healthcare System Barriers: Lack of dissemination of study opportunities to provider/ patient | Provider Barriers: Provider attitudes; Communication/ method of presentation | Provider Barriers: Mistrust of researchers | | | Provider Promoters: Competent/ experienced physician/ researcher; Compassionate provider
| | | | | | | | | | Healthcare System Promoters: Reputation of medical facility
Sateren, 2002 | AA (24,332) | All patients from NCI-funded trials between April 1998-April 1999 | All | Cross-sectional; Descriptive; Retrospective (Secondary analysis of national database) | | Patient Barriers: Lack/ inadequate health insurance*; Being Black male aged 30–59 years*; Asian / Latino/ Hispanic adults* | | | Patient Promoters: Place of residence; Higher SES
| | | | | | | | | Provider Promoters: Higher number of oncology specialists
| | | | | | | | | Healthcare System Promoters: Presence of cancer programs
Sears, 2003 | AA, White women (558) | Community | Breast | RCT | | Patient Barriers: Time commitment; Willingness to travel; Stress; >65 years old; minority; Not married
| | | | | | Study Design Barriers: Medication exclusion; Metastatic disease
Simon, 2004 | AA, White women (319) | Hospital inpatient | Breast | Descriptive; Qualitative (Secondary analysis of NCI patient log data; Interviews from site visits) | | Patient Barriers: Lack/ inadequate health insurance | Patient Barriers: Leaving care of physician to participate in trial*
| | | | | | Provider Barriers: Patient likely to be non-compliant; No protocol available for disease stage
| | | | | | Study Design Barriers: Age exclusion; Medication exclusion
Spaight, 1984 | Elderly (23) | Hospital inpatient | NR | Qualitative: Structured interviews of physicians | | Patient Barriers: Age; Transportation; Inability to understand protocol; Cost | Patient Barriers: Patient resistance or potential noncompliance | | | Provider Promoters: Advancement of cancer field
| | | | | | Study Design Barriers: Participation requires too much travel; Failure to use most effective drug; Too many lab tests
Twelves, 1998 | Elderly women (4,688) | Hospital inpatient; Hospital outpatien; Solo practice | Breast | Retrospective; Tumor registry review | | Patient Barriers: Age* | | | Patient Promoters:: Place of initial treatment*
| | | | | | | | | Provider Promoters: Surgeons with high case load*; Referral to an oncologist*
Woods, 2002 | AA (120) | Hospital outpatient | NR | Qualitative: Focus groups, Interviews | | Patient Barriers: Transportation problems; Time commitment; Family considerations; | Patient Barriers: Mistrust of medical research; Perceived harms of clinical trial participation; Not ready to quit smoking; Job issues | Study Design Promoters: Reminder phone call | Patient Promoters: Transportation support | Patient Promoters: Incentives; Perceived benefit of trial participation; Support/ encouragement/ prayer; Certainty of receiving actual medication
| | | | | | Provider Barriers: Training in communicating with patients; Communication/ method of presentation | | | Study Design Promoters: Length of study/visit structure

AA = African American

Adol = Adolescent

AIAN = American Indian/Alaska Native

CCT = Concurrent controlled trial

CRA = Clinical research associates

Lat/Hisp = Latino Hispanic

NCI = National Cancer Institute

NR = Not reported

Pop. = Population

RCT = Randomized controlled trial

SES = Socioeconomic status

Table 6 Summary of Studies Investigating the Barriers and Promoters of Participation of Underrepresented Populations in Cancer Prevention Trials (Key Question 5)

Author, Year | Pop. (N) | Setting | Type of Cancer | Method | Barriers Associated with Decrease in Reported Enrollment | | | Promoters Associated with Increase in Reported Enrollment
| | | | | Awareness | Opportunities | Decision-Making | Awareness | Opportunities | Decision-Making
Chemoprevention
Bieniasz, 2003 | AA women (66) | Community | Cervical (dysplasia) | Qualitative: Semi-structured interviews | | Patient Barriers: Intervention characteristics*
Ling, 2000 | Elderly (1,206) | Hospital inpatient; Hospital outpatient | NR | Qualitative: Surveys | | | | | Study Design Promoters: Entry criteria
Moinpour, 2000 | AA and Lat/Hisp men (NR) | Hospital outpatient; NCI Comprehensive Cancer Center | Prostate | RCT | | Study Design Barriers: Lack of time to establish presence in communities | Patient Barriers: Mistrust of research
Mouton, 1997 | AA, White women (80) | Community | Breast, colorectal | Descriptive; Cross-sectional (telephone surveys) | | | Patient Barriers: Mistrust of research and medical system*; Perception of researchers not caring about patient | | | Patient Promoters: Preference for study's Principal Investigator to be Black; Perception that it is better to be treated by research doctors
Thornquist, 1991 | Elderly (1,284) | Community | Lung | Cohort; Prospective | | Patient Barriers: Age (50–54; 65–69)* | | | Patient Promoter: Age (60–64; 55–59)*
Smoking cessation
Berman, 1998 | Lat/Hisp, AAs (435) | Community | Smoking cessation | Quasi-experimental. | | | | | Patient Promoters: Latinos: Lack/ inadequate health insurance; Opportunistic strategies
| | | | | | | | | Provider Promoters: Communication or Method of presentation
Lerman, 1994 | AA women (271) | Community | Breast | Descriptive; Cross-sectional (Structured telephone interview) | | | | | Patient Promoters: > HS educ: marriage, unemployment, # of affected relatives; ≤HS educ: age, employment; Age* | Patient Promoters: Impact of diagnosis on risk perception*
Woods, 2002 | AAs (12) | Hospital outpatient | NR | Qualitative: Focus groups, Interviews | | Patient Barriers: Transportation; Time; Family | Patient Barriers: Mistrust of research; Perceived harms of trial participation; Not ready to quit smoking; Job issues | Study Design Promoters: Reminder phone call | Patient Promoters: Transportation support | Patient Promoters: Incentives; Perceived benefit of participation; Support/ encouragements/ prayer; Certainty of receiving actual medication
| | | | | | Provider Barriers: Training in communicating with patients; Communication/ method of presentation | | | Study Design Promoters: Length of study/visit structure
Screening trial
Ford, 2003 | AA men (34,376) | Community | Prostate, lung, and colorectal | RCT | Patient Barriers: Unlisted telephone number* | Patient Barriers: Age* | | | Patient Promoters: Low income level*
Other
Brewster, 2002 | Lat/ Hisp women (545) | Community; Hospital outpatient | Cervical | CCT | | Patient Barriers: Family considerations (childcare problems); Work conflict; No time; Transportation; Other insurance/physician/clinic | Patient Barriers: Did not wish to participate in a “study”; Modesty/ embarrassment Uncomfortable with test
Brown, 2000 | AA, Lat/Hisp, and White women (434) | Hospital outpatient | Breast and cervical | Descriptive (Surveys, Interviews) | Patient Barriers: Lack of education about clinical trials | Patient Barriers: Transportation Lack of health insurance / inadequate health insurance | Patient Barriers: Fear; Family considerations; Taste of drug; Mistrust of research and medical system
Fouad, 2001 | AAs (103) | Community | NR | Qualitative: Focus groups / Key informant interviews | Patient Barriers: Lack of education about trials; Lack of knowledge about origins of cancer; Culturally relevant education about clinical trials | Patient Barriers: Job issues; Indirect costs | Patient Barriers: Mistrust of research and medical system; Cultural barriers; Perceived harms of trial participation | Patient Promoters: Adequate knowledge about study; Workshops on trials | Patient Promoters: Provide transportation; Flexible scheduling | Patient Promoters: Provide childcare; Incentives (free meals); Trust
Lee, 1999 | AA men (165) | Hospital inpatient | Prostate | Descriptive; Cross-sectional (Surveys) | | | | | | Patient Promoters: Willingness to take pills
McCaskill-Stevens, 1999 | AAs (89) | Community | All | Qualitative: Discussions, Questionnaires | Provider Barriers: Lack of physician awareness of trials | Patient Barriers: Poverty/cost to patient | Patient Barriers: Mistrust of research and medical system; Fear; Cultural barriers | Patient Promoter: Culturally relevant education about trials
| | | | | Healthcare System Barriers: Lack of dissemination of study opportunities to provider/patient | Provider Barriers: Insufficient resources | Provider Barriers: Mistrust of researchers; Lack of proven therapy
| | | | | | Study Design Barrier: Length of study/visit structure
| | | | | | Healthcare System Barriers: Lack of minority personnel; Lack of minority investigators
Millon-Underwood, 1993 | AAs (220) | Community | NR | Descriptive; Cross-sectional (Surveys) | | | Patient Barriers: Mistrust of medical research; Perceived harms of clinical trial participation | | | Patient Promoters: Hope; Altruism; Perceived efficacy
Pinto, 2000 | AAs (73) | Community | NR | Qualitative: Focus groups | Patient Barriers: Lack of education about trials | Patient Barriers: Physicians do not offer trials; Cost | Patient Barriers: Mistrust of medical research; Fear; Cultural barriers, Perceived harms of participation | | Patient Promoter: Culturally relevant education about clinical trials
| | | | | Provider Barriers: Lack of provider awareness about trial | Provider Barriers: Lack of time; Provider attitudes | Provider Barriers: Mistrust of researchers; Cultural barriers; Racial bias | | Provider Promoter: Incentive (financial or other)
| | | | | Healthcare System Barriers: Lack of dissemination of study opportunities to provider/ patient | Study Design Barriers: Comorbidity exclusion, Length of study/visit structure, Protocols too complex; Randomization
| | | | | | Healthcare System Barriers: Lack of cultural competence among providers and/or staff; Lack of access to institution conducting trial

CCT = Concurrent controlled trial

HS = High school

NCI = National Cancer Institute

NR = Not reported

Pop. = Population

PSA = Prostate specific antigen

RCT = Randomized controlled trial

AA = African American

Lat/Hisp = Latino/Hispanic

### Quality of Studies

The articles were rated in terms of quality in each of five areas or domains: 1) representativeness, 2) justification of study methods, 3) reliability and validity of data collection methods, 4) potential for bias/confounding, and 5) data analysis. Selected aspects of quality are summarized in Evidence Table 5-4 (see Appendix F). In terms of representativeness, ten of 45 studies provided adequate descriptions of study participants. ^42^ , ^47^ , ^50^ , ^60^ , ^64^ , ^69^ , ^70^ , ^77^ , ^78^ , ^87^ For justification of study methods, six studies provided excellent documentation for the basis for their studies, ^43^ , ^69^ , ^75^ , ^79^ , ^84^ , ^93^ and 27 other studies provided good documentation. ^41^ , ^42^ , ^46^ – ^48^ , ^50^ , ^58^ , ^60^ , ^64^ , ^66^ , ^70^ , ^72^ – ^74^ , ^77^ , ^80^ , ^81^ , ^83^ , ^85^ – ^92^ , ^97^ With the exception of two studies, ^50^ , ^53^ the study instruments used in the surveys and data collection methods used in the qualitative studies did not show adequate reliability and validity. While 14 studies ^46^ , ^58^ , ^66^ , ^70^ , ^75^ , ^81^ , ^85^ , ^86^ – ^91^ , ^93^ made notable efforts to protect against confounding or other types of bias, only four were rated as excellent in this regard. ^58^ , ^70^ , ^86^ , ^92^ For studies that used surveys as part of data collection, potential sources of confounding included participant response rates and selection of subjects; for studies that used qualitative techniques to collect data, the selection of subjects was a potential source of confounding. In terms of the description of the data analysis, all but three studies ^43^ , ^48^ , ^90^ were inadequate in their reporting.

### Overall Barriers and Promoters of Participation in Cancer Therapeutic and Prevention Trials

Tables 5 and 6 present a summary of information regarding barriers to participation in cancer prevention and treatment trials (see Evidence Table 5-3 in Appendix F for additional detail).

Types of Barriers Identified. Overall, the eligible studies identified 118 distinct barriers to accrual to cancer clinical trials, including 97 barriers to accrual to therapeutic trials, 18 barriers to accrual to prevention trials, and 32 barriers to accrual to both therapeutic and prevention trials. Across all of the studies, these barriers include eight barriers to awareness of cancer clinical trials, 80 barriers to the opportunity to participate in a cancer trial, and 40 barriers to acceptance of enrollment. Among these, 63 barriers were relevant at the patient level, 31 at the provider level, 20 at the study design level and seven at the healthcare systems level (see Evidence Table 5-3 in Appendix F for additional detail).

Types of Promoters Identified. The eligible studies identified 59 distinct promoters of enrollment to cancer clinical trials, including 36 promoters of enrollment to therapeutic trials, 14 promoters of enrollment to prevention trials, and 17 promoters of enrollment to both therapeutic and prevention trials. Overall, these promoters include six promoters of awareness of cancer clinical trials, 29 promoters of the opportunity to participate in a cancer trial, and 25 promoters of the decision to enroll. We identified promoters at the patient level (n = 40) (see Evidence Table 5-3 in Appendix F for additional detail), at the provider level (n = 12), at the study design level (n = 6), and at the healthcare system level (n = 2) (see Evidence Table 5-3 in Appendix F for additional detail).

### Barriers and Promoters of Participation in Cancer Therapeutic and Prevention Trials for African Americans

Barriers to Accrual to Cancer Therapeutic Trials in African American Populations. Overall, there were 19 studies of barriers to accrual of African Americans to cancer therapeutic trials, and on average, each reported eight barriers (range: 0 to 20). Among the 85 barriers to accrual to therapeutic trials, there were six barriers to awareness, and the most frequently reported among them were lack of education about trials (n = 5), ^50^ , ^79^ , ^80^ , ^92^ , ^93^ lack of dissemination of study opportunities to patients/providers (n = 3), ^88^ , ^92^ , ^93^ and lack of knowledge about origins of cancer (n = 2). ^76^ , ^94^ Of the reported 56 barriers to opportunity, the most frequently reported were costs (n = 5), ^58^ , ^79^ , ^80^ , ^88^ , ^92^ functional status (n = 2), ^58^ , ^69^ time commitment or additional time required (n = 5), ^47^ , ^79^ , ^81^ , ^93^ , ^97^ lack of or inadequate health insurance (n = 3), ^32^ , ^64^ , ^81^ and provider attitudes (n = 4). ^79^ , ^91^ , ^92^ , ^94^ Of the 28 barriers to acceptance, the most frequently reported were perceived harms of clinical trial participation (n = 8), ^45^ , ^80^ , ^81^ , ^89^ , ^91^ , ^92^ , ^94^ , ^97^ mistrust of research, researchers, and the medical system (n = 10), ^62^ , ^74^ , ^79^ – ^81^ , ^89^ – ^94^ , ^97^ and fear (n = 5). ^88^ , ^91^ – ^94^

Promoters of Accrual to Therapeutic Trials in African American Populations. Among the 19 studies of accrual of African Americans to cancer therapeutic trials, each reported, on average, two promoters (range: 0 to 8). Among the 34 promoters of accrual to therapeutic trials, there were six promoters of awareness, including education programs for community physicians (n = 1), ^79^ adequate knowledge about study (n = 1), ^80^ and workshop on trials (n = 1). ^80^ Of the reported 14 promoters of opportunity, the most frequently reported were culturally relevant education about trials (n = 3), ^92^ – ^94^ and providing transportation (n = 2). ^80^ , ^97^ Of the 14 promoters of acceptance, the most frequently reported were altruism (n = 3), ^50^ , ^81^ , ^89^ perceived benefits of trial participation (n = 5), ^50^ , ^89^ , ^93^ , ^94^ , ^97^ and incentives (n = 5). ^80^ , ^81^ , ^93^ , ^94^ , ^97^

### Barriers and Promoters of Accrual to Therapeutic Trials in Other Underrepresented Populations

Because of the limited evidence available regarding barriers and promoters of participation in cancer therapeutic trials in populations other than African Americans, we discuss these barriers and promoters together within each of the following paragraphs.

Barriers and Promoters in Other Racial and Ethnic Minority Populations.

Latinos/Hispanics . Overall, three studies reported evidence on barriers to accrual of Latinos/Hispanics to cancer therapeutic trials, and on average, each reported seven barriers (range: 0 to 9). ^32^ , ^66^ , ^93^ For this population, there were two barriers to awareness, and three barriers to acceptance. The reported 13 barriers to opportunity included age (n = 1), ^66^ toxicity of treatment (n = 1), ^66^ comorbid conditions (n = 1), ^66^ and disease stage (n = 1). ^66^ Two studies reported evidence on promoters of enrollment of Latinos/Hispanics to cancer therapeutic trials. ^32^ , ^93^

American Indian/Alaska Natives . The amount of evidence available for the American Indian and Alaska Native population with regard to accrual to clinical trials was very limited. The aggregate number of American Indian/ Alaska Native participants in all of the eligible studies for which data on population subgroups was reported was 15. ^53^ , ^72^ , ^73^ , ^93^ Most of the evidence regarding this population comes from focus groups conducted by Roberson (n = 28), which included African American, Latino/Hispanic and American Indian/ Alaska Native (n = 10) respondents, and addressed behavioral intention to participate in both cancer treatment and prevention trials. ^93^ When asked “Why do you think people of your race do not participate in experimental studies?”, the responses included “lack of information”, “do not get involved”, and “mistrust—do not like to be treated as guinea pigs.” All of the participating groups reported “mistrust of white people” as a barrier. In a publication that was technically ineligible for this review, some investigators found that it took several years to build trust and lay the foundation for the conduct of cancer clinical trials with an American Indian/Alaska Native population. ^103^ Roberson reported that the American Indian/Alaska Native participants suggested that programs and studies be set up on reservations, and details, including benefits, be explained. They also suggested videos, fliers, free food and money as potential incentives for participation.

Asian/Pacific Islanders . We did not find any evidence regarding barriers or promoters of participation in any type of cancer clinical trial for the Asian/Pacific Islander population. The only available evidence was that this population is under-represented in NCI-funded cancer clinical trials. ^32^

Barriers and Promoters in the Elderly. Overall, there were 11 studies of barriers and promoters of enrollment of the elderly to cancer therapeutic trials. On average, each of these studies reported four barriers (range: 0 to 9). Among the studies of accrual to therapeutic trials, there were no promoters of awareness, two studies of promoters of opportunity, and six studies of promoters of acceptance. Of the 25 barriers to opportunity, the most frequently reported were age (n = 5), ^66^ , ^77^ , ^78^ , ^95^ , ^96^ comorbidity exclusions (n = 3), ^61^ , ^76^ , ^84^ transportation (n = 2), ^84^ , ^95^ lack of or inadequate health insurance (n = 1), ^84^ and inability to understand the trial (n = 2). ^84^ , ^95^ In this population, concern about drug toxicity among both providers and participants (n = 2) ^66^ , ^84^ was an important barrier to participation, even though such concern may not be substantiated in the literature on the basis of elderly status alone. ^104^ Interestingly, in a study of protocol exclusion criteria that reduced the participation of the elderly in cancer clinical trials, Lewis and colleagues found that trials that did not specify life expectancy as an exclusion criteria resulted in relatively greater participation of elderly subjects than those that included this exclusion criteria. ^61^

Barriers and Promoters in Adolescents. Only two of the available studies yielded evidence for our review of barriers to accrual of adolescents to therapeutic trials. Krailo and colleagues documented the lack of available trials as a significant barrier to enrollment of adolescents. ^60^ In addition, Broome and colleagues reported that adolescents who enrolled in a trial had traveled long distances and tended to be highly anxious; however, neither distance nor being anxious constituted a barrier to enrollment. ^72^ Similarly, financial incentives were neither a barrier nor a promoter of participation. Promoters of participation for this population included the perceived benefits of trial participation, including a chance for better treatment, and altruistic motives. However, some of the study participants had a limited understanding of a randomized controlled trial.

Barriers and Promoters in Rural Populations. Only two of the available studies focused on barriers to accrual of rural populations to cancer clinical trials. Paskett conducted serial cross-sectional surveys for an aggregate sample size of 360 physicians who serve a rural population. ^46^ The respondents identified the lack of education about clinical trials, and the lack of physician awareness about trials, as barriers. Additionally, they reported a number of barriers that reduced their opportunity to participate in clinical trials, including the logistical burden of trial participation, transportation, and established referral patterns. Moreover, the barriers to acceptance of trial participation were cost to the patient, perceived treatment risk, mistrust of research and of the medical system, the need to see an unfamiliar physician, and the perceived harms of trial participation. Randall-David conducted focus groups in the community on barriers to participation in prevention and treatment trials. ^53^ This study identified similar barriers and promoters to those reported by Paskett and colleagues, and included the lack of dissemination of study opportunities to providers and patients, the method of presentation of the trial to physicians and patients, and religious belief, as additional barriers. This study also included altruism and incentives (financial and otherwise) as promoters.

### Barriers and Promoters of Accrual to Prevention Trials in African-American Populations

Overall, there were 13 studies of barriers and promoters to accrual of African Americans to cancer prevention trials. These included three studies of accrual to a chemoprevention trial, ^62^ , ^71^ , ^90^ baseline data from the African American Men's (AAMEN) study, ^43^ and three studies of accrual to smoking cessation trials. ^41^ , ^86^ , ^97^ However, we did not include studies of accrual to other types of primary prevention trials (e.g., diet and exercise) in this systematic review.

Barriers to Accrual to Prevention Trials in African-American Populations.

On average, each of these studies reported five barriers (range: 0 to 20). Among the 41 barriers to accrual to prevention trials, there were five barriers to awareness, and the most frequently reported among them were lack of education about clinical trials (n = 3) ^74^ , ^80^ , ^92^ and lack of dissemination of study opportunities to patient/provider (n = 2). ^88^ , ^92^ Of the reported 24 barriers to opportunity, the most frequently reported were costs (n = 3), ^80^ , ^88^ , ^92^ the study's duration and visit structure (n = 2), ^88^ , ^92^ the time commitment (n = 1), ^97^ and lack of transportation (n = 1). ^97^ Of the 13 barriers to acceptance, the most frequently reported were fear (n = 3), ^74^ , ^88^ , ^92^ mistrust of research and medical system (n = 8), ^62^ , ^74^ , ^80^ , ^88^ – ^90^ , ^92^ , ^97^ perceived harms of clinical trial participation (n = 4), ^80^ , ^89^ , ^92^ , ^97^ and family considerations (n = 1). ^74^

Chemoprevention Trials . ^62^ , ^71^ , ^90^ On average, each of the chemoprevention trials reported two barriers (range: 1 to 2). There were no barriers to awareness, two barriers to opportunity, ^62^ , ^71^ and three barriers to acceptance with mistrust of research reported in two studies. ^62^ , ^90^

Smoking Cessation Trials . ^41^ , ^86^ , ^97^ Out of the three smoking cessation trials in African American populations, only one trial reported barriers to accrual. ^97^ The barriers were: transportation problems, time and family considerations, communication / methods of presentation, mistrust of medical research, perceived harms of trial participation, reluctance to quit smoking, and job issues.

Screening Trials . ^43^ The AAMEN study is a randomized trial comparing four different strategies for accrual of African American men into the Prostate, Lung, Colorectal, and Ovarian (PLCO) trial. According to the baseline data from this enrollment trial, having an unlisted phone number was a statistically significant barrier to enrollment. Because the enrollment procedures included telephone-based recruitment, having an unlisted phone number functioned as a barrier to awareness about the study. Those who had been screened by the prostate-specific antigen-screening test within the previous three years were excluded from participation in the study. Interestingly, having a lower income level was a promoter of participation, suggesting both the lack of access to screening services in the targeted low-income African-American population, and the screening study as an opportunity for low-income men to access these services.

Promoters of Accrual to Cancer Prevention in African-American Populations. Among the 13 studies of barriers and promoters to accrual of African Americans to cancer prevention trials, each reported, on average, three promoters (range: 0 to 8). Among the 29 promoters of accrual to prevention trials, there were four promoters of awareness, each reported in a single study: reminder phone call, ^97^ adequate knowledge about the study, ^80^ a workshop on clinical trials, ^80^ and culturally relevant education about trials. ^88^ Of the 14 reported promoters of opportunity the most frequently reported was provision of transportation (n = 2). ^80^ , ^97^ Of the 12 promoters of acceptance, the most frequently reported was the use of incentives (n = 2). ^80^ , ^97^

Chemoprevention Trials . ^62^ , ^71^ , ^90^ Of the three chemoprevention trials that enrolled African Americans, only Mouton's study ^90^ reported promoters for a total of two promoters to acceptance: preference for the study's principal investigator to be Black, and perception that it is better to be treated by research doctors.

Smoking Cessation Trials . ^41^ , ^86^ , ^97^ On average, each of the three smoking cessation trials reported five promoters (range: 3 to 8). While no promoters of awareness were reported, 11 promoters of opportunity were reported including provision of transportation, ^97^ communication/method of presentation, ^41^ and employment status. ^86^ The five reported promoters of acceptance were incentives, support, encouragement, prayer, the certainty of receiving actual medication, the impact of diagnosis on risk perception, and perceived benefit of trial participation.

Screening Trials . ^43^ Because the AAMEN study targeted a low-income African-American population, having a lower income level was a promoter of participation.

### Barriers and Promoters of Accrual to Prevention Trials Among Other Underrepresented Populations

Because of the limited evidence available regarding barriers and promoters of participation in cancer prevention trials in populations other than African Americans, we discuss these barriers and promoters together within each of the following paragraphs.

Barriers and Promoters in Other Racial and Ethnic Minority Populations.

Latinos/Hispanics . Overall, there were four studies that reported evidence on barriers and promoters to accrual of Latino/Hispanics to cancer prevention trials, ^41^ , ^42^ , ^62^ , ^74^ and on average, each reported four barriers (range: 0 to 8). For this population, there was only one reported barrier to awareness, the lack of education about clinical trials. ^74^ Of the reported seven barriers to opportunity, the most frequently reported was transportation (n = 2). ^42^ , ^74^ Of the seven barriers to acceptance, the most reported was mistrust of research and the medical system (n = 2). ^62^ , ^74^

American Indian/Alaska Natives . The limited amount of evidence available for the American Indian/Alaska Native population with regard to accrual to clinical trials in general, was discussed in the section on barriers and promoters to accrual to therapeutic trials.

Asian/Pacific Islanders . We did not find any evidence regarding barriers or promoters of awareness, opportunity or acceptance of cancer clinical trials for this population. The only available evidence was that this population is underrepresented in NCI-funded cancer clinical trials. ^32^

Barriers and Promoters in the Elderly. Overall, there were three studies of barriers and promoters of enrollment to cancer prevention trials in the elderly. These studies reported three distinct barriers, age being the most frequently cited (n = 2). ^43^ , ^48^ On average, each of these studies reported one barrier (range: 0 to 3). Among the three promoters of accrual to prevention trials, there were no promoters of awareness or acceptance. The three reported promoters of accrual were the entry criteria, ^87^ age, ^48^ and low-income status. ^43^

Barriers and Promoters in Rural Populations. The available evidence on barriers and promoters of accrual of rural populations to cancer prevention and treatment trials is based on two studies that we discussed in the section on barriers and promoters of accrual to therapeutic trials. ^46^ , ^53^

### Grading of the Total Body of Evidence

The overall evidence denotes a wide variety of barriers and promoters that have an influence on the participation of underrepresented populations into cancer clinical trials. However, the overall was considered to be very low due to the limitations in quality and precision as well as the lack of strong evidence within the studies (see Table 9). In addition, a high probability of reporting bias existed within the studies. The evidence is based on 45 studies, 34 of which addressed cancer treatment trials, 16 of which addressed cancer prevention trials, and five of which addressed trials for both cancer treatment and prevention. While the studies were heterogeneous and contained over 35,000 participants in total, the majority of the studies generally focused on an African American population and an elderly population. Other underrepresented populations such as Latinos/Hispanics, Native Americans/Alaska Natives, Asian/Pacific Islanders, adolescent or rural populations were scarcely evaluated.

Table 9 Grading of the Quality of Evidence on Barriers to and Promoters of Participation of Underserved Populations in Cancer Prevention and Treatment Trials (Key Question 5)

| For Treatment Trials | For Prevention Trials | For Treatment and/or Prevention Trials
[underlined: Quantity of Evidence:]
Number of studies | 32 | 13 | 3
Total number of patients studied | 28,689 | 7,948 (excluding AAMEN)
| | 24,119 (assumed with minimum of 16,171 who are the same throughout the three AAMEN studies) | 413
[underlined: Quality and Consistency of Evidence:]
Were study designs appropriate for determining effects of providers' attitudes and perceptions? (Yes = high quality; no = low quality) | Yes | Yes | Yes
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | -1 | -1
Did the studies have important inconsistency? (-1) | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness or extent to which the people and measures are similar to those of interest? | 0 | 0 | 0
Were data imprecise or sparse? (-1) | -1 | -1 | -1
Did the studies have high probability of reporting bias? (-1) | -1 | -1 | -1
Did the studies show strong evidence of association? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0
Overall quality grade (high, medium, low, very low) | Very Low | Very Low | Very Low

*According to the evidence grading system recommended by the international GRADE Working Group, the overall grade was based on the initial assessment of the study designs (medium quality) with lowering of the grade by one or two levels for each of the limitations identified. “Very Low” grade of evidence means that any estimate of effect is very uncertain.

## Key Question 5a: Effects of Demographic Factors

Overall, the available evidence for Key Question 5 suggested that accrual to or intention to participate in a trial varied by the following socio-demographic factors: age (n = 16) ^32^ , ^43^ , ^47^ , ^48^ , ^50^ , ^58^ , ^60^ , ^64^ , ^66^ , ^75^ , ^77^ , ^78^ , ^86^ , ^90^ , ^95^ , ^96^ ; gender (n = 3) ^32^ , ^70^ , ^75^ ; SES (n = 4) ^32^ , ^43^ , ^44^ , ^86^ ; race/ethnicity (n = 4). ^32^ , ^41^ , ^47^ , ^75^ These barriers and promoters related most frequently to study design barriers, including exclusion by age (n = 3), ^58^ , ^60^ , ^64^ study duration and visit structure (n = 4), ^44^ , ^79^ , ^88^ , ^92^ comorbid conditions (n = 7), ^44^ , ^58^ , ^61^ , ^69^ , ^76^ , ^84^ , ^92^ and functional status (n = 4). ^58^ , ^60^ , ^68^ , ^75^ Few trials were available for adolescents; and as expected, parental influence was reported as a factor in decision-making only in this population. However, the available evidence did not suggest age as a factor that reduced awareness or acceptance of participation.

Few of the eligible studies attempted to assess whether the identified barriers or promoters varied by SES. However, some included measures of SES, such as income, education, suburban residence, and having a functioning telephone, in association with recruitment outcomes. A relatively large proportion of eligible studies reported on barriers or promoters of accrual of African Americans (n = 27). However, in this population as well as other groups, it was difficult to separate race/ethnicity and SES, central defining characteristics of some of the under-represented populations, from the barriers themselves.

## Key Question 5b: Effects of Cultural Factors

Three of the studies reported that barriers or promoters of enrollment varied by cultural factors, however, it is not entirely clear whether such cultural factors refer to cultural norms, values, or beliefs. For the elderly population, enrollment barriers and promoters did not vary by culturally relevant factors other than race or ethnicity. The heterogeneity of the available evidence, and the definitional overlap among several of the underrepresented populations limited our ability to synthesize the evidence regarding whether some barriers or promoters vary by cultural factors.

## Key Question 6: What Effects do the Attitudes and Perceptions of Healthcare Providers Have on the Efficacy/Effectiveness of Strategies for Recruitment of Underrepresented Populations into Cancer Prevention and Treatment Trials?

### Identification of Relevant Articles

In reviewing the current literature on question 6, we found a total of 10 eligible articles. ^46^ , ^56^ , ^64^ , ^66^ , ^84^ , ^88^ , ^92^ , ^95^ , ^100^ , ^101^ Details about these studies are given in Table 7, and Evidence Tables 6-1, 6-2, 6-3, and 6-4 in Appendix F.

### Study Characteristics

Of the 10 studies eligible for review, two were published before 1990, ^95^ , ^101^ three were published between 1990 and 1999, ^55^ , ^88^ , ^100^ and five were published after 2000 ^46^ , ^64^ , ^66^ , ^76^ , ^92^ (see Evidence Table 6-1 in Appendix F). The study designs used were concurrent controlled trial (n=1), ^46^ case-control (n=1), ^66^ or descriptive (n=8) ^56^ , ^64^ , ^84^ , ^88^ , ^92^ , ^95^ , ^100^ , ^101^ with three of the studies also employing qualitative techniques to facilitate in-depth assessments of physician attitudes and perceptions. Nine were U.S.-based studies and one was a British-based study. All were recruiting into treatment trials; three of the studies were also recruiting into prevention trials.

### Target Population Characteristics

Seven studies ^46^ , ^56^ , ^84^ , ^88^ , ^95^ , ^100^ , ^101^ targeted physicians, one targeted physicians/investigators ^92^ and two studies ^64^ , ^66^ targeted patients/participants as the study group of interest. Specific methods and techniques employed in these studies included surveys (n=8) that were implemented either via mail, ^46^ , ^56^ , ^84^ , ^100^ , ^101^ telephone, ^66^ or other methods. Other methods employed to assess physician barriers to enrolling patients into clinical trials were focus groups, ^92^ workshops, ^88^ and face-to-face interviews ^95^ (Evidence Table 6-2 in Appendix F).

Two studies employed physician interventions to increase patient accrual to clinical trials ^46^ , ^88^ with only one measuring the outcomes of their interventions. ^46^

Six of the studies targeted at least one of the underrepresented populations as a primary goal of the study. Three studies targeted either racial or ethnic minorities ^88^ , ^92^ two studies targeted the elderly, ^66^ , ^84^ and one study targeted rural populations. ^46^ Four studies did not target an underrepresented population as a primary endpoint; however, data were presented on advanced age ^92^ , ^95^ , ^100^ and social class (non-U.S. study)^106^ to merit their inclusion in this report.

### Quality of Studies

We evaluated the quality of studies in each of five areas or domains: 1) representativeness, 2) justification of study methods, 3) reliability and validity of data collection methods, 4) potential for bias/confounding, and 5) data analysis. Selected aspects of study quality are summarized in Evidence Table 6-3 (see Appendix F).

In terms of representativeness, the studies were fairly well described (four clearly described study participants). For justification of study methods, five studies adequately documented the rationale for their studies. With the exception of one study, ^100^ the study instruments used in the surveys and the data collection methods used in the qualitative studies had serious limitations in reliability and validity. Five studies used adequate measures to protect against bias or confounding. For studies that used surveys as part of data collection, this was based on participant response rate and selection of subjects; for studies that used qualitative techniques to collect data, this was based on the selection of subjects. In terms of the description of the data analysis, all studies were inadequate in their reporting.

### Results of Studies

Role of provider attitudes. Nine studies presented data on how provider attitudes/perceptions were barriers to and promoters of accrual to cancer clinical trials. Four studies found provider atttitudes as a barrier to enrollment ^46^ , ^66^ , ^92^ , ^101^ while one study found provider attitudes to be a promoter of patient accrual. ^84^ The studies also reported that patient age, ^66^ , ^95^ , ^101^ comorbidity, ^66^ , ^95^ disease stage, ^66^ mistrust of researchers, ^88^ , ^92^ and lack of physician awareness about trials ^88^ , ^92^ were factors that prevented providers from enrolling their patients into clincial trials. Two studies ^56^ , ^100^ found that provider communication or method of presentation were barriers to patient enrollment, whereas one study found it to be a promoter of trial enrollment. ^84^

For studies that targeted minority populations, ^64^ , ^88^ , ^92^ mistrust of researchers and lack of provider awareness about trials were leading provider barriers ^88^ , ^92^ that decreased patient enrollment in clinical trials. Additionally, concerns about patient non-compliance and a lack of available protocols were reasons cited for not talking to patients about clinical trials. ^64^

For studies that targeted the elderly, provider attitudes regarding clinical trials prevented them from sharing information about trials to their patients in one study, ^66^ and increased their willingness to enroll patients in clinical trials in another study ^84^ (Evidence Table 6-4 in Appendix F).

Study design barriers. Eight studies evaluated the role a clinical trial's study design plays in the ability to accrue underrepresented populations to cancer clinical trials. Four studies reported issues with the protocol itself with the length of the trial and visit structure being issues in two studies, ^88^ , ^92^ the strictness of the protocol in one study, ^92^ and the amount of travel, failure to use the most effective drug, and the number of required lab tests being issues in one study. ^94^ We also found that accrual to cancer treatment trials was decreased by study design issues including comorbid conditions, ^84^ , ^92^ age exclusion, ^84^ , ^92^ eligibility criteria, ^56^ issues with randomization, ^92^ medication exclusion, ^64^ treatment toxicity and side-effects, ^95^ life expectancy, ^84^ and disease stage/location ^100^ (Evidence Table 6-4 in Appendix F).

Health care system. Two studies ^88^ , ^92^ reported that the healthcare system itself played a role in decreased patient accrual to cancer clinical trials. Both studies found that a lack of dissemination of study opportunities to providers made it difficult for them to match potentially eligible patients to cancer clinical trials. Additionally, Pinto et al. ^92^ found that a lack of cultural competence among providers and/or staff as well as a lack of patient access to institutions conducting the clinical trials made it difficult to accrue patients to these trials. McCaskill-Stevens et al. ^88^ found that a lack of minority investigators and personnel impeded accrual (Evidence Table 6-4 in Appendix F).

Clearly the impact of the provider on accrural has not been completely elucidated. While our review highlights that the role of individual level provider factors, study design and system level factors may be important to the accrual process, it is still unclear how these factors relate to each other, which are most important, if temporal or spatial effects occur or if any of these factors are synergistic.

### Grading of the Total Body of Evidence

As summarized in Table 10, we assessed the quantity, quality, and consistency of evidence on Question 6 and concluded that the studies merited an overall “very low” evidence grade. This grade is based primarily on the fact that all ten studies scored below the 50th percentile in the quality rating, with two scoring below the 25th percentile, based on study representativeness, justification, bias, reliability/validity, and statistical analysis. Additionally, points were deducted for imprecision or sparcity of data as well as the high probability of reporting bias, based on the study designs. Thus, the evidence was insufficient to determine with any confidence how healthcare providers' attitudes and perceptions influence the efficacy/effectiveness of strategies for recruitment of underrepresented populations into cancer treatment and prevention trials. This evidence is based on studies where approximately 1,178 providers were interviewed or surveyed. Furthermore, the studies were heterogeneous in what underrepresented population they targeted.