# Introduction

## Clinical Research and the Medically Underserved

Until recently, contemporary cancer prevention and control research approaches have failed to address the basis of persistent health disparities; and they have produced mixed results in regard to the adoption, replication and diffusion of successful interventions in underserved communities. Medically underserved populations, including low-income and racial/ethnic minority populations, face substantial barriers to state-of-the-art cancer care throughout the continuum of cancer care, from preventive services to detection, to treatment and survival. Health disparities, including those related to cancer, have multiple causes, including socio-political, economic, cultural, and geographic factors. Disparities in cancer mortality rates are mediated, in part, by socioeconomic factors, ^1^ – ^3^ and low socioeconomic status is a predictor of the lack of preventive services. ^4^ – ^6^ African Americans have among the highest age-adjusted cancer incidence and mortality rates, even when controlling for poverty rates. ^1^ , ^3^ , ^7^ – ^9^ Disparities in cancer mortality may be due to disparities in incidence and/or in life expectancy following diagnosis. ^1^ , ^10^

Differences in access to medical care, including cancer detection and treatment, may be major determinants of racial disparities in cancer mortality, as the disparities in cancer mortality rates are greater than those in incidence rates, ^8^ and African Americans and other minority populations are more likely to be diagnosed with advanced stage cancer than are Whites ^4^ , ^8^ ; however, when cancer patients receive comparable treatment at the same disease stage, they experience similar treatment outcomes. ^11^ – ^20^ Once diagnosed, African Americans receive less intensive treatment, ^9^ , ^21^ and survive for a shorter duration. ^22^ – ^26^ The physicians who care for African Americans are less likely to be board-certified than those who care for Caucasian patients, ^27^ suggesting that cancer health disparities may be due, to a large degree, to disparities in the quality of care delivered by available health care systems. ^18^ , ^19^ Moreover, there is evidence that compared to the rest of the population, racial/ethnic minority populations are less likely to receive optimal treatment regimens following the diagnosis of cancer. ^21^ Therefore, to reduce these disparities, it is essential to identify and address existing barriers to care.

The goal of clinical cancer research is to advance knowledge and improve decision-making in cancer care. Clinical trials focused on cancer prevention and treatment serve health professionals and the public by translating the insights of the biological and public health sciences into effective health interventions. The National Cancer Institute (NCI) provides support for the evaluation of cancer prevention and treatment strategies through clinical trials. National research standards have been formulated to ensure that benefits and burdens of clinical research are distributed equitably in society. ^1^ However, many studies fail to recruit their planned number of participants; and studies that recruit too few patients might miss clinically important effects and are thus inappropriate uses of participants and resources. ^28^ Clinical trials are used to evaluate the efficacy and effectiveness of health promotion, prevention, and cancer care intervention strategies; however, questions often remain regarding the generalizability of trial results to a population broader than those enrolled in the clinical trials.

Medically underserved groups have been underrepresented in cancer clinical trials. ^29^ Since 1993, the National Institutes of Health (NIH) has required that all sponsored clinical trials, including cancer trials, ensure that women and members of minorities and their subpopulations be included in all human subjects research. ^30^ , ^31^ In addition, results must be reported so that potential differences in treatment effect can be detected between study subgroups. The NIH has sponsored several efforts to recruit women and racial/ethnic minorities into cancer clinical trials and other types of studies (e.g., cross-sectional and observational studies). ^30^ , ^31^ However, more than a decade following the institution of this NIH requirement, enrollment of minority populations into cancer clinical trials remains woefully inadequate. In a review of accrual to NCI-funded clinical trials, Sateren found that certain populations were underrepresented, including racial and ethnic minorities, the elderly, adolescents, rural populations and individuals of low socioeconomic status, irrespective of race/ethnicity. ^32^ Barriers to participation in cancer clinical trials would differentially exclude members of these groups from the potential benefits of new treatments and ancillary care services.

According to a recent Institute of Medicine (IOM) Report:

“The inclusion of ethnic minority and medically underserved individuals in clinical trials and the dissemination of information to their community and health care providers are critical links connecting scientific innovation with improvements in health and health care delivery. Enhancement of these links is clearly within the purview of NCI and NIH. Although many factors pose challenges to such improvements (e.g., mistrust of the scientific establishment among many members of ethnic minority communities), without a concerted effort to enhance this process, ethnic minority and medically underserved communities will continue to lag behind the American majority in benefiting from the tremendous recent scientific achievements and medical breakthroughs in cancer prevention, treatment, and control.” ^19^

Thus, the IOM underscored the urgent need to improve opportunities for culturally sensitive recruitment and accrual of underrepresented populations to cancer clinical trials, as a necessary step in addressing the public health impact of cancer health disparities.

Some investigators have systematically documented a range of factors important to participation in clinical trials in general ^33^ and to the recruitment of minorities to a broad range of clinical trial types. ^34^ More recently, systematic research on the reporting of minorities in cancer clinical trial publications has emerged. The literature in recent years has produced occasional reports of efficacious and/or effective recruitment strategies directed at medically underserved populations in cancer treatment and prevention trials. While generalization and extrapolation from other populations and disease states may be necessary, those interested in applying the evidence from clinical trials benefit most from studies conducted in specific populations with specific cancer prevention or treatment protocols.

On the basis of a systematic review of cancer prevention and treatment trials, Swanson and Bailar observed that:

- The majority of cancer clinical trial reports do not even describe the race or ethnicity of trial participants;
- When women and minorities are included in clinical trials, their participation more often appears to be by chance than by plan;
- When subgroup analyses are reported, it is rarely clearly stated whether they are done to test hypotheses or to generate hypotheses;
- When subgroups are reported, differences in treatment or prevention effect often are found;
- Trial report recommendations rarely limit the scope of their recommendations on the basis of participant gender or participant race or ethnicity; and
- Trials often do not include participant populations that are adequately diverse to ensure broad generalizability of results.' ^29^

The first five of these practices are clear and correctible shortcomings in clinical trials. The sixth practice limits the generalizibility of trial results. ^29^ However, Swanson and Bailar did not address barriers to and strategies for successful recruitment to cancer clinical trials since the 1993 change in NIH policy regarding the reporting of clinical trial accrual results for women and minority populations.

Little has been done to systematically synthesize published evidence regarding recruitment of underrepresented populations to cancer clinical trials. Such an assessment should serve to strengthen the evidence base for our knowledge about progress in increasing participation in cancer clinical research. By using the research literature to assess the state of knowledge about recruitment of underrepresented populations to cancer clinical trials, we should accomplish the following:

- Document how the problem has been studied to date,
- Ascertain proven ways to improve the recruitment,
- Unify our knowledge regarding persistent barriers to recruitment.

If nothing else, a comprehensive appraisal should serve to summarize from an evidence-based perspective what we do know and, equally importantly, what we do not know about the recruitment of the medically underserved to cancer clinical trials. Of equal importance may be reports of failed attempts to recruit underserved groups. Knowing what strategies have been ineffective can be as helpful in the process of discovery as ascertaining effective strategies. Furthermore, systematically documenting the barriers of various recruitment interventions may be equally important in future study designs.

## Recruitment of Underrepresented Populations to Cancer Clinical Trials

To summarize evidence for recruitment of underrepresented populations to cancer clinical trials, one must first overcome several barriers, not the least of which is defining “underrepresented.” We adopted a definition of underrepresented similar to the “priority populations” defined in authorizing legislation for the Agency for Healthcare Research and Quality (AHRQ) and incorporated into the National Healthcare Disparities Report. ^35^ , ^36^ For the purposes of this report, the following groups constitute the “underrepresented populations:” adolescents, older adults, those of low socioeconomic status, those residing in rural areas, African Americans, Hispanics/Latinos, Asian Americans, and American Indians. Although individual investigators may define each component of this definition somewhat differently, it provides a rough framework while preserving enough breadth to encompass the vast majority of populations affected by disparities in the U.S. healthcare system and in recruitment into cancer-related trials. The definition is intended to encompass populations such as the elderly, that may be underrepresented in clinical trials even if they are not always considered medically underserved otherwise.

We used a conceptual framework adapted from previous work done at Johns Hopkins University that includes various relevant factors for participation in clinical trials (see Figure 1). A multitude of factors may contribute to an individual's participation in cancer clinical trials. Research characteristics (study design, interventions) interrelate with participants' backgrounds (sociodemographic factors, knowledge, attitudes, beliefs, etc.), which in turn contribute to an individual's awareness of a clinical trial. These in combination with opportunity comprise the key determinants of participation. Literature from the past decade suggests that medically underserved populations face significant barriers to participation in clinical trials along the continuum from awareness to acceptance, and the nature and extent of these barriers may vary across specific underrepresented populations.

Figure 1. Conceptual Framework

Heterogeneous research tools have been used to study recruitment of the medically underrepresented populations to clinical trials in a variety of geographic and social contexts. These tools range from open-ended qualitative approaches in the community to structured experimental designs in the workplace. The historical, social, and ethical context for including the underserved in clinical trials is replete with examples of abuse. This history makes the study of barriers and the testing of strategies to improve participation of the underserved potentially suspect for those appropriately concerned about abuse.

Complicating matters further, the literature shows that neither investigators nor policy makers have reached a consensus on a uniform definition of “success” in recruitment. For instance, some have suggested that if underserved minorities enroll in trials at least as often as non-underserved, success has been achieved. Others have argued that the proportion of those enrolled in a given trial should have subgroup demographics that are proportionately representative of the more immediate geographic area or the U.S. population as a whole. Arguably, the appropriate level of inclusion might depend on the prevalence of the condition/disease studied in the overall population. Others might have serious concerns about any set numerical outcome standard, relying instead on assurance of an ethically and culturally appropriate process of recruitment. Few authors have adequately discussed this problem.

Despite these challenges literature has emerged in recent years to warrant a summary of the evidence.

## Rationale for Commissioning This Evidence Report

The NCI requested this report to summarize the state of scientific knowledge regarding the recruitment of underrepresented populations to cancer clinical trials. As envisioned by NCI, this report would:

- Summarize the ways the problem has been studied to date;
- Describe the measures of success used in the literature to assess recruitment;
- Summarize strategies that have been found to be efficacious and /or effective in the recruitment of underrepresented populations to both cancer prevention and treatment trials; and
- Summarize the barriers to and promoters of participation in clinical trials for these populations.

This report is limited to recruitment to cancer clinical trials (not, for example, recruitment to observational studies) and to the underrepresented populations as defined above. This report will be used by the NCI to guide future funding opportunities, identify priority areas for researchers, and educate clinical and cancer control investigators about the effectiveness of different recruitment approaches. We expect this report to serve the overall goal of improving opportunities for underrepresented populations to participate in cancer clinical trials, thereby eventually leading to a reduction in cancer health disparities for those populations.

However, we recognize that even if members of underrepresented populations do participate in cancer clinical trials, and reporting and recruitment are adequate, the benefits of clinical trial knowledge may not translate into improved cancer outcomes for these populations due to other factors. If systemic inequities persist in the healthcare delivery system, including in access to quality care, the availability of research data may not benefit underrepresented populations so much as other populations. Therefore, recruitment efforts to cancer clinical trials must interface with other ongoing initiatives designed to address cancer health disparities through discovery, development, and delivery, and to overcome the critical disconnect between discovery and development on the one hand, and delivery of cancer care on the other. ^10^ , ^38^

## Objectives and Scope of Report

This report summarizes and synthesizes the available evidence used to answer the key questions provided to the Johns Hopkins University Evidence-based Practice Center (EPC) by the NCI covering the following: research literature and study design characteristics, and proven strategies and barriers to the recruitment of the medically underserved to cancer prevention and treatment trials (see key questions in the Methods section). The report is comprehensive and current for literature published as of July 2004. In answering the above questions, we have written this report for the purpose of ongoing planning and priority setting of national cancer research policy. In addition, we hope it will contribute to the growing national dialogue addressing disparities in health outcomes for various U.S. populations.