# Appendix F. Evidence Tables

Evidence Table 1-1. Characteristics of Studies About Methods Used to Study Strategies to Recruit Underrepresented Populations into Cancer Prevention and Treatment Trials (Key Question 1)

Author, Year | U.S. or non-U.S. | Study Setting | Target Population | Study Design | Type of Cancer Studied | Recruitment Dates | Study Objective(s)
Advani, 2003 | U.S. | Hospital outpatient | Patients/Participants | Case-control | Solid or hematologic malignancy (excluding melanoma) | NR | A. Determine if African-American oncology patients are less willing to participate in clinical trials.
| | | | | | | B. Better delineate existing barriers to recruitment in African Americans.
| | | | | | | C. Compare attitudes of oncology patients who were treated in rural areas compared to a major medical center.
Berman, 1998 | U.S. | Community, school district | Patients/Participants | Quasi-experimental | Smoking cessation | 1990-1992 | Determine whether there are race & ethnic differences in recruitment.
Brewster, 2002 | U.S. | Community; Hospital outpatient | Patients/Participants | CCT | Cervical | 1999-2000 | Review and compare the recruitment strategies associated with recruiting Latinas into cancer prevention trials.
Ford, 2004 | U.S. | Community | Patients/Participants | RCT | Prostate, lung, and colorectal | 1996-2001 | Evaluate the outcomes of a randomized trial designed to recruit African American men aged 55-74 years to a PLOC screening trial.
Kaluzny, 1993 | U.S. | Community; Hospital outpatient; Group practice | Patients/Participants; Physicians | Descriptive; Qualitative | All | 1990-1992 | Describe the early implementation of the MBCCOP and identify the challenges that have emerged in developing a network aimed at increasing the participation of minority populations in clinical trials.
Linnan, 2002 | U.S. | Work site; Workers homes | Patients/Participants | RCT | Lung | NR | A. Describe organizational factors associated with each employee recruitment method.
| | | | | | | B. Investigate differences in employee enrollment and attrition based on elected recruitment method.
| | | | | | | C. Compare self-reported health behaviors and motivational readiness to change among employees enrolled in home-based intervention study by recruitment method.
Maurer, 2001 | U.S. | Hospital inpatient | Patients/Participants | Case series | Breast, colon, rectum, lung, prostate | 1993-1997 | Determine whether participation in clinical trials would lead to generalizable changes in patterns of care from before to after implementation.
Paskett, 1995 | U.S. | Community | Physicians | Community physicians | Colorectal Cancer | 1991-present | Get community physicians involved in clinical trial research.
Paskett, 2002 | U.S. | Community | Physicians | CCT | Breast and colorectal | 1993-1996 | A. Evaluate a rural cancer care Intervention.
| | | | | | | B. Assess rural-based primary care.
| | | | | | | C. Assess physician knowledge and attitudes/beliefs about patient and physician barriers to cancer clinical trials and accrual to clinical treatment trials.
Randall-David, 2001 | U.S. | Unclear | Patients/Participants | Qualitative | All | NR | Use focus groups to elicit perceptions of urban and rural adults regarding participation in cancer clinical trial.
Sears, 2003 | U.S. | Community | Patients/Participants | Descriptive; Retrospective | Breast | 1999-2000 | Examine recruitment, retention, and predictors of participation.
Thornquist, 1991 | U.S. | Community | Patients/Participants | Descriptive; Retrospective | Lung cancer prevention | 1985-1988 | Describe any differences in accrual and adherence to trial by age group--relevant to overall study power calculation
Zhu, 2000 | U.S. | Community | Physicians | Descriptive; Qualitative | Breast Cancer | NR | Present the strategy and outcome of a strategy to recruit elderly African American women into cancer prevention and control studies.

CARET = Beta-carotene and Retinol Efficacy Trial

CCT = Concurrent controlled trial

MBCCOP = Minority-based Community Clinical Oncology Program

NR = Not Reported

PLOC =Prostate, Lung, Ovarian and Colorectal Cancer

RCT = Randomized controlled trial

Evidence Table 1-2. Target Population Characteristics of Studies About Methods Used to Evaluate Strategies to Recruit Underrepresented Populations into Cancer Prevention and Treatment Trials (Key Question 1)

Author, Year | U.S. or non-U.S. | Mean Age, y | Age, Range | % Male | % Underrepresented | Study Setting | Target Population | Study Design | Type of Cancer Studied | Recruitment Dates
Advani, 2003 | U.S. | NR | NR | NR | 33% AIAN; 64% rural | Hospital outpatient | Patients/Participants | Case-control | Solid or hematologic malignancy (excluding melanoma) | NR
Berman, 1998 | U.S. | NR | NR | 0 | 15% AA; 85% Latino/Hispanic | Community | Patients/Participants | Quasi experimental | Smoking cessation | 1990-1992
Brewster, 2002 | U.S. | 43 | 17-78 | 0 | 78% Latino/Hispanic; 39% with <$10,000/y income | Community; Hospital outpatient | Patients/Participants | CCT | Cervical | 1999-2000
Ford et al, 2004 | U.S. | 62 | 55-74 | 100 | 100% AA; 100% elderly; 35% low SES | Community | Patients/Participants | RCT | Prostate, lung, and colorectal | 1996-2001
Kaluzny, 1993 | U.S. | NR | NR | NR | NR | Community; Hospital outpatient; Group practice | Patients/Participants; Physicians | Descriptive; Qualitative | All | 1990-1992
Linnan, 2002 | U.S. | 43 | NR | 53 | 6% Latino/Hispanic; 27% with <29,999/ yr income | Work site; Workers' homes | Patients/Participants | RCT | Lung | NR
Maurer, 2001 | U.S. | NR | NR | NR | 100% rural | Hospital inpatient | Patients/Participants | Case series | Breast, colon, rectum, lung, prostate | 1993-1997
Paskett, 1995 | U.S. | NR | NR | NR | NR | Community | Physicians | Community physicians | Colorectal | 1991-present
Paskett, 2002 | U.S. | 47 | NR | 84 | 100% rural | Community | Physicians | CCT | Breast, colorectal | 1993-1996
Randall-Davi2, 2001 | U.S. | 55 | 18-72 | 0 | 100% rural | Unclear | Patients/Participants | Qualitative | All | NR
Sears, 2003 | U.S. | 56 | NR | NR | 6% AA; 9% Asian/PI | Community | Patients/Participants | RCT; Retrospective | Breast | 1999-2000
Thornquist et al, 1991 | U.S. | NR | 45-74 | 53 | 23% elderly | Community | Patients/Participants | Descriptive; Retrospective | Lung | 1985-1988
Zhu, 2000 | U.S. | NR | 65-85 | 0 | 100% AA; 100% elderly; 91% with <$15,000/ y income | Community | Physicians | Descriptive; Qualitative | Breast | NR

AA = African American

AIAN =American Indian/ Alaskan Native

CCT = Concurrent controlled trial

NR = Not reported

PI = Pacific Islander

RCT = Randomized controlled trial

SES = Socioeconomic status

Evidence Table 1-3. Methods That Have Been Used to Study Strategies to Recruit Underrepresented Populations into Cancer Prevention and Treatment Trials (Key Question 1)

Author, Year | Recruitment definition | Method(s) to design recruitment | Primary Outcomes | Recruitment Intervention(s)
Advani, 2003 | Willingness to participate | Survey | Therapeutic treatment; Willingness to participate | NR
Berman, 1998 | Actual participation | NR | Primary prevention | A. Individuals interested in participating in a smoking-cessation program were invited via telephone to participate.
| | | | B. Tailored.
| | | | C. Opportunistic.
| | | | D. General publicity presentations, media, distribution of flyers.
Brewster, 2002 | Actual participation | Literature Review; Assumed based on introduction but not reported specifically by author | Secondary prevention | A. First 6 months, bilingual letters of introduction mailed with return postcards. Bilingual research personnel made 3 attempts to contact patients (only individuals who attended that particular clinic).
| | | | B. Second 6 months, media recruitment (study advertised weekly in community and regional newspapers in English or Spanish). Fliers placed in local businesses, community organizations, churches, mental health and free clinics, and 2 Spanish language TV stations.
Ford, 2004 | Actual Participation | Addressed barriers to recruitment of minority group members | Primary Prevention | A & B. Eligibility screening telephone call conducted; baseline information gathered via mailed packet; telephone and mailed reminder to return baseline information.
| | | | C. Eligibility screening telephone call conducted; church-based project sessions -study site collection of baseline information took place at church, transportation was provided to the churches
| | | | D. Standard recruitment letter and mailing process, eligibility screening via telephone by Caucasians or African Americans, telephone and mailed reminder to return baseline information.
Kaluzny, 1993 | Actual participation | NR | Treatment | A. Modification and translation of protocol consent forms and educational materials to reach low literacy and non-English speakers.
| | | | B. Promotional and educational materials to increase awareness of trials among physicians practicing in minority communities.
| | | | C. Design of interdisciplinary teams to aid with protocol recruitment and assure compliance follow-up.
| | | | D. Targeting younger physicians (interns, residents, fellows) and emphasizing the special needs of minority populations to them.
| | | | E. Development of data management systems to track and evaluate the provision of services in large minority populations
Linnan, 2002 | Actual participation | NR | Primary prevention | A. Letter from CEO to workers.
| | | | B. Recruitment events at work with free food and giveaways.
| | | | C. Flyers, posters, and notices at work.
| | | | D. Passive vs. active recruitment.
Maurer, 2001 | Actual participation | NR | Treatment | NR
Paskett, 1995 | Actual participation | Lead oncologist model | Survivorship; Recurrence prevention | A. Medical oncologists as community leaders carry out activities in community hospitals and clinics.
| | | | B. Lead oncologist meets with community physicians.
| | | | C. Community physicians meet at yearly meetings.
Paskett, 2002 | Actual participation | NR | Treatment | A. Tumor reporting - for state cancer registry.
| | | | B. Nurse facilitator to inform physicians on available trails.
| | | | C. Quarterly newsletter to physicians about cancer treatment and clinical trials.
| | | | D. Health educator for community about cancer screening and treatment
Randall-David, 2001 | Not defined | Focus group used to assess beliefs which subsequently were used to establish an awareness campaign | No particular trial, no recruitment attempted. | NA
Sears, 2003 | Actual participation | NR | Therapeutic CAM | A. Provide contact information on all eligible patients within 5 weeks of surgery.
| | | | B. Mail introductory letter to patient 1 to 5 weeks after surgery.
| | | | C. Called patient 2 to 6 weeks after surgery; 3 calls without response = passive refusal.
Thornquist, 1991 | Actual participation | NR | Chemo-prevention | A. Mailings to all insurers of Seattle-based King County Medical Blue Shield—one arm
Zhu, 2000 | Actual participation | In-person interview | Primary prevention | A. Use of in-person communications by door-to-door canvassing.
| | | | B. Use of local spokesperson to establish trust and increase credibility.
| | | | C. Representation of African-Americans among research staff and use of African Americans women in direct contact with potential subjects.
| | | | D. Provisions of monetary and/or material incentives.

CAM = complimentary alternative medicine

CEO = Chief Executive Officer

MBCCOP = Minority-based Community Clinical Oncology Program

NCI = National Cancer Institutes

NR = Not reported

NA = Not applicable

Evidence Table 2-1. Characteristics of Studies about Measures of Success Used to Evaluate the Efficacy or Effectiveness of Strategies for Recruitment of Underrepresented Populations into Cancer Prevention and Treatment Trials (Key Question 2)

Author, Year | Country | Study Setting | Target Population | Study Design | Type of Cancer Studied | Recruitment Dates
Alexander, 2000 | U.S. | All NCI-sponsored trials from 1994 to 1998 | Patients/Participants | Cross-sectional; | All | 1994-1995
| | | | Descriptive;
| | | | Retrospective
Benson, 1991 | U.S. | Clinical Trials Cooperative Group (1839 hospitals, 194 universities) | Patients/Participants | Cross-sectional; | All | 1991-1994
| | | | Descriptive;
| | | | Retrospective
Berman, 1998 | U.S. | Community | Patients/Participants | Quasi-experimental | Smoking cessation | 1990-1992
Brewster, 2002 | U.S. | Community; Hospital outpatient | Patients/Participants | CCT | Cervical | 1999-2000
Ford, 2004 | U.S. | Community | Patients/Participants | RCT | Prostate, lung, colorectal | 1996-2001
Goodwin, 1988 | U.S. | SWOG | Patients/Participants | Cross-sectional; | All | 1959-1982
| | | | Descriptive;
| | | | Retrospective
Hunter, 1987 | U.S. | Hospital inpatient; Hospital outpatient; | Patients/Participants | Cross-sectional; | All | 1984-1985
| | | | Descriptive;
| | | | Retrospective
Kaluzny, 1993 | U.S. | Community; Hospital outpatient; Group practice | Patients/Participants; Physicians | Descriptive | All | 1990-1992
Kemeny, 2003 | U.S. | Community | Patients/Participants | Case-control | Breast | NR
Kladbunde, 1999 | U.S. | CCOP, Hospitial inpatient | Patients/Participants | Retrospective | All | 1997-1998
Krailo, 1993 | U.S. | Hospital inpatient; Hospital outpatient | Patients/Participants | Cross-sectional; | All | 1980-1987
| | | | Descriptive;
| | | | Retrospective
Lewis, 2003 | U.S. | NCI cooperative groups | Patients/Participants | Cross-sectional; | All | 1997-2000
| | | | Descriptive;
| | | | Retrospective
Linnan, 2002 | U.S. | Work site; Workers homes | Patients/Participants | RCT | Lung | NR
Maurer, 2001 | U.S. | Hospital inpatient | Patients/Participants | Case series | Breast, colon, rectum, lung, prostate | 1993-1997
Moinpour, 2000 | U.S. | Hospital outpatient; NCI Comprehensive Cancer Center | Patients/Participants; Researchers | Descriptive | Prostate | 1993-1997
Murthy, 2004 | U.S. | Hospital inpatient; Hospital outpatient | Patients/Participants | Cross-sectional; | Breast, colorectal, lung, prostate | 1996-2002
| | | | Descriptive;
| | | | Retrospective
Paskett, 2002 | U.S. | Community | Physicians | CCT | Breast, colorectal | 1993-1996
Schiffman, 2000 | U.S. | Community; Group practice | Patients/Participants | Descriptive | Cervical | 1997-1998
Simon, 2004 | U.S. | NCI Comprehensive Cancer Center | Patients/Participants | Descriptive | Breast | 1996-1997
Thornquist, 1991 | U.S. | Community | Patients/Participants | Descriptive; | Lung | 1985-1988
| | | | Retrospective
Trimble, 1994 | U.S. | All NCI trials in 1992 | Patients/participants | Retrospective review of NCI trials in 1992 | All | 1992-1993
Yee, 2003 | Canada | Canada NCIC CTG treatment trials & U.S. SWOG treatment trials | Patients/Participants | Cross-sectional; | All | 1993-1996
| | | | Descriptive;
| | | | Retrospective
Zhu, 2000 | U.S. | Community | Physicians | Descriptive; | Breast | NR
| | | | Qualitative

CCOP = Community clinical oncology program

CCT = Concurrent controlled trial

CTEP = Cancer Therapy Evaluation Program

NCI = National Cancer Institute

NCI = National Cancer Institutes

NCIC CTG = National Cancer Institute of Canada Clinical Trials Group

NR = Not reported

RCT = Randomized controlled trial

SWOG = Southwest Oncology group

Evidence Table 2-2. Characteristics of Studies about Measures of Success Used to Evaluate the Efficacy or Effectiveness of Strategies for Recruitment of Underrepresented Populations into Cancer Prevention and Treatment Trials (Key Question 2)

Author/ year | Country | Mean Age, y | Age Range, y | % High School or Less | % Male | % White | % Underrepresented | Study Setting | Target Population | Study Design | Type of Cancer Studied | Recruitment Dates
Alexander, 2000 | U.S. | NR | NR | NR | 41 | NR | NR | NCI-sponsored trials from 1994 to 1998 | Patients/ Participants | Cross-sectional; | All | 1994-1995
| | | | | | | | | | Descriptive;
| | | | | | | | | | Retrospective
Benson, 1991 | U.S. | NR | NR | NR | | 85 | 10% AA; 6% LH; 51% elderly | Clinical Trials Cooperative Group (1,839 hospitals, 194 universities) | Patients/ Participants | Cross-sectional; | All | 1991-1994
| | | | | | | | | | Descriptive;
| | | | | | | | | | Retrospective
Berman, 1998 | U.S. | NR | NR | 84 | 49 | | 85% Hispanic; 15% AA | Community | Patients/ Participants | Quasi-experimental | Smoking cessation | 1990-1992
Brewster, 2002 | U.S. | 43 | 17-78 | NR | 0 | 22 | 78% LH; 39% low annual income | Community; Hospital outpatient | Patients/ Participants | CCT | Cervical | 1999-2000
Ford, 2004 | U.S. | 63 | (55-74) | NR | 100 | 0 | 100% AA; 100% elderly; 38% low SES | Community | Patients/ Participants | RCT | Prostate, lung cololrectal | 1996-2001
Goodwin, 1988 | U.S. | 53 | NR | NR | NR | NR | 15% elderly | SWOG | Patients/ Participants | Cross-sectional; | All | 1959-1982
| | | | | | | | | | Descriptive;
| | | | | | | | | | Retrospective
Hunter, 1987 | U.S. | NR | NR | NR | 43 | 93 | 4% AA; 3% LH | Hospital inpatient; Hospital outpatient; | Patients/ Participants | Cross-sectional; | All | 1984-1985
| | | | | | | | | | Descriptive;
| | | | | | | | | | Retrospective
Kaluzny, 1993 | U.S. | NR | NR | NR | NR | NR | NR | Community; Hospital outpatient; Group practice | Patients/ Participants; Physicians | Descriptive | All | 1990-1992
Kemeny, 2003 | U.S. | 48(younggroup),74(oldergroup) (young group), 74 (older group) | NR | 45 | 0 | NR | 50% elderly | Community | Patients/ Participants | Case-control | Breast | NR
Kladbunde, 1999 | U.S. | NR | NR | NR | 0 | 30 | NR | CCOP, Hospital inpatient | Patients/ Participants | Retrospective | All | 1997-1998
Krailo, 1993 | U.S. | NR | 0-19 | NR | NR | NR | NR | Hospital inpatient; Hospital outpatient | Patients/ Participants | Cross-sectional; | All | 1980-1987
| | | | | | | | | | Descriptive;
| | | | | | | | | | Retrospective
Lewis, 2003 | U.S. | NR | NR | NR | NR | NR | 32% elderly | NCI cooperative groups | Patients/ Participants | Cross-sectional; | All | 1997-2000
| | | | | | | | | | Descriptive;
| | | | | | | | | | Retrospective
Linnan, 2002 | U.S. | 43 | NR | 50 | 53 | 91 | 6% LH; 27% low income | Work site; Workers homes | Patients/ Participants | RCT | Lung | NR
Maurer, 2001 | U.S. | NR | NR | NR | NR | NR | 100% rural | Hospital inpatient | Patients/ Participants | Case series | Breast, colon, rectum, lung, prostate | 1993-1997
Moinpour, 2000 | U.S. | NR | 51-91 | 25 | 100 | 91 | NR | Hospital outpatient; NCI Comprehensive Cancer Center | Patients/ Participants; Researchers | Descriptive | Prostate | 1993-1997
Murthy, 2004 | U.S. | NR | 30-75 | NR | 32 | 86 | 9% AA; 2% Asian/PI; 3% LH; 32% elderly | Hospital inpatient; Hospital outpatient | Patients/ Participants | Cross-sectional; | Breast, colorectal, lung, prostate | 1996-2002
| | | | | | | | | | Descriptive;
| | | | | | | | | | Retrospective
Paskett, 2002 | U.S. | 47 | NR | NR | 87 | NR | 100% rural | Community | Physicians | CCT | Breast, colorectal | 1993-1996
Schiffman, 2000 | U.S. | 27 | 18-81 | 31 | NR | 64 | 31% AA; 2% AIAN; 3% Asian/PI; 5% LH | Community; Group practice | Patients/ Participants | Descriptive | Cervical | 1997-1998
Simon, 2004 | U.S. | 55 | NR | NR | 0 | 57 | 32% AA | NCI Comprehensive Cancer Center | Patients/ Participants | Descriptive | Breast | 1996-1997
Thornquist, 1991 | U.S. | NR | 45-74 | | 53 | | 23% elderly | Community | Patients/ Participants | Descriptive; | Lung | 1985-1988
| | | | | | | | | | Retrospective
Trimble, 1994 | U.S. | NR | NR | NR | NR | NR | 100% elderly | NCI cancer trials | Patients/ Participants | Descriptive; | Lung, prostate, colorectal, pancreas, leukemia, ovarian, breast | 1992-2993
| | | | | | | | | | retrospective
Yee, 2003 | Can | NR | NR | NR | NR | NR | 22% elderly | Canada NCIC CTG treatment trials & U.S. SWOG treatment trials | Patients/ Participants | Cross-sectional; | All | 1993-1996
| | | | | | | | | | Descriptive;
| | | | | | | | | | Retrospective
Zhu, 2000 | U.S. | NR | 65-85+ | 88 | 0 | | 100% AA; 100% elderly; 91% low income | Community | Physicians | Descriptive; | Breast | NR
| | | | | | | | | | Qualitative

AA = African American

AIAN = American Indian/Alaska Native

Can = Canada

CCOP = Community Cooperative Oncology Program

CCT = Concurrent controlled trial

CTG = Clinical trials group

LH = Latino/Hispanic

NCIC =National Cancer Institute of Canada

NR = Not reported

PI = Pacific Islander

RCT = randomized controlled trial

SES = Socioeconomic status

SWOG = Southwest Oncology GroupF-12

Evidence Table 2-3. Studies about Measures of Success Used to Evaluate the Efficacy or Effectiveness of Strategies for Recruitment of Underrepresented Populations into Cancer Prevention and Treatment Trials (Key Question 2)

Author, Year | Recruitment Definition | Primary Outcomes of Trial | Was Recruitment Goal Stated a priori (Y/N). If yes, what was goal (in %)? | Recruitment Success Measure | For Which Underserved Group was the Measure of Success Used?
Alexander, 2000 | Actual participation | Primary and secondary prevention; Treatment for NCI supported trials | NA | Disease-specific proportion in U.S. for Asian/PI; Researcher set for elderly: proportion younger Asian/PIs in the NCI-supported treatment trials | Asian/ PI; elderly
Benson, 1991 | Actual participation | Treatment | NA | Disease-specific proportion in U.S. | African American; Latino/Hispanic
Berman, 1998 | Actual participation | Primary prevention | No | Geographic representation: proportion underserved group in school district. | Latino/Hispanic, African American
Brewster, 2002 | Actual participation | Secondary prevention | No | Researcher set: Proportion underserved that agreed to participate in study | Latino/Hispanic
Ford, 2004 | Actual participation | Primary prevention | No | Measurement of enrollment of increasingly intensive intervention strategies compared to the control arm | African American men
Goodwin, 1988 | Actual participation | Treatment | NA | Researcher set: New Mexico non-SWOG cancer trials proportion of underserved groups | Elderly
Hunter, 1987 | Actual participation | Treatment; Phase I, II, III trials | NA | Disease-specific proportion in U.S.: Compared CCOP participation to SEER data from 1973-1977 | African American; Elderly
Kaluzny, 1993 | Actual participation | Treatment | NA | Researcher set: Proportion of minority-based CCOP eligible patients compared to annual proportion of CCOP eligible patients who entered trials from 1985-89 | African American; Latino/Hispanic
Kemeny, 2003 | Actual participation | Treatment | NA | Researcher set: Proportion underserved offered a cancer trial | Elderly
Kladbunde, 1999 | Actual participation | Treatment | NA | Research Institution proportion | African American
Krailo, 1993 | Actual participation | Prevention and treatment | NA | Disease-specific proportion in county: proportion underserved with cancer in county | Adolescents
Lewis, 2003 | Actual participation | Treatment | NA | Disease-specific proportion in U.S. | Elderly
Linnan, 2002 | Actual participation | Primary prevention | NA | Researcher set: Proportion underserved eligible for trial | Low SES; persons with high school education or less
Maurer, 2001 | Actual participation | Treatment | No elderly goal, Yes-rural goal; 40% of incident cancer cases & 54% would be eligible | Researcher set: proportion underserved based upon elements from another study for rural and proportion underserved participated in trial for elderly | Elderly, rural
Moinpour, 2000 | Actual participation | Treatment | Yes; 8% African American | Geographic representation: U.S. proportion underserved | African American
Murthy, 2004 | Actual participation | Treatment | NA | Disease-specific proportion in U.S. | African American; Asian/ PIs; Latino/Hispanic; Elderly
Paskett, 2002 | Actual participation | Treatment | No | Researcher set: Proportion underserved enrolled pre and post intervention | Rural
Schiffman, 2000 | Actual participation | Secondary prevention | No | Researcher set: Proportion underserved enrolled in the trial | African American
Simon, 2004 | Actual participation | All treatment trials except one diet intervention | No | Disease-specific proportion: proportion underserved group with cancer(taken from the SEER database) in Detroit | African American; Elderly
Thornquist, 1991 | Actual participation | Primary prevention/ Chemoprevention | No | Researcher set: Wanted enough elderly participants to evaluate them in study. Also wanted equal participation in 5-year age groups. | Elderly
Trimble, 1994 | Actual participation | Cancer treatment; phase II and III trials | NA | Disease-specific proportion in the U.S. | Elderly
Yee, 2003 | Actual participation | Treatment | NA | 1) Disease-specific proportion in Canada. | Elderly
| | | | 2) Researcher set: proportion underserved compared to U.S SWOG cancer treatment trial rates.
Zhu, 2000 | Actual participation | Primary prevention | No | Researcher set for African-American elderly women: Authors noted participation rates were high, compared to other study with participation rate ranging from 20-48% | African American; Elderly

CCOP = Community Cooperative Oncology Program

NA = Not applicable

NCI = National Cancer Institute

PI = Pacific Islander

SEER = Surveillance, Epidemiology, and End Results Program

SES = Socioeconomic status

SWOG = Southwest Oncology Group

Evidence Table 3/4-1. Characteristics of Studies on the Efficacy or Effectiveness of Recruitment Strategies for Increasing Participation of Underrepresented Populations in Cancer Prevention and Treatment Trials (Key Questions 3 and 4)

Author, Year | Study setting | Target population | Study Design | Type of Cancer studied | Recruitment Dates | Study Objective(s)
Brewster, 2002 | Community; Outpatient hospital | Participants | CCT | Cervical | 1999-2000 | Review and compare the recruitment strategies associated with recruiting Latinas into cancer prevention trials
Ford, 2004 | Community; Faith-based organization | Participants | RCT | Prostate, Lung, Colorectal | 1996-2001 | Test effectiveness of three increasingly intensive recruitment strategies in recruiting African-American men to the PLCO Cancer Screening Trial
Linnan, 2002 | Community | Participants | RCT | Lung | NR | 1) Describe organizational factors associated with each selected employee recruitment method.
| | | | | | 2) Investigate differences in employee reaction, enrollment, and attrition based on selected recruitment methods.
| | | | | | 3) Compare self-reported health behaviors and motivational readiness to change among employees enrolled in home-based intervention study by recruitment method.
Moinpour, 2000 | Outpatient hospital | Participants; Researchers | RCT | Prostate | 1993-1997 | Summarize the challenges of enrolling and randomizing African Americans and other minorities in the prostate cancer prevention trial (PCPT).
Paskett, 2002 | Community | Physicians | CCT | Breast, Colorectal | 1992-1996 | 1) Evaluate a rural cancer care intervention.
| | | | | | 2) Assess rural-based primary care physician knowledge and attitudes/beliefs about patient and physician barriers to research.
| | | | | | 3) To study cancer clinical trials and accrual to clinical treatment trials.

CCT = Concurrent controlled trial

PLCO = Prostate, Lung, Cervical, Ovarian

RCT = Randomized controlled trial

Evidence Table 3/4-2. Target Population Characteristics of Studies on the Efficacy or Effectiveness of Recruitment Strategies for Increasing Participation of Underrepresented Populations in Cancer Prevention and Treatment Trials (Key Questions 3 and 4)

Author, Year | Target Population | Study Subgroup | Sample size | Mean Age, y | Mean Education | Mean Income (per year) | % Male | % AA | % Cauc | % Lat/Hisp | Study Setting
Brewster, 2002 | Participants | Clinic registry | 405 | 44 | < HS graduate (55%) | ≤ $10,000 (41%) > $10,000 (59%) | 0 | 0 | 27 | 73 | Urban
| | Media campaign | 535 | 42 | < HS graduate (49%) | ≤ $10,000 (38%) > $10,000 (62%) | 0 | 0 | 17 | 83
Ford, 2004 | Participants | AA, Arm A | 3,079 | NR | NR | NR | 100 | 100 | 0 | 0 | Urban
| | AA, Arm B | 3,075
| | AA, Arm C | 2,949
| | AA, Arm D | 3,297
Linnan, 2002 | Participants | Passive employee contact | 891 | 41 | ≤ HS graduate (50.4%) | < $29,999 (24%) | 53 | NR | 90 | 5 | Urban
| | Active employee contact | 1,015 | 44 | ≤ HS graduate (39.5%) | < $29,999 (14%) | 53 | NR | 95 | 2 | Urban
Moinpour, 2000 | Participants; Researchers | AA, Site A, 1995 | NR | NR | NR | NR | 100 | NR | 0 | NR | Urban
| | AA, Site A, 1996
| | AA, Site B, 1995
| | AA, Site B, 1996
| | AA, Site C, 1995
| | AA, Site C, 1996
| | AA, Site D, 1995
| | AA, Site D, 1996
| | Lat/Hisp, Site E, 1995
| | Lat/Hisp, Site E, 1996
Paskett, 2002 | Providers (physicians) | South Carolina 1993 | 72 | 44 | NR | NR | 92 | NR | NR | NR | Rural
| | North Carolina 1993 | 124 | 49 | NR | NR | 84 | NR | NR | NR
| | South Carolina 1996 | 62 | 45 | NR | NR | 85 | NR | NR | NR
| | North Carolina 1996 | 102 | 49 | NR | NR | 87 | NR | NR | NR

AA = African American

Cauc. = Caucasian

HS = High School

Lat/Hisp = Latino/Hispanic

NR = not reported

Evidence Table 3/4-3. Interventions Used in Studies on the Efficacy or Effectiveneses of Strategies for Increasing Participation of Underrepresented Populations in Cancer Prevention and Treatment Trials (Key Questions 3 and 4)

Author, Year | Target Population | Intervention Group | Elapsed Duration of Interventions | Underrepresented Recruitment Primary Outcome | Study Design
Brewster, 2002 | Clinic registry | Women were identified from clinic registry and contacted to participate. | 1 year | Yes: objective was to review recruitment strategies associated with recruiting Latinas into prevention trials. | CCT
| Media campaign | The study advertised using several media strategies (flyers, newspapers). Women responded to these advertisements.
Ford, 2004 | AA, Arm A | Enhanced mailing process; eligibility screening conducted by AA interviewers; baseline information gathered via mailed packet. | NR | Yes: enrollment of AA men to cancer screening trial. | RCT
| AA, Arm B | Enhanced mailing process; eligibility screening conducted by AA interviewers; baseline information gathered via telephone interviews. | NR
| AA, Arm C | Enhanced mailing process; eligibility screening and church project sessions conducted by AA; baseline information gathered at church sessions; letters and telephone call reminders for church session | NR
| AA, Arm D | Control group: standard PLCO trial recruitment procedures; eligibility screening conducted by AA or Caucasian interviewers; baseline information gathered via mailed packets | NR
Linnan, 2002 | Passive employee contact | Companies provided list of employee names and home telephone numbers to research team and employees (target population) were contacted by research team to participate in study. | NA | No, target population was worksite employees but population included persons with less than high school education and relatively lower income. | RCT
| Active employee contact | Companies did not provide employee list to research team. Instead, employees (target population) actively contacted research team to partcipate in the study. | NA
Moinpour, 2000 | AA, Site A, 1995 | No specific details of intervention for each of the five sites were given. | 3.5 years | No, but the successes and failures in increasing minority participation in cancer prevention trial were presented. | RCT
| AA, Site A, 1996
| AA, Site B, 1995
| AA, Site B, 1996
| AA, Site C, 1995
| AA, Site C, 1996
| AA, Site D, 1995
| AA, Site D, 1996
| Lat/Hisp, Site E, 1995
| Lat/Hisp, Site E, 1996
Paskett, 2002 | Physicians in North Carolina, 1993 | Interventions included tumor-reporting system to expedite receipt of data on cancer patients to physicians, nurse facilitator and quarterly newspapers to inform physicians of cancer treatment and clinical trials, and health educators to provide community-based cancer education about cancer screening, treatment, and clinical trials. | 4 years | Yes: enrollment of rural patients to controlled trials | CCT
| Physicians in North Carolina, 1996
| Physicians in South Carolina, 1993 | Control group (usual medical care in South Carolina counties) | NA
| Physicians in South Carolina, 1996

AA = African American

CCT = Concurrent controlled trial

Lat/Hisp = Latino/Hispanic

NA = Not applicable

NR = Not reported

PLCO = Prostate, Lung, Cervical, Ovarian

RCT = Randomized controlled trial

Evidence Table 3/4-4. Quality of Studies on the Efficacy or Effectiveness of Strategies for Increasing Participation of Underrepresented Populations in Cancer Prevention and Treatment Trials (Key Questions 3 and 4)

Author/ Year | Representativeness^a^ | Bias and confounding^b^ | Recruitment Description^c^ | Outcomes and Follow-Up^d^ | Statistical Quality and Interpretation^e^ | Conflict of Interest Mean^f^
Linnan, 2002
Brewster, 2002
Paskett, 2002
Moinpour, 2000 | NA | NA | NA | NA | NA | NA
Ford, 2004

Excellent: > 75% quality score

Good: 50–74% quality score

Fair: 25–49% quality score

Poor: <25% quality score

NA Not applicable

a Representativeness: Score was based on a total maximum score of 8 points. This included the authors' description of setting and population (2 points), detail on provided inclusion and exclusion criteria (2 points), information provided on non-participants (2 points), and description of key participant characteristics (2 points).

b Bias and Confounding: Score was based on a total maximum score of 6 points. This included random assignment of participants to a study group (2 points), differenced of participants between groups (2 points), and details on the recruitment trial, blinding of the clinician, patient and/or outcome assors (2 points).

c Recruitment description: Score was based on a total maximum score of 4 points. This included details on the flow of participants through each stage of the clinical trial (2 points), and description of the details of the recruitment strategy (2 points).

d Outcomes and Follow-up: Percentage score was based on a total maximum score of 6 points. This included how the recruitment success outcomes were defined (2 points), description of the measures used to define the recruitment barriers and promoters (2 points), and whether the study reported the numbers and reasons for withdrawals from the study protocol (2 points).

e Statistical Quality and Interpretation: Percentage score was based on a total maximum score of 4 points. This included the statistical analyses used to determine recruitment success (2 points), and whether withdrawals, crossovers, and loss to follow-up were handled appropriately (2 points).

f Conflict of Interest: Percentage score was based on a total maximum score of 2 points. Did the study report it's source of funding (2 points)

Evidence Table 3/4-5. Outcome Point Estimates on the Efficacy or Effectiveness of Recruitment Strategies for Increasing Participation of Underrepresented Populations in Cancer Prevention and Treatment Trials (Key Questions 3 and 4)

Author, Year | Descriptor of Point Estimate (%, OR, difference) | Point Estimate (value) | Measure of Spread / Significance (CI, P value) | Author Conclusion
Brewster, 2002 | OR of women presenting to clinic (media campaign vs. clinic registry) | 3.0 | 2.38 – 3.78 | Media campaign recruitment yielded better recruitment results compared to the clinic registry recruitment strategy.
| OR of women screened by telephone (media campaign vs. clinic registry) | 3.0 | 2.52 – 3.51
Ford, 2004 | Difference of enrollment between Arm C vs. Arm D | 1.0 | P = .02 | Arm C, the most intensive of the arm interventions, yielded higher enrollment compared to the control (Arm D) and other intervention arms (Arms A and B).
| Arm C = intervention included enhanced mailing process and church-based sessions
| Arm D = control group which received standard recruitment procedures
Linnan, 2002 | Difference of enrollment between passive employee contact and active employee contact (%) | 36.6 | P < .0001 | Active recruitment had lesser reach, higher enrollment, and smaller attrition rate. Passive recruitment had wider ethnic and financial diversity. No significant differences in organizational factors comparing active and passive recruitment.
Moinpour, 2000 | Change in Site A enrollment from 1995 to 1996 (%) | 0.3 | NR | It was difficult to evaluate effectiveness of minority recruitment strategies since the strategies were used at the final period of accrual.
| Change in Site B enrollment from 1995 to 1996 (%) | 0.5 | NR
| Change in Site C enrollment from 1995 to 1996 (%) | 2.8 | NR
| Change in Site D enrollment from 1995 to 1996 (%) | 0.6 | NR
| Change in Site E enrollment from 1995 to 1996 (%) | 0.5 | NR
Paskett, 2002 | Change in enrollment of breast cancer patients from 1991 to 1996, North Carolina (%) | 9 | NR | No improvement in enrollment of cancer patients into cancer clinical trials was observed after intervention.
| Change in enrollment of colorectal cancer patients from 1991 to 1996, North Carolina (%) | 1 | NR
| Change in enrollment of breast cancer patients from 1991 to 1996, South Carolina (%) | 44 | NR
| Change in enrollment of colorectal cancer patients from 1991 to 1996, South Carolina (%) | 5 | NR

CI = Confidence interval

OR = Odds ratio

Evidence Table 5-1. Characteristics of Studies Investigating the Barriers and Promoters of Participation of Underrepresented Populations in Cancer Prevention and Treatment Trials (Key Question 5)

Author, Year | Study Setting | Target Population | Targeted Under-represented Population | Study Design | How Measured | Type of Cancer Studied | Study Objective(s) | Type of Cancer Trial into Which Recruiting
Adams-Campbell, 2004 | Hospital inpatient; Hospital outpatient | Patients/Participants; Physicians | AA | Tumor registry review | Enrollment NR | Breast, colorectal, head and neck, lung, prostate | Determine AA barriers to enrollment in trials. | Treatment
Advani, 2003 | Hospital outpatient | Patients/Participants | AA | Case-control | Surveys, phone interview | Solid or hematologic malignancy (excluding melanoma) | A. Determine if AA oncology patients are less willing to participate in trials | Treatment
| | | | | | | B. Better delineate existing barriers to recruitment in AAs.
| | | | | | | C. Compare attitudes of oncology patients who were treated in rural areas compared to a major medical center.
Barofsky, 1979 | Community; Hospital inpatient | Patients/Participants | AA | Qualitative | Semi-structured Interview | Histologically confirmed soft-tissue or osteosarcoma | Determine the extent and nature of patient nonparticipation in the soft tissue and osteosarcoma protocols at NCI. | Treatment
Berman, 1998 | Community | Patients/Participants | Lat/Hisp, AA | Quasi experimental. | Survey; Enrollment | Smoking cessation | Determine whether there are race & ethnic differences in recruitment. | Prevention
Bieniasz, 2003 | Community | Patients/Participants | AA women | Qualitative | Semi-structured interview | Cervical (dysplasia) | A. Explore women's intention to participate in a chemoprevention trial for cervical dysplasia. | Prevention
| | | | | | | B. Identify women's attitudes to certain outcomes from participation in trials.
| | | | | | | C. Determine who women would consult regarding participation.
Brewster, 2002 | Community; Hospital outpatient | Patients/Participants | Latino / Hispanic women | CCT | Enrollment | Cervical | Review and compare the recruitment strategies associated with recruiting Latinas into cancer prevention trials. | Prevention
Broome, 2003 | Hospital inpatient; | Patients/Participants | Children; Adolescents | Qualitative | Semi-structured interview | Ewing's sarcoma, acute lymphatic leukemia or hematological malignancy | How childrens' relationships with parents and clinicians influence participation in the study. | Treatment
Broome, 2001 | Community; Hospital inpatient; Hospital outpatient | Patients/Participants | Children; Adolescents | Qualitative | Interview | Hematological malignancy or solid tumors | Assess childrens' and adolescents' understanding about research and their involvement in the decision to participate in trials. | Treatment
Brown, 2000 | Hospital outpatient | Patients/Participants | AA and Hispanic women | Descriptive | Survey; Interview; Enrollment | Breast, cervical | A. Determine factors related to intention to participate in a chemo-prevention trial for cervical neoplasia. | Prevention
| | | | | | | B. Address differences in AA and Caucasians in factors affecting clinical trial accessibility and participation.
Brown, 2003 | Community | Patients/Participants | AA | Cross-sectional; Descriptive | Telephone surveys | NR | Analysis on factors affecting willingness of older AAs and whites to participate in clinical treatment study. | Treatment
Chen, 2000 | Hospital inpatient | Patients/Participants | Elderly | Hospital registry review; Retrospective | Enrollment NR | Aggressive histology lymphoma | Compare baseline patient characteristics, treatments, and outcomes of elderly patients who were entered or not entered into a randomized phase I trial. | Treatment
Comis, 2003 | Community | Patients/Participants | Elderly (by sub-group analysis) | Cross-sectional; Descriptive | Telephone interview | NR | Examine attitudes regarding participation in cancer trials. | Treatment
Diener-West, 2001. | Hospital inpatient; Hospital outpatient; Group practice; Solo practice | Patients/Participants | Elderly (by sub-group analysis) | RCT | Enrollment; Face-to-face interview | Eye | Study and compare predictors of patient participation in 2 related multicenter trials conducted concurrently in the U.S. and Canada. | Treatment
Ford, 2003 | Community | Patients/Participants | AA men | RCT | Enrollment NR | Prostate, lung, colorectal | A. Demonstrate that low-income and moderate to high income older AA men can be recruited into a cancer trial. | Prevention
| | | | | | | B. Identify a method for increased participation of older AA men in cancer screening trials.
Fouad, 2000 | Community | Patients/Participants; Physicians | AA | Qualitative | Focus groups / key informant interview | NR | A. Determine the perceptions of AA residents regarding participation in research. | NR
| | | | | | | B. Determine health care providers perceptions of barriers to participation of AAs in trials.
Fouad, 2001 | Community | Patients/Participants; Physicians | AA | Qualitative | Focus groups / key informant interview | NR | Ascertain the community's perspective of participating in trials. | NA
Green, 2000 | Community | Patients/Participants | AA | Qualitative | Focus group | NR | Identify important issues regarding AAs' perceptions/ attitudes toward trials and to plan a conference. | NR
Grunfeld, 2002 | Hospital inpatient | Researchers | Clinical research associates | Qualitative | Semi-structured interview | NR | Get the views of clinical research associates on barriers and facilitators to accrual. | Treatment
Hunter, 1987 | Group practice; Hospital inpatient | Patients/Participants | AA | Descriptive; Qualitative; Retrospective | Secondary analysis of program data | All | A. Provide characteristics of the cancer patient population from which patients entered in trials are derived. | Treatment
| | | | | | | B. Describe the process by which patients are recruited and selected from trials as determined from the CCOP physicians' patient log.
Kaluzny, 1993 | Community; Hospital outpatient; Group practice | Patients/Participants; Physicians | NR | Descriptive; Qualitative | Secondary analysis of NCI patient log data; Interviews from site visits | NR | Describe the early implementation of the MBCCOP and identify the challenges that have emerged in developing a network aimed at increasing the participation of minority populations in trials. | Treatment
Kemeny, 2003 | Community | Patients/Participants; Physicians | Elderly | Case-control | Patient interviews; Self-administered written questionnaires for physicians | Breast | A. Were patients older than 65 years offered trial more often than younger patients ? | Treatment
| | | | | | | B. Assess reasons why oncologists choose not to offer a trial to their older patients and why patients chose to, or refused to participate.
Kemp, 1984 | Community | Patients/Participants | Elderly (by sub-group analysis) | Descriptive; Cross-sectional | Face-to-face interview; Survey | Breast, bone | A. Assess whether people were prepared to participate in randomized trials or whether they wanted to choose their own treatment. | Treatment
| | | | | | | B. Assess whether or not people wanted their doctor to provide information about their treatment and the system of allocation.
Kornblith, 2002 | Hospital inpatient | Physicians | Elderly | Cross-sectional; Descriptive | Questionnaire | Breast | Test the magnitude of barriers to recruitment among elderly breast cancer patients from physician perspective. | Treatment
Krailo, 1993 | Hospital inpatient; Hospital outpatient | Patients/Participants | Children; Adolescents | Hospital registry review, Qualitative | Enrollment NR | All | Assess the proportion of children diagnosed with cancer who are enrolled in cancer studies. | Treatment
Lee, 1999 | Hospital inpatient | Patients/Participants | AA men | Descriptive; Cross-sectional | Survey | Prostate | Assess factors affecting interest in participation in a prostate cancer chemoprevention trial. | Prevention
Lerman, 1994 | Community | Patients/Participants | AA women | Descriptive; Cross-sectional | Structured telephone interview | Breast | Identify factors, especially sociodemographic, psychological, historic and risk factors of breast cancer patients associated with their decision to participate in a randomized trial. | Prevention
Lewis, 2003 | NCI cooperative groups | Patients/Participants | Elderly | Cross-sectional; Descriptive; Retrospective | Secondary analysis of national database (NCI, CTEP, PDQ, SEER) | NR | Determine the proportion of elderly participants in NCI-sponsored cancer treatment trials from 1997-2000. | Treatment
Ling, 2000 | Hospital inpatient; Hospital outpatient | Patients/Participants | Elderly (by sub-group analysis) | Qualitative | Survey | NR | Describe recruitment experiences into RCTs of a Palliative Care Center. | Treatment
McCaskill-Stevens, 1999 | Community | Physicians | AA | Qualitative | Workshops with discussions and questionnaires | All | Identify barriers and solutions to AA accrual to cancer trials. | Prevention; Treatment
Millon-Underwood, 1993 | Community | Patients/Participants | AA | Descriptive; Cross-sectional | Survey | NR | A. Assess perceptions/attitudes and beliefs of AAs regarding participation in cancer studies. | Prevention; Treatment
| | | | | | | B. Evaluate effect of perception/attitudes belief on willingness.
| | | | | | | C. Evaluate role of perceived risk, personal experience, perceived efficacy, economics status on willingness to participate.
Moinpour, 2000 | Hospital outpatient; NCI Comprehensive Cancer Center | Patients/Participants; Researchers | AA and Hispanic men | RCT | Enrollment NR | Prostate | Summarize challenges of enrolling and randomizing AAs/other minorities in the PCPT. | Prevention
Mouton,, 1997 | Community | Patients/Participants | AA women | Descriptive; Cross-sectional | Telephone survey | Breast,colorectal | A. Compare attitudes toward participation in cancer trials and attitudes toward cancer screening and prevention for black and white subjects. | Prevention
| | | | | | | B. Discover why black women decide to participate in cancer trials.
| | | | | | | C. Assess whether blacks are more likely to participate in research that is conducted by black researchers.
Outlaw, 2000 | Hospital inpatient | Physicians; Data managers | AA | Qualitative | Survey | NR | Identify factors related to AAs participation in trials. | NR
Paskett, 2002 | Community | Physicians | Rural | CCT | Survey, Enrollment NR | Breast, colorectal | A. Evaluate a Rural Cancer Care Intervention. | Treatment
| | | | | | | B. Assess rural-based primary care physician knowledge, attitudes, and beliefs about patient and physician barriers to cancer trials and accrual to clinical treatment trials.
Pinto, 2000 | Community | Physicians | AA | Qualitative | Focus groups | NR | Identify barriers to accrual of minority patients and develop solutions to these barriers from physicians perspective | Prevention; Treatment
Randall-Davis, 2001 | Community | Patients/Participants | Rural | Qualitative | Focus groups | All | To elicit perceptions of urban and rural adults regarding participation in cancer trial. | Treatment
Roberson, 1994 | Community | Patients/Participants | AA, American Indian or Alaskan Native, Lat/Hisp | Qualitative | Telephone survey | NR | Discuss racial/ethnic minority groups views and opinions about clinical trial participation. | Treatment
Robinson, 1996 | Community | Patients/Participants | AA men | Qualitative | Focus groups | Prostate | Identify attitudes among AAs associated with participation in prostate cancer trials. | Treatment
Sateren, 2002 | All patients from NCI-funded trials between April 1998-April 1999 | Patients/Participants | AA | Cross-sectional; Descriptive; Retrospective | Secondary analysis of national database (US Census, SEER) | All | Examine the impact of socioeconomic factors on accrual to to NCI-sponsored cancer treatment trials | Treatment
Sears, 2003 | Community | Patients/Participants | AA women | RCT; Retrospective | Enrollment NR | Breast | Examine recruitment, retention, and predictors of participation. | Treatment
Simon, 2004 | Hospital inpatient | Patients/Participants | AA | Descriptive | Survey | Breast | Better understand factors associated with accrual to breast cancer trials. | Treatment
Spaight, 1984 | Hospital inpatient | Physicians | Elderly | Qualitative | Structured interview | NR | Assess factors influencing trials participation from the perspective of medical oncologists and hematologists | Treatment
Thornquist, 1991 | Community | Patients/Participants | Elderly (by sub-group analysis) | Cohort; Prospective | Enrollment NR | Lung | Describe any differences in accrual and adherence to trial by age group or by gender. | Prevention
Twelves, 1998 | Hospital inpatient; Hospital outpatient; Solo practice | Patients/Participants | Elderly women (by sub-group analysis) | Retrospective; Tumor registry review | Enrollment NR | Breast | Identify factors influencing enrollment into invasive breast cancer trials. | Treatment
Woods, 2002 | Hospital outpatient | Patients/Participants | AA | Qualitative | Focus groups / interview | NR | A. Identify characteristics of those who chose not to participate in a trial. | Prevention; Treatment
| | | | | | | B. To understand why some eligible participants did not return for enrollment.
| | | | | | | C. To see what strategies might make participation more likely.

AA = African American

CCOP = Community Clinical Oncology Program

CCT = Concurrent controlled trials

CTEP = Cancer Therapy Evaluation Program

ECOG = Eastern Cooperative Oncology Group

Lat/Hisp = Latino/Hispanic

MBCCOP = Minority-based Community Clinical Oncology Program

NCI = National Cancer Institute

PCPT = Prostate Cancer Prevention Trial

PDQ = Physician Data Query

PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Trial

RCT = Randomized controlled trial

SEER = Surveilance, Epidemiology, and End Results Program

SES = Socioeconomic status

Evidence Table 5-2. Target Population Characteristics of Studies Investigating the Documented Barriers and Promoters of Participation of Medically Underserved Populations in Cancer Prevention and Treatment Trials (Key Question 5)

Author, Year | U.S.or Non-U.S. | Sample Size | Mean Age, y | Age Range, y | Mean Income ($) | Income range ($) | % Male | % AA | % AIAN | % Asian /PI | % White | % Lat/ Hisp | % Adol | % Elderly | % Low SES | % Rural
Adams-Campbell, 2004 | U.S. | 235 | NR | 22–97 | NR | NR | 30 | 100 | 0 | 0 | 0 | 0 | NR | NR | NR | NR
Advani, 2003 | U.S. | 218 | NR | NR | NR | <15,000->35,000 | NR | 33 | NR | NR | 67 | NR | NR | NR | NR | NR
Barofsky, 1979 | U.S. | 103 | NR | ≤19-≥50 | NR | NR | 65 | 16 | 0 | 0 | 84 | 0 | NR | NR | NR | NR
Berman, 1998 | U.S. | 435 | 37 | NR | NR | NR | 49 | 15 | 0 | 0 | 0 | 85 | NR | NR | NR | NR
Bieniasz, 2003 | U.S. | 66 | 37 | 18–81 | 28,045 | NR | 0 | 64 | NR | NR | 27 | NR | NR | NR | NR | NR
Brewster, 2002 | U.S. | 545 | 43 | 17–78 | NR | <10,000-≥10,000 | 0 | 0 | 0 | 0 | 22 | 78 | NR | NR | NR | NR
Broome,2003 | U.S. | 34 | 14 | 8–22 | NR | NR | NR | 9 | 3 | 3 | 73 | 12 | 100 | NR | NR | NR
Broome, 2001 | U.S. | 34 | NR | 8–22 | NR | NR | NR | 9 | 3 | 3 | 74 | 11 | 100 | NR | NR | NR
Brown, 2000 | U.S. | 434 | Study 1 = 32; Study 2 = NR | NR | NR | NR | 0 | 29 | NR | NR | 54 | 17 | NR | NR | NR | NR
Brown, 2003 | U.S. | 438 | NR | 50->75 | NR | <25,000->40,000 | 33 | 49 | 0 | 0 | 51 | 0 | NR | 100 | NR | NR
Chen, 2000 | Non-U.S. | 68 | NR | 65–89 | NR | NR | 50 | NR | NR | NR | NR | NR | NR | 100 | NR | NR
Comis, 2003 | U.S. | 887 | NR | 18->65 | NR | NR | 51 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Diener-West, 2001 | U.S. | 4,191 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Ford, 2003 | U.S. | 34,376 | 63 | 55–74 | NR | NR | 100 | 100 | 0 | 0 | 0 | 0 | 0 | 100 | 38 | NR
Fouad, 2000 | U.S. | 103 | 51 | NR | NR | NR | 31 | 100 | NR | NR | NR | NR | NR | NR | NR | NR
Fouad, 2001 | U.S. | 103 | NR | NR | NR | NR | 31 | 100 | NR | NR | NR | NR | NR | NR | NR | NR
Green, 2000 | U.S. | 103 | 50.8 | NR | NR | NR | 30 | 100 | NR | NR | NR | NR | NR | NR | NR | NR
Grunfeld, 2002 | Non-U.S. | 29 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Hunter, 1987 | U.S. | 17,773 | NR | NR | NR | NR | 43 | 4 | NR | NR | 93 | NR | NR | NR | NR | NR
Kaluzny, 1993 | U.S. | NR | NR | 51->71 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kemeny, 2003 | U.S. | 154 | 61 | NR | NR | NR | 0 | NR* | 0 | 0 | 77 | NR* | NR | 50 | NR | NR
Kemp, 1984 | Non-U.S. | 1,022 | NR | 16–70 | NR | NR | 49 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kornblith, 2002 | U.S. | 156 | NR | 29–74 | NR | NR | 69 | 3 | 3 | NR | 87 | NR | NR | 7 | NR | NR
Krailo, 1993 | U.S. | 2,788 | NR | 0–19 | NR | NR | NR | NR | NR | NR | NR | NR | 33 | NR | NR | NR
Lee, 1999 | U.S. | 165 | NR | NR | NR | NR | 59 | 67 | NR | NR | 33 | NR | NR | NR | NR | NR
Lerman, 1994 | U.S. | 271 | NR | 35->50 | NR | NR | 0 | NR | NR | NR | 100 | NR | NR | NR | NR | NR
Lewis, 2003 | U.S. | 59,300 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 32 | NR | NR
Ling, 2000 | Non-U.S. | 1,206 | NR | 18–95 | NR | NR | 35 | NR | NR | NR | NR | NR | NR | 51 | NR | NR
McCaskill-Stevens, 1999 | U.S. | 89 | NR | NR | NR | NR | NR | 56 | 0 | 0 | 0 | 0 | NR | NR | NR | NR
Millon-Underwood, 1993 | U.S. | 220 | 27 | 18–47 | 30,626 | 13,915–46,138 | 56 | 100 | NR | NR | NR | NR | NR | NR | NR | NR
Moinpour, 2000 | U.S. | NR | NR | NR | NR | NR | 100 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Mouton, 1997 | U.S. | 80 | NR | <56->72 | NR | <25,000-≥25,000 | 0 | 36 | 0 | 0 | 64 | 0 | NR | NR | NR | NR
Outlaw, 2000 | U.S. | 52 | NR | <40->61 | NR | NR | NR | 2 | 0 | 2 | 96 | 0 | NR | NR | NR | NR
Paskett, 2002 | U.S. | 360 | 47 | NR | NR | NR | 84 | NR | NR | NR | NR | NR | NR | NR | NR | 100
Pinto, 2000 | U.S. | 73 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Randall-David, 2001 | U.S. | 37 | 55 | 18–72 | NR | NR | 8 | 31 | 6 | NR | 58 | 3 | NR | NR | NR | 73
Roberson, 1994 | U.S. | 28 | NR | NR | NR | NR | 12 | 29 | 36 | 0 | 0 | 36 | NR | NR | NR | NR
Robinson, 1996 | U.S. | 46 | NR | NR | NR | NR | 100 | 100 | NR | NR | NR | NR | NR | NR | NR | NR
Sateren, 2002 | U.S. | 24,332 | NR | 0->80 | NR | NR | 44 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Sears, 2003 | U.S. | 558 | 57 | NR | NR | NR | 0 | 6 | NR | NR | 85 | NR | NR | NR | NR | NR
Simon, 2004 | U.S. | 319 | 55 | NR | NR | NR | 0 | 32 | NR | NR | 57 | NR | NR | NR | NR | NR
Spaight, 1984 | U.S. | 23 | NR | 33–65 | NR | NR | 87 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Thornquist, 1991 | U.S. | 1,284 | NR | 45–74 | NR | NR | 52 | NR | NR | NR | NR | NR | NR | 35 | NR | NR
Twelves, 1998 | Non-U.S. | 4,688 | NR | <50-≥80 | NR | NR | 0 | NR | NR | NR | NR | NR | NR | 9 | NR | NR
Woods, 2002 | U.S. | 120 | 41 | NR | NR | NR | 27 | 100 | NR | NR | NR | NR | NR | NR | NR | NR

* Kemeny, 2003 reports that 23% were Latino/Hispanic or African American.

AA = African American

Adol = Adolescent

AIAN = American Indian/Alaska Native

Lat/Hisp = Latino/Hispanic

NR = Not reported

PI = Pacific Islander

SES = Socioeconomic status

Evidence Table 5-3. Results of Studies Investigating the Documented Barriers and Promoters of Participation of Underrepresented Populations in Cancer Prevention and Treatment Trials (Key Question 5)

Author, Year | Type of Barrier/ Promoter | Patient Barrier Associated with Decrease in Reported Enrollment | Patient Promoter Associated with Increase in Reported Enrollment | Provider Barrier Associated with Decrease in Reported Enrollment | Provider Promoter Associated with Increase in Reported Enrollment | Study Design Barrier Associated with Decrease in Reported Enrollment | Study Design Promoter Associated with Increase in Reported Enrollment | Healthcare System Barrier Associated with Decrease in Reported Enrollment | Healthcare System Promoter Associated with Increase in Reported Enrollment | Barriers/ Promoters Modified by Cultural Factors?
Adams-Campbell, 2004 | Study design | NR | NR | NR | NR | Comorbidity exclusion; Functional status; Diagnostic test result cut-off; Lack of available protocols | NR | NR | NR | No
Advani, 2003 | Patient | Lack of education about clinical trials*; Perceived harms of clinical trial participation*; Chance of side effects*; Distance to clinic* | Younger age*; Altruism*; Perceived benefits of clinical trial participation | NR | NR | NR | NR | NR | NR | No
Barofsky, 1979 | Patient | NR | Being male* | NR | NR | NR | NR | NR | NR | No
Berman, 1998 | Patient; Provider | NR | Lack/ inadequate health insurance for Latinos; Opportunistic strategies for Latinos | NR | Communication/ Method of presentation for Latinos and AAs | NR | NR | NR | NR | Yes: Difference between Latinos and AAs regarding reasons for participation
Bieniasz, 2003 | Patient | Intervention characteristics* | NR | NR | NR | NR | NR | NR | NR | No
Brewster, 2002 | Patient | Did not wish to participate in study; Family considerations (childcare problems); Work conflict; No time; Modesty / embarrassment; Uncomfortable with test; Transportation; Other insurance / physician / clinic | NR | NR | NR | NR | NR | NR | NR | No
Broome, 2001 | Patient | NR | Chance for better treatment; altruism | NR | NR | NR | NR | NR | NR | No
Broome, 2003 | Patient | NR | Family considerations; Trust, communication, and love of parents | NR | NR | NR | NR | NR | NR | No
Brown, 2000 | Patient | Fear; Transportation; Family considerations; Taste of Drug; Mistrust of research and medical system; Lack of health insurance / inadequate health insurance; Lack of education about clinical trials | NR | NR | NR | NR | NR | NR | NR | No
Brown, 2003 | Patient | AA older age*; Lower income* | Male gender* | NR | NR | NR | NR | NR | NR | Yes
Chen, 2000 | Patient; Provider; Study design | Patient refusal | NR | Physician choice | NR | Comorbidity exclusion; Functional status; Previous cancer | NR | NR | NR | No
Comis, 2003 | Patient | Age | NR | NR | NR | NR | NR | NR | NR | No
Diener-West | Patient; Study design | Age*; Living near treatment center* | NR | NR | NR | NR | Large tumor size* | NR | NR | No
Ford, 2004 | Patient; Study design | Unlisted telephone number*; Age* | Low income level* | NR | NR | NR | NR | NR | NR | No
Fouad, 2000 | Patient; Provider; Study design | Mistrust of research and medical system; Time commitment; Indirect costs; Lack/inadequate health insurance; Lack of education about trials; Blood draw; Radiation involvement; Past experiences | Benefit to family; Benefit to church | Provider attitudes; Skepticism about low-income patients' ability to participate; Concern that their patients would be randomized | Education programs for community physicians; Involvement of providers in prevention trials | Length of study/visit structure; Complexity of forms | Easy to read consent forms; Using recruiters who are known to community | NR | NR | No
Fouad, 2001 | Patient | Mistrust of research and medical system; Cultural barriers; Job issues; Indirect costs; Lack of education about trials; Lack of knowledge about origins of cancer; Culturally relevant education about clinical trials; Perceived harms of trial participation | Provide transportation; Flexible scheduling; Provide childcare; Incentives (free meals); Adequate knowledge about the study; Workshops on trials; Trust | NR | NR | NR | NR | NR | NR | No
Green, 2000 | Patient | Mistrust of research and medical system; Time commitment; Family considerations; Perceived harms of trial participation; Radiation involved in treatment | Altruism*; Incentives*; No cost treatment* | NR | NR | NR | NR | NR | NR | No
Grunfeld, 2002 | Patient; Provider; Study Design | Mistrust of researcher and medical system; Transportation; Language barrier; Perceived harms of clinical trial participation; Physician expertise; Physician discouragement | Incentives (financial or other); Trial beneficial to them; Hope for care; Receive extra care; Benefit future generations | Provider attitudes; Communication / method of presentation; Physician beliefs about patient preference | NR | Excessive requirements of study | NR | NR | NR | No
Hunter, 1987 | Patient; Provider; Study Design | Experimentation; Treatment toxicity; Costs | NR | Physician's preference for a specific treatment or alternative therapy | NR | Comorbidity exclusion; Age exclusion; Functional status /Poor performance | NR | NR | NR | No
Kaluzny, 1993 | Patient; Provider; Study design; Healthcare system | Mistrust of research and medical system; Fear; Transportation; Family considerations; Language barrier; Job issues; Indirect costs; Limited education or low literacy; Socio-economic conditions of inner-city communities | NR | Mistrust of researchers; Provider attitudes; Little time available per patient; Lack of interest in protocol studies (unless money); Lack of support staff | Incentive | Comorbidity exclusion; Length of study/visit structure; Late stage disease | NR | Lack of dissemination of study opportunities to provider/ patient; Lack of language services; lack of support staff to facilitate protocol activity | NR | No
Kemeny, 2003 | Patient; Provider | Age*; Disease stage*; Number of comorbidities* | NR | Toxicity of treatment; Thought patient ineligible; Patient comorbid conditions | NR | NR | NR | NR | NR | No
Kemp, 1984 | Patient | NR | Less control over health decisions | NR | NR | NR | NR | NR | NR | No
Kornblith, 2002 | Patient; Provider; Study design | Transportation; Lack/ inadequate health insurance; Toxicity of treatment; Co-morbidity; Patient unable to understand trial | NR | NR | Provider attitudes; Communication/ method of presentation | Comorbidity exclusion; Life expectancy | NR | NR | NR | No
Krailo, 1993 | Study design | NR | NR | NR | NR | Age exclusion; Treatment policies; Lack of available protocols | NR | NR | NR | No
Lee, 1999 | Patient | NR | Willingness to take pills | NR | NR | NR | NR | NR | NR | No
Lerman, 1994 | Patient | NR | Impact of diagnosis on risk perception*; >HS education; if > HS education: marriage, unemployment, # of affected relatives; >HS education: age, employment; Age* | NR | NR | NR | NR | NR | NR | No
Lewis, 2003 | Patient | Protocol exclusions | NR | NR | NR | Comorbidity exclusion; Functional status; Diagnostic test cut-off | Life expectancy | NR | NR | No
Ling, 2000 | Study design | NR | NR | NR | NR | Entry criteria | NR | NR | NR | No
McCaskill-Stevens, 1999 | Patient; Provider; Study design; Healthcare system | Mistrust of research and medical system; Fear; Cultural barriers; Poverty / cost to patient | Culturally relevant education about clinical trials | Mistrust of researchers; Lack of physician awareness of trials; Insufficient resources; Lack of proven therapy | NR | Length of study/visit structure | NR | Lack of minority personnel; Lack of minority investigators; Lack of dissemination of study opportunities to provider/ patient | NR | No
Millon-Underwood, 1993 | Patient | Mistrust of medical research; Perceived harms of clinical trial participation | Hope; Altruism; Perceived efficacy | NR | NR | NR | NR | NR | NR | No
Moinpour, 2000 | Patient; Study design | Mistrust of research | NR | NR | NR | Lack of time to establish presence in communities | NR | NR | NR | No
Mouton, 1997 | Patient | Mistrust of research and medical system*; Perception of researchers not caring about patient | Preference for study's Principal Investigator to be Black; Perception that it is better to be treated by research doctors | NR | NR | NR | NR | NR | NR | No
Outlaw, 2000 | Patient; Provider; Study design | Mistrust of medical research; Fear; Language barriers; cultural barriers; Indirect costs; Religious/ spiritual beliefs; Lack of education (culturally relevant) about clinical trials; Perceived harms of trial participation; Lack of comfort with technology care; Lack of family support; Perceived discrimination; Lack of access to health care | NR | Mistrust of researchers; Provider attitudes; Lack of minority providers; Lack of support staff; Additional time required; concern in patient age frailty; Discomfort | NR | Complexity of clinical trials; Late stage disease | NR | NR | NR | No
Paskett, 2002 | Patient; Provider; Study design | Mistrust of research & medical system; Discomfort; Transportation; Unfamiliar physician; Costs; Lack /inadequate health insurance; Lack of education about trials; Perceived harms of participation | NR | Logistical burden; Cost to patient; Perceived treatment risk; Established referral patterns | NR | Eligibility | NR | NR | NR | No
Pinto, 2000 | Patient; Provider; Study design; Healthcare system | Mistrust of medical research; Fear; Cultural barriers; Lack of education about trials; Perceived harms of participation; Physicians do not offer trials; Cost | Culturally relevant education about clinical trials | Provider attitudes; Mistrust of researchers; Cultural barriers; Lack of provider awareness about trial; Lack of time; Racial bias | Incentive (financial or other) | Comorbidity exclusion; Length of study/visit structure; Protocols too complex; Randomization | NR | Lack of cultural competence among provider/staff; Lack of dissemination of study opportunities to provider/ patient; Lack of access to institution | NR | No
Randall-David, 2001 | Patient; Provider; Healthcare system | Mistrust of medical research; Fear; Lack of knowledge about origins of cancer; Transportation; Time commitment; Family considerations; Religious/ spiritual beliefs; Lack of education about trials; Perceived harms of trial participation | Altruism; Incentives (reimbursement); Perceived benefit of trial participation | Mistrust of researcher; Communication / method of presentation | NR | NR | NR | Lack of dissemination of study opportunities to provider/ patient | NR | No
Roberson, 1994 | Patient | Mistrust of medical research; Fear; Access to information; Time commitment; Language barriers; Cultural barriers; Lack of education about trials; Do not like to get involved; Lack of information / awareness | Incentives; Culturally relevant education about trials; Perceived benefits of trial participation | NR | NR | NR | NR | NR | NR | Yes: Among Latino / Hispanic participants
Robinson, 1996 | Patient; Provider; Healthcare system | Mistrust of research/ medical system; Fear; Lack of knowledge about origins of cancer; Lack of education about trials; Perceived harms of trial participation; Concerns about randomization | Incentives; Culturally relevant education about trials; Perceived benefits of trial participation | Mistrust of researchers; Provider attitudes; Communication/ method of presentation | Competent/ experienced physician/ researcher; Compassionate provider | NR | NR | Lack of dissemination of study opportunities to provider/ patient | Reputation of medical facility | No
Sateren, 2002 | Patient; Provider; Healthcare system | Lack/inadequate health insurance*; Being Black male aged 30-59 years*; Asian adults / Latino / Hispanic adults* | Living in suburban area; Higher SES | NR | Higher number of oncology specialists | NR | NR | NR | Presence of cancer programs | No
Sears, 2003 | Patient; Study design | Time commitment; Willingness to travel, Stress; ≥ 65 years old; minority; Not married | NR | NR | NR | Medication exclusion; Metastatic disease | NR | NR | NR | No
Simon, 2004 | Patient; Provider; Study design | Leaving care of physician to participate in trial; Lack/ inadequate health insurance* | NR | Patient likely to be non-compliant; No protocol available for disease stage | NR | Age exclusion; Medication exclusion | NR | NR | NR | No
Spaight, 1984 | Patient; Provider; Study design | Age; Transportation; Inability to understand protocol; Patient resistance or potential noncompliance; Cost | NR | NR | Advancement of cancer field | Participation requires too much travel; Failure to use most effective drug; Too many lab tests | NR | NR | NR | No
Thornquist, 1991 | Patient | Age (50-54; 65-69)* | Age (60-64; 55-59)* | NR | NR | NR | NR | NR | NR | No
Twelves, 1998 | Patient; Provider | Age* | Place of initial treatment* | NR | Surgeons with high case load*; Referral to an oncologist* | NR | NR | NR | NR | No
Woods, 2002 | Patient; Provider; Study design | Mistrust of medical research; Job issues; Transportation problems; Time commitment; Family considerations; Perceived harms of trial participation; Not ready to quit smoking | Transportation support; Incentives; Perceived benefit of trial participation; Support/ encouragements/ prayer; Certainty of receiving actual medication | Training in communicating with patients; Communication/ method of presentation | NR | NR | Length of study/visit structure; Reminder phone calls | NR | NR | No

* Statistically significant

HS = High school

NR = Not reported

PSA = Prostate specific antigen test

SES = Socioeconomic status

Evidence Table 5-4. Quality of Studies Investigating the Documented Barriers and Promoters of Participation of Underrepresented Populations in Cancer Prevention and Treatment Trials (Key Question 5)

Author, Year | Representativeness^a^ | Justification^b^ | Bias^c^ | Reliability & Validity^d^ | Analysis^e^
Adams-Campbell, 2004 | | | | | NA
Advani, 2003
Barofsky, 1979
Berman, 1998
Bieniasz, 2003 | | | | | NA
Brewster, 2002
Broome, 2001 | | | | | NA
Broome, 2003 | | | | | NA
Brown, 2000
Brown, 2003
Chen, 2000 | | | NA | NA | NA
Comis, 2003
Diener-West | | | NA | NA | NA
Ford, 1998 | | | NA | NA | NA
Ford, 2003
Fouad, 2000 | | | | | NA
Fouad, 2001 | | | | | NA
Green, 2000 | | | | | NA
Grunfeld, 2002 | | | | | NA
Hunter, 1987 | | | | | NA
Kaluzny, 1993 | | | NA | NA | NA
Kemeny, 2003
Kemp, 1984
Kornblith, 2002
Krailo, 1993 | | | NA | NA | NA
Lee, 1999
Lerman, 1994
Lewis, 2003 | | | NA | NA | NA
Ling, 2000
McCaskill-Stevens, 1999 | | | | | NA
Millon-Underwood, 1993
Moinpour, 2000 | | | NA | NA | NA
Mouton, 1997
Outlaw, 2000
Paskett, 2002
Pinto, 2000 | | | | | NA
Randall-David, 2001 | | | | | NA
Roberson, 1994
Robinson, 1996 | | | | | NA
Sateren, 2002 | | | NA | NA | NA
Sears, 2003 | | | | | NA
Simon, 2004
Spaight, 1984 | | | NA | | NA
Thornquist, 1991
Twelves, 1998 | | | NA | NA | NA
Woods, 2002 | | | | | NA

Excellent: ≥ 75% quality score

Good: 50–74% quality score

Fair: 25–49% quality score

Poor: < 25% quality score

NA = Not applicable

a Representativeness: Score was based on a total maximum score of 8 points. This included assessment of how well the studydescribed the study setting and population (2 points), inclusion/exclusion criteria (2 points), non-participating patients (2 points), andpatient characteristics at enrollment (2 patients).

b Justification: Percentage score was based on a total maximum score of 6 points. This included whether the study design wasbased on a conceptual model (2 points), whether the research question and objectives were stated (2 points), and whether thetarget population was adequately justified (2 points).

c Bias: Percentage score was based on a total maximum score of 4 points. This included the response rate or proportion of eligible people that actually completed the questionnaire (2 points), and the description of how study participants were selected (2 points).

d Reliability and Validity: Percentage score was based on a total maximum score of 6 points. This included intra-rater reliability (2 points), inter-rater reliability (2 points), and validation of the survey instrument (2 points)

e Analysis: Percentage score was based on a total maximum score of 4 points. This included assessment of whether the study was planned to have adequate power to detect differences within groups (2 points), and whether the study was planned to have adequate power to detect changes within groups.

Evidence Table 6-1. Characteristics of Studies on the Effects of Attitudes and Perceptions of Healthcare Providers on the Efficacy or Effectiveness of Strategies for Recruitment of Underrepresented Populations into Cancer Prevention and Treatment Trials (Key Question 6)

Author, Year | Sample Size | Study Setting | Target Population of Study | Targeted Under-represented Population | Study Design | How Measured | Type of Cancer Studied | Study Objective(s) | Type of Cancer Trial
Benson, 1991 | 252 | Community | Physicians | NR | Descriptive | Mailed survey | NR | Investigate the reasons physicians do not place patients in clinical trials. | Treatment
Fallowfield, 1997 | 357 | Community | Physicians | NR | Descriptive | Mailed survey | All | Compare results of physician orientation profile used in the ECOG study with that obtained from surveying British oncologists. | Treatment
Kemeny, 2003 | 154 | Hospital inpatient | Patients; Participants | Elderly | Case-control | Telephone survey; Interview | Breast | A. Test the extent to which eligible breast cancer patients older than 65 years were offered trials compared to younger patients. | Treatment
| | | | | | | | B. Assess reasons why oncologists chose not to offer a trial to their older patients and why patients chose to, or refused to participate.
Kornblith, 2002 | 156 | Hospital inpatient | Physicians | Elderly | Descriptive | Mailed survey | Breast | Test the magnitude of barriers to recruitment among elderly breast cancer patients from physician perspective. | Treatment
McCaskill-Stevens, 1999 | 90 | Community | Physicians | Minorities | Descriptive/ Qualitative | Open-ended questionnaire | Breast, Colorectal, Lung, Prostate | Identify barriers and solutions to African American accrual to cancer trials. | Treatment / Prevention
Paskett, 2002 | 196 (in 1993); 168 (in 1996) | Community | Physicians | Rural | CCT | Mailed survey | Breast, colorectal | A. Evaluate a Rural Cancer Care Intervention. | Treatment
| | | | | | | | B. Assess rural-based primary care physician knowledge, attitudes, and beliefs about patient and physician barriers to accrual to cancer treatment trials.
Pinto, 2000 | 73 | Community | Physicians; Investigators | Minorities | Descriptive/ Qualitative | Focus groups | All | Identify barriers to accrual of minority patients & develop solutions to these barriers from physician's perspective. | Treatment / Prevention
Richardson, 1986 | 59 | Community | Physicians | NR | Descriptive | Mailed survey | NR | Assess attitudes and perceptions of medical oncologists regarding cancer trial participation. | Treatment
Simon, 2004 | 319 | Hospital inpatient | Patients; Participants | African Americans | Descriptive | Survey | Breast | Understand factors associated with accrual to breast cancer clinical trials. | Treatment / Prevention
Spaight, 1984 | 23 | Community | Physicians | NR | Descriptive/ Qualitative | Face-to-face interview | NR | Assess factors influencing clinical trials participation from the perspective of medical oncologists and hematologists. | Treatment

CCT = Concurrent controlled trial

ECOG = Eastern Cooperative Oncology Group

NR = Not reported

Evidence Table 6-2. Target Population Characteristics of Healthcare Providers Discussed in Studies on the Efficacy or Effectiveness of Strategies for Recruitment of Underrepresented Populations into Cancer Prevention and Treatment Trials (Key Question 6)

Author, Year | U.S.or Non-U.S. Study | Mean Age, y | Age Range, y | % Male | % AA | % AIAN | % Cauc | % Elderly
Benson, 1991 | U.S. | NR | NR | NR | NR | NR | NR | NR
Brown, 2003 | U.S. | NR | NR | 33 | 49 | NR | 51 | 100
Fallowfield, 1997 | U.S. | NR | NR | NR | NR | NR | NR | NR
Kemeny et al, 2003 | U.S. | NR | 48 to 74 | NR | NR | NR | NR | 50
Kornblith, 2002 | U.S. | NR | NR | 69 | 3 | 3 | 87 | 7
McCaskill-Stevens, 1999 | U.S. | NR | NR | NR | 1 | 0 | 0 | NR
Paskett, 2002 | U.S. | 49 | NR | 84 | NR | NR | NR | NR
Pinto, 2000 | U.S. | NR | NR | NR | NR | NR | NR | NR
Richardson, 1986 | U.S. | NR | NR | 1 | NR | NR | NR | NR
Simon, 2004 | U.S. | 55 | NR | NR | 32 | NR | 57 | NR
Spaight, 1984 | U.S. | NR | 33 to 65 | 1 | NR | NR | NR | NR

AA = African American

AIAN = American Indian/Alaska Native

Cauc = Caucasian

NR = Not reported

Evidence Table 6-3. Quality of Studies on the Effects of Attitudes and Perceptions of Healthcare Providers on the Effectiveness of Strategies for Recruitment of Underrepresented Populations into Cancer Prevention and Treatment Trials (Key Question 6)

Author, Year | Representativeness^a^ | Justification^b^ | Bias^c^ | Reliability & Validity^d^ | Analysis^e^
Benson, 1991
Fallowfield, 1997
Kemeny, 2003
Kornblith, 2002
McCaskill-Stevens et al., 1999 | | | | | N/A
Paskett, 2002
Pinto, 2000 | | | | | N/A
Richardson 1986
Simon, 2004
Spaight, 1984 | | | | | N/A

N/A= Not Applicable

Excellent: 75–100% quality score

Good: 50–74% quality score

Fair: 25–49% quality score

Poor: <25% quality score

a - Representativeness: Score was based on a total maximum score of 8 points. This included assessment of how well the study described the study setting and population (2 points), inclusion/exclusion criteria (2 points), non-participating patients (2 points) and patient characteristics at enrollment (2 patients).

b - Justification: Percentage score was based on a total maximum score of 6 points. This included whether the study design was based on a conceptual model (2 points), whether the research question and objectives were stated (2 points), and whether the target population was adequately justified (2 points).

c - Bias: Percentage score was based on a total maximum score of 4 points. This included the response rate or proportion of eligible people that actually completed the questionnaire (2 points), and the description of how study participants were selected (2 points).

d -Reliability and Validity: Percentage score was based on a total maximum score of 6 points. This included intra-rater reliability (2 points), inter-rater reliability (2 points), and validation of the survey instrument (2 points)

e - Analysis: Percentage score was based on a total maximum score of 4 points. This included assessment of whether the study was planned to have adequate power to detect differences within groups (2 points), and whether the study was planned to have adequate power to detect changes within groups.

Evidence Table 6-4. Provider Barriers/Promoters on the Efficacy or Effectiveness of Strategies for Recruitment of Underrepresented Populations into Cancer Prevention and Treatment Trials (Key Question 6)

Author, Year | Type of Barrier/ Promoter | Provider Barrier/ Promoter Associated with Decrease in Enrollment | Provider Barrier/ Promoter Associated with Increase in Enrollment | Study Design Barrier/ Promoter Associated with Decrease in Enrollment | Healthcare System Barrier/ Promoter Associated with Decrease in Enrollment
Benson, 1991 | Provider | Communication/ method of presentation; Need to obtain informed consent; Follow-up time; Insufficient resources | | Age exclusion; Strict protocols
Fallowfield, 1997 | Provider | Provider attitudes; Communicating/ method of presentation; Perceived patient intelligence as low | Social class (i.e., working class easier to approach) | Disease stage or location
Kemeny, 2003 | Provider; Patient | Patient age*; Disease stage (Stage II)*; Comorbidity*; Provider attitudes; Toxicity of treatment; Ineligibility
Kornblith, 2002 | Provider; Patient; Study design | | Provider attitudes; Communication/ method of presentation | Comorbidity exclusion; Life expectancy
McCaskill-Stevens, 1999 | Provider; Patient; Study design; Healthcare system | Mistrust of researchers; Lack of provider awareness of trials; Insufficient resources; Lack of proven therapy | | Length of study/visit structure | Lack of minority investigators; Lack of other minority personnel; Lack of dissemination of study opportunities to provider
Paskett, 2002 | Provider; Patient | Provider attitudes; Logistics; Cost; Referral patterns; Treatment risk; | | Eligibility
Pinto, 2000 | Provider; Patient; Study design; Healthcare system | Provider attitudes; Mistrust of researchers; Cultural barriers; Lack of provider awareness about trial; Lack of time; Racial bias | Incentive (financial or other) | Comorbidity exclusion; Length of study/visit structure; Protocols too complex; Randomization | Lack of cultural competence among providers and/or staff; Lack of dissemination of study opportunities to provider/ patient; Lack of access to institution conducting cancer trial
Richardson, 1986 | Provider | Patient age | Patients with regionalized disease*; Physician training*; Institutional affiliation*
Simon, 2004 | Provider; Patient | Potential patient non-compliance; No protocol available for disease stage | | Age exclusion*; Medication exclusion*
Spaight, 1984 | Provider; Patient; Study design | Patient age; Cost; Potential patient non-compliance; Lack of patient understanding about trial; Comorbidity | Advancement of cancer medicine | Toxicity and side effects; Protocol (i.e., requires too much travel; failure to use most effective drug; too many lab tests)

* Statistically significant