# Appendix D. EPC Recruitment to Clinical Trials Abstract Review Form

Reviewer: _________

Data Entry: ________

Delete article because (check one): | Article may address the following questions (check all that apply):
□ not in English | □ efficacious research methodologies (Q1)
□ not U.S.-based study | □ measures of success (Q2)
□ does not include human data | □ participation in treatment trials (Q3)
□ no original data | □ participation in prevention trials (Q4)
□ meeting abstract (no full article for review) | □ documented barriers/promoters (Q5)
□ does not address cancer treatment or prevention | □ barriers/promoters differ (Q5a)
□ does not report a controlled trial or discuss recruitment to a controlled trial | □ barriers/promoters modified (Q5b)
□ other: (specify)_____________________ | □ attitudes and perceptions (Q6)
□ Unclear: get article to decide | □ This article does not apply to any of the questions
Do not go on if any item above is checked. | □ Get article for reference regarding:___________________________________________