# Appendix C. EPC Recruitment: Search Strategies

MEDLINE Strategy

(neoplasm[mh] OR cancer[tw] OR carcino*[tiab] OR tumor[tiab] OR oncolog*[tiab]) AND (patient selection[mh] OR recruit*[ti] OR participat*[ti] OR enrol*[ti] OR enlist*[ti]) AND eng[la] NOT (animal[mh] NOT human[mh]) | 3676
ADD “OR refer*[ti]” | 6844
Most of these titles aren't relevant
Try ((recruitment terms) AND (strategies/methods/etc)) | 1688
ADD “AND strateg*[tiab] OR method*[tiab]”
Can't use this phrase because the Donovan et al. study doesn't mention strategy or method

PsychINFO Strategy

neoplasm or cancer or carcinogen or tumor or oncolog* | 17106
patient selection or TI recruit* or TI participat* or TI enrol* or TI enlist* or TI refer* | 18396
trial* or stud* | 1186777
And LA english
(neoplasm or cancer or carcinogen or tumor or oncolog*) and (patient selection or TI recruit* or TI participat* or TI enrol* or TI enlist* or TI refer*) and (trial* or stud*) And LA english and human | 152

CINAHL Strategy

neoplasm or cancer or carcino* or tumor or oncolog* | 67915
MW patient selection or MW research subject recruitment or TI recruit* or TI participat* or TI enrol* or TI enlist* or TI refer* | 12547
trial* or stud* | 306204
And LA English and
(neoplasm or cancer or carcino* or tumor or oncolog*) and (MW patient selection or MW research subject recruitment or TI recruit* or TI participat* or TI enrol* or TI enlist* or TI refer*) and (trial* or stud*) | 1070
(neoplasm or cancer or carcino* or tumor or oncolog*) and (MW patient selection or MW research subject recruitment or TI recruit* or TI participat* or TI enrol* or TI enlist* or TI refer*) and (trial* or stud*) and LA English and human | 284

Cochrane Database (CENTRAL and Methodology Review) Strategy

Neoplasm* | 20087
neoplasm* OR cancer OR carcino* OR tumor* or oncolg* | 39642
(neoplasm* or cancer or carcino* or tumor* or oncolg*) and (patient selection or recruit*:ti or particip*:ti or enrol*:ti or enlist*:ti or refer*:ti) | 436
(neoplasm* or cancer or carcino* or tumor* or oncolg*) and (patient selection or recruit*:ti or particip*:ti or enrol*:ti or enlist*:ti or refer*:ti) and (trial* OR stud*) | 416
(neoplasm* or cancer or carcino* or tumor* or oncolg*) and (patient selection or recruit*:ti or particip*:ti or enrol*:ti or enlist*:ti or refer*:ti) and (trial* OR stud*) NOT (animal NOT human) | 414

C2-SPECTR Strategy

All Indexed Fields: {neoplasm} or {cancer} or {carcino} or {tumor} or {oncolog} | 16
All Indexed Fields: {neoplasm} or {cancer} or {carcino} or {tumor} or {oncolog} | 28
OR All Non-Indexed Fields: {neoplasm} or {cancer} or {carcino} or {tumor} or {oncolog}
All Indexed Fields: {neoplasm} or {cancer} or {carcino} or {tumor} or {oncolog} | 18
OR All Non-Indexed Fields: {neoplasm} or {cancer} or {carcino} or {tumor} or {oncolog}
AND All Non-Indexed Fields {patient selection} or {recruit} or {participat} or {enrol} or {enlist} or {refer}
All Indexed Fields: {neoplasm} or {cancer} or {carcino} or {tumor} or {oncolog} | 15
OR All Non-Indexed Fields: {neoplasm} or {cancer} or {carcino} or {tumor} or {oncolog}
AND All Non-Indexed Fields {patient selection} or {recruit} or {participat} or {enrol} or {enlist} or {refer}
AND All Non-Indexed Fields {trial} or {stud}
All Indexed Fields: {neoplasm} or {cancer} or {carcino} or {tumor} or {oncolog} | 15
OR All Non-Indexed Fields: {neoplasm} or {cancer} or {carcino} or {tumor} or {oncolog}
AND All Non-Indexed Fields {patient selection} or {recruit} or {participat} or {enrol} or {enlist} or {refer}
AND All Non-Indexed Fields {trial} or {stud}
NOT All Non-Indexed Fields {animal} NOT {human}