# Appendix B. EPC Recruitment: Journals Hand Searched

All journals searched January 2003 through June 2004.

## Journal Title

American Journal of Epidemiology

American Journal of Preventive Medicine

American Journal of Public Health

Annals of Epidemiology

Annals of Family Medicine

Archives of Pediatric and Adolescent Medicine

British Medical Journal

CA - A Cancer Journal for Clinicians

Cancer

Cancer Causes and Control

Cancer Epidemiology, Biomarkers and Prevention

Clinical Trials

Controlled Clinical Trials

Ethnicity and Disease

Ethnicity and Health

Gerontologist

Gerontology

Health Services Research

Journal of General Internal Medicine

Journal of Clinical Epidemiology

Journal of Clinical Oncology

Journal of Community Health

Journal of the American Medical Association (JAMA)

Journal of Health Care for the Poor and Underserved

Journal of the National Cancer Institute (JNCI)

Journal of the National Medical Association

Annals of the New York Academy of Science

Journal of School Health

Lancet

New England Journal of Medicine

Pediatrics

Preventive Medicine

Psycho- Oncology

Social Science and Medicine