# Appendix A. EPC Recruitment: Technical Experts and Peer Reviewers

## External Technical Experts and Peer Reviewers

- Luis Baez, M.D.
- Division of Hemetology and Oncology
- University of Puerto Rico
- San Juan, PR

- Michaele Christian
- National Cancer Institute
- U.S. National Institutes of Health
- Bethesda, MD

- Mona Fouad, M.D., M.P.H.
- The University of Alabama at Birmingham
- Birmingham, AL

- Cary Gross, M.D.
- Yale University
- New Haven, CT

- Melissa Hudson, M.D.
- Department of Hematology-Oncology
- Director, After Completion of Therapy Clinic
- St. Jude Children's Research Hospital

- Chanita Hughes, Ph.D.
- Assistant Professor
- Department of Psychiatry
- University of Pennsylvania
- Philadelphia, PA

- Marjorie Kagawa-Singer, Ph.D., M.N., R.N.
- Associate Professor
- UCLA School of Public Health & Asian American Studies
- Los Angeles, CA

- *Judith Kaur, M.D.
- Medical Director for Native American Programs
- Associate Professor of Oncology
- Mayo Clinic College of Medicine
- Rochester, MN

- Jon Kerner, Ph.D.
- Cancer Prevention & Control
- National Cancer Institute
- U.S. National Institutes of Health
- Bethesda, MD

- Worta McCaskill-Stevens, Ph.D.
- Treatment & Prevention Trials, Minority
- Physicians and Clinical Trial Accrual
- National Cancer Institute
- U.S. National Institutes of Health
- Bethesda, MD

- *Electra D. Paskett, Ph.D.
- Division of Epidemiology and Biometrics
- The Ohio State University
- Columbus, OH

- Eliseo Perez-Stable, M.D.
- Dept. General Internal Medicine
- University of California, San Francisco
- San Francisco, CA

- *Amelie Ramirez
- Associate Director for Community Research
- San Antonio Cancer Institute
- San Antonio, TX

- Vickie Shavers, Ph.D.
- Racial/ Ethnic Health Disparities
- National Cancer Institute
- U.S. National Institutes of Health
- Bethesda, MD

- Cynthia Vinson
- Dissemination and Diffusion
- National Cancer Institute
- U.S. National Institutes of Health
- Bethesda, MD

* Member of the Special Populations Network (SPN)

## Internal Technical Experts

- Martin Abeloff, M.D.
- Director and Professor
- Oncology Administration
- Johns Hopkins University School of Medicine

- Lawrence Appel, M.D., M.P.H.
- Professor
- Division of General Internal Medicine
- Johns Hopkins University School of Medicine

- Steve Goodman, M.D., Ph.D.
- Associate Professor Oncology-Clinical Trials and Biometrics
- Johns Hopkins University School of Medicine

- David Levine, M.D.
- Professor
- Division of General Internal Medicine
- Johns Hopkins University School of Medicine

- Jonathan Samet, M.D.
- Professor and Chair
- Department of Epidemiology
- Johns Hopkins University Bloomberg
- School of Public Health