# Appendixes

Appendix A. EPC Recruitment: Technical Experts and Peer Reviewers

Appendix B. EPC Recruitment: Journals Hand Searched

Appendix C. EPC Recruitment: Search Strategies

Appendix D. EPC Recruitment to Clinical Trials Abstract Review Form

Appendix E. EPC Recruitment: Article General Abstraction Form

Appendix F. Evidence Tables