# List of Acronyms/Abbreviations

AAFP | American Academy of Family Practitioners
AAP | American Academy of Pediatrics
ACP | American College of Physicians
AHRQ | Agency for Healthcare Research and Quality
ARR | Absolute Risk Reduction
ATS | American Thoracic Society
β | Beta
BODE | (B)=Body mass index; (O)=airflow Obstruction; (D)=Dyspnea; (E)=Exercise capacity
CCT | Controlled Clinical Trial
CI | Confidence Interval
CO | Carbon Monoxide
COPD | Chronic Obstructive Pulmonary Disease
CRQ | Chronic Respiratory disease Questionnaire
ED | Emergency Department
EPC | Evidence-based Practice Center
ERS | European Respiratory Society
FEV_1_ | Forced Expiratory Volume in 1 second
FVC | Forced Vital Capacity
GOLD | Global initiative for Obstructive Lung Disease
ISOLDE | Inhaled Steroids in Obstructive Lung Disease
ITT | Intention to Treat
LABA | Longacting beta agonists
LHS | Lung Health Study
LR | Likelihood Ratio
N | Number
NHANES | National Health and Nutrition Examination Survey
NIMV | Non-Invasive Mechanical Ventilation
NLHEP | National Lung Health Education Program
NRTs | Nicotine replacement therapies
OLD | Obstructive Lung Disease
OR | Odds Ratio
PFT | Pulmonary Function Test
RC | Repeat Counseling
RCT | Randomized Control Trials
RD | Risk Difference
RR | Risk Ratio
SGRQ | St. George's Respiratory Questionnaire
TEP | Technical Expert Panel
WMD | Weighted Mean Difference