# Summary Tables

Summary Table 1. Spirometry-based national estimates of chronic obstructive pulmonary disease prevalence and low lung function

Study (Reference) | Country | Diagnostic Criteria | Age, Year | Prevalence (%), Overall | Prevalence (%), Men | Prevalence (%), Women | Total Sample Size
NHANES III* | United States | Low lung function: FEV1/FVC <70%; FEV_1_ <80% predicted | ≥17 | 6.8 | 7.4 | 6.3 | 16,084
Mannino 2000 ^150^ | | FEV_1_/FVC <70%; FEV_1_ >80% predicted | | 7.2 | Not reported | Not reported
| | With the addition of GOLD 0, defined as symptom of phlegm | | 7.2 | 10.2 | 7.1
| | Total prevalence of subjects with low lung function and at risk | | 21.2 | Not reported | Not reported
CCHS** | Denmark | GOLD stages 1–3 | ≥20 | 14.5 | 18.2 | 11.4 | 13,108
Vestbo 2002 ^149^ | | With the addition of GOLD 0 | | 5.8 | 7.1 | 4.8
| | Total prevalence of subjects with GOLD 0–3 | | 20.3 | 25.3 | 16.2
Mini-Finland Health Survey | Finland | 1) Clinical examination plus spirometry | ≥30 | Not reported | 22 | 7 | 7217
von Hertzen 2000 ^151^ | | 2) FEV_1_/FVC <69% | ≥30 | Not reported | 11 | 5
Isoaho 1994 ^153^ | Finland | Clinical examination plus spirometry | ≥65 | Not reported | 12.5 | 3 | 1196
Po Delta Survey | Italy | European Respiratory Society (ERS) spirometric criteria, defined as FEV_1_/slow vital capacity (VC) <0.88 predicted in men, <0.89 in women | ≥25 | 11 | Not reported | Not reported | 1727
Viegi 2000 ^152^ | | American Thoracic Society (ATS) criteria, defined as FEV_1_/FVC <75% | | 40.4
Bakke 1991 ^154^ | Norway | Symptoms plus spirometry | 18–70 | 5.4 | 5.6 | 5.2 | 1259
| | FEV_1_/FVC <70%; FEV_1_ <80% predicted | 18–70 | 4.5 | 4.8 | 4.2
IBERPOC*** | Spain | ERS spirometric criteria plus reversibility test | 40–69 | 9.1 | 14.3 | 3.9 | 4035
Pena 2000 ^155^

* National Health and Nutrition Examination Survey-NHANES III

** Copenhagen City Heart Study

*** IBERPOC Multicentre Epidemiological Study

Summary Table 2. Prevalence of COPD based upon American Thoracic Society (ATS) or Global Initiative for Chronic Obstructive Lung Disease (GOLD) category spirometric categories for general populations

Variable / Country; Study | % Normal Spirometry and No Respiratory Symptoms (n / N) | % GOLD 0 or “At Risk” / Normal Spirometry + Symptoms of Cough, Sputum (n / N) | % GOLD 1 or Mild - FEV_1_/FVC <70 and FEV_1_ >80% Predicted) (n / N) | % ATS 1 or GOLD 2 or “Moderate” / FEV_1_/FVC <70 and FEV_1_ >50 to 80–85% Predicted) (n / N) | % ATS 2 or 3 or GOLD >3 or “Severe” / FEV_1_/FVC <70 and FEV_1_ <50% Predicted) (n / N) | Study, Population, and Notes
National Health And Nutrition Examination Survey-NHANES III ^150^
United States | 51.6 | 34.4 | 7.2 | 5.4 | 1.5 | NHANES III, Estimated prevalences based on 16,084 U.S. white or black adults selected to be a representative sample of the U.S., >17 years of age, who had pulmonary function testing performed.
| | 7.2 phlegm (approx. GOLD 0) | 50.8% had “any symptom,” (cough, phlegm, wheeze, or dyspnea) | 60.1% had “any symptom,” (cough, phlegm, wheeze, or dyspnea) | 79% had “any symptom,” (cough, phlegm, wheeze, or dyspnea)
National Health And Nutrition Examination Survey-NHANES I ^156^
United States | 67.2 | 16.1 | 7.9 | 7.1 | 1.7 | NHANES I, 5,542 U.S. white or black adults in the final cohort of analysis (of the original 14,407 subjects.
| (3,725 / 5,542) | (had “any respiratory symptom,” defined as cough, sputum, or wheeze) | (438 / 5542) | (393 / 5,542) | (94 / 5,542)
European Community Respiratory Health Survey ^157^
Europe | 84.6 | 11.8 | 2.5 | 1.1 | | Multinational study of randomly selected young adults (aged 20–44) who had 2 FEV_1_ and FVC measurements.
| (12,567 / 14,855) | (1,751 / 14,855) | (369 / 14,855) | (168 / 14,855)
| | | | (GOLD 2–3 were combined)
Differential Diagnosis Between Asthma and COPD-DIDASCO ^158^
Belgium | 85.4 | Not reported | 5.7 | 7.4 | 1.4 | A prospective survey of Belgian subjects aged 35 to 70, visiting general practitioner clinics. Subjects were screened for COPD. Subjects on bronchodilators were removed. 3,158 subjects were questioned regarding COPD symptoms. Spirometry was used on all symptomatic subjects (n=728) and 10% of a random sample with no symptoms (n=243 out of 2,430 total).
| (Some normals reported symptoms, exact percentage unknown)
Copenhagen City Heart Study ^149^
Denmark | 79.7 | 5.9 | 5.1 | 9.2 | <1 | A prospective epidemiologic survey of randomly selected Danish subjects, age >20 who had a least one spirometric measurement. Rates are at baseline.
| (10,441 / 13,108) | (766 / 13,108) | (663 / 13,108) | (1,205 / 13,108) | (33 / 13,108)
| Mean FEV_1_ (L) = 2.7; % pred. = 97 | Mean FEV_1_ (L) = 2.9; % pred. = 100 | Mean FEV_1_ (L) = 2.6; % pred. = 92 | Mean FEV_1_ (L) = 1.7; % pred. = 63 | Mean FEV_1_ (L) = 0.6; % pred. = 23
Mini-Finland Health Survey ^151^
Finland | 58.1 | Not reported | 34.7 | 6.6 | <1 | Randomly selected Finnish subjects, age >30 years. Subjects with normal spirometry may or may not have symptoms.
| (3,956 / 6,810)* | | (2,360 / 6,810) | (451 / 6,810) | (43 / 6,810)
| (asthma and other chronic respiratory. diseases excluded) | | (asthma and other chronic respiratory. diseases excluded) | (asthma and other chronic respiratory. diseases excluded) | (asthma and other chronic respiratory diseases excluded)
Prevalence of COPD in Elderly Finns ^152^
Finland | 90.1 | Not reported | 1.8 | 6.4 | 1.3 | Epidemiologic survey of respiratory diseases in elderly Finnish men and women (age 64–97). Severity based on FEV_1_ % predicted value.
| (687 / 760)* | | (14 / 760) (FEV_1_ % predicted >80) | (49 / 760) (FEV_1_ % predicted 40–79) | (10 / 760) (FEV_1_ % predicted <40)
Po Delta Survey ^153^
Italy - ERS Criteria | 89 | 1 | 8.1 | 1.4 | 0.5 | Cross-sectional epidemiologic survey of Italian subjects, ages 25 to 73. Subjects at risk had a “possible physiological variant” NOT YET DEFINED
| (1,537 / 1,727) | (17 / 1727) | (140 / 1,727) | (24 / 1,727) | (9 / 1,727)
| | (see notes)
Italy - ATS Criteria | 59.6 | 12 | 25.8 | 1.3 | 1.3
| (1,030 / 1,727) | (207 / 1,727) | (446 / 1,727) | (22 / 1,727) | (22 / 1,727)
| | (see notes)
IBERPOC Multicentre Epidemiological Study ^155^
Spain | 90.9 | Not reported | 3.5 | 3.6 | 2 | Epidemiologic survey of randomly selected Spanish men and women, ages 40–69.
| (3,618 / 3,981)* | | (139 / 3,981) | (144 / 3,981) | (80 / 3,981)

* Subjects may or may not be symptomatic and include “at risk”

Summary Table 3. Prevalence of COPD based upon American Thoracic Society (ATS) or Global Initiative for Chronic Obstructive Lung Disease (GOLD) spirometric categories for age

Variable / Country; Study | % Normal Spirometry and No Respiratory Symptoms (n / N) | % GOLD 0 or “At Risk” / Normal Spirometry + Symptoms of Cough, Sputum (n / N) | % GOLD 1 or Mild - FEV_1_/FVC <70 and FEV_1_ >80% Predicted) (n / N) | % ATS 1 or GOLD 2 or “Moderate” / FEV_1_/FVC <70 and FEV_1_ >50 to 80–85% Predicted) (n / N) | % ATS 2 or 3 or GOLD > 3 or “Severe” / FEV_1_/FVC <70 and FEV_1_ <50% Predicted) (n / N) | Study, Population, and Notes
National Health And Nutrition Examination Survey-NHANES III ^150^
Age 25–44 | Not reported | Not reported | 3.7 | 2.3 | Not reported | Estimated prevalence
Age 45–54 | Not reported | Not reported | 8.7 | 7.2 | Not reported
Age 55–64 | Not reported | Not reported | 12.6 | 14.1 | Not reported
Age 64–74 | Not reported | Not reported | 16.5 | 20.7 | Not reported
Age >75 | Not reported | Not reported | 17.8 | 22.9 | Not reported
National Health and Nutrition Examination Survey-NHANES I ^156^
Age 25–39 | 72 (1371 / 1903) | 19.2 (365 / 1903) (see notes) | 4 (76 / 1903) | 2.8 (53 / 1903) | 0.2 (4 / 1903) | Subjects had “any respiratory symptom,” defined as cough, sputum, or wheeze
Age 40–49 | 67.6 (792 / 1,171) | 18.7 (219 / 1,171) (see notes) | 7 (82 / 1,171) | 5.9 (69 / 1,171) | 0.8 (9 / 1,171)
Age 50–59 | 64.7 (412 / 1,168) | 12.8 (150 / 1,168) (see notes) | 9.5 (111 / 1,168) | 10.4 (121 / 1,168) | 2.6 (30 / 1,168)
Age 60–69 | 60.4 (584 / 967) | 12.5 (121 / 967) (see notes) | 12.7 (123 / 967) | 10.7 (103 / 967) | 3.7 (36 / 967)
Age 70–74 | 56.8 (189 / 333) | 11.4 (38 / 333) (see notes) | 14.1 (47 / 333) | 13.5 (45 / 333) | 4.2 (14 / 333)
Po Delta Survey ^153^
Age 25–45, ERS Criteria | 90.3 (862 / 955) | 1.4 (13 / 955) (see notes) | 8 (76 / 955) | 0.4 (4 / 955) | 0 | Described as “possible physiological variant”
ATS Criteria | 73 (697 / 955) | 8.2 (see notes) | 18.3 (175 / 955) | 0.4 (4 / 955) | <1 (1 / 955)
Age ≥45, ERS Criteria | 88.6 (684 / 772) | 0.5 (4 / 772) (see notes) | 8.1 (63 / 772) | 2.6 (20 / 772) | <1 (1 / 772)
ATS Criteria | 43 (332 / 772) | 16.7 (129 / 772) (see notes) | 35.1 (271 / 772) | 2.3 (18 / 772) | 2.8 (22 / 772)
Prevalence of COPD in Norwegians ^154^
Men: age 18–44 | 96.4* | Not reported | 1.3 | 2.3 | 0
Men: age 45–73 | 88.3* | Not reported | 2.4 | 8.6 | 0.6
Women: age 18–44 | 97.9* | Not reported | 1.2 | 0.7 | 0.1
Women: age 45–73 | 90.8* | Not reported | 0.9 | 8.1 | 0.2

* Subjects may or may not be symptomatic and include “at risk”

Summary Table 4. Prevalence of spirometric categories: American Thoracic Society (ATS) or Global Initiative for Chronic Obstructive Lung Disease (GOLD) category criteria for symptoms

Variable / Country; Study | % Normal Spirometry (n / N) | % GOLD 0 or “At Risk” / Normal Spirometry + Symptoms of Cough, Sputum (n / N) | % GOLD 1 or Mild - FEV_1_/FVC <70 and FEV_1_ >80% Predicted) (n / N) | % ATS 1 or GOLD 2 or “Moderate” / FEV_1_/FVC <70 and FEV_1_ >50 to 80–85% Predicted) (n / N) | % ATS 2 or 3 or GOLD > 3 or “Severe” / FEV_1_/FVC <70 and FEV_1_ <50% Predicted) (n / N) | Study, Population, and Notes
National Health and Nutrition Examination Survey-NHANES III ^ 150 ^
Productive cough | 7.9 | 100 | 17.5 | 14.6 | 41.2
Sputum or phlegm | 7.2 | 100 | 12.2 | 15.4 | 32.7
Wheeze | 15.2 | Not reported | 28.8 | 42.6 | 63.6
Dyspnea | 21.5 | Not reported | 25.6 | | 65.4
Any symptom | 34.4 | 100 | 50.8 | 60.1 | | Percents age-adjusted to all study participants
No symptom | 65.6 | | 49.2 | 39.9 | 21

Summary Table 5. Characteristics of studies using spirometry as an aid in smoking cessation

Study | Study Duration (Months) | Intervention(s) | N | Control(s) | N | Description of Subjects; Inclusion Criteria
Independent effects of spirometry assessed
Segnan et al., 1991 ^79^ | 12 | Repeated counseling (RC): minimal intervention (see control group) plus followup counseling at 1, 3, 6, and 9 months. | 275 | Minimal intervention: one session of counseling. An explanatory brochure was provided. | 62 | Male and female patients (age range = 20–60 years) who were smokers and free of any life-threatening disease.
(Italy) | | RC plus nicotine gum: subjects advised on use of gum; gum provided at initial and first followup visits. | 294
| | RC plus spirometry: subjects given written prescription and asked to set up appointment for spirometry at another location. Results discussed at next followup visit. | 292
Effects of spirometry plus other interventions assessed
Risser et al., 1990 ^80^ | 12 | 50-minute education and skills training intervention (see controls) plus spirometry, exhaled CO and symptom questionnaire, and discussion of results. | 45 | 50-minute education and skills training intervention: discussion of risks/benefits, self-help manual reviewed, subjects encouraged to attend a 9-session counseling program and to select a quit date. | 45 | Male and female veterans who were outpatients, smokers, and who participated in a health promotion clinic, but were not selected for their initial motivation to quit.
(U.S.)
Sippel et al., 1999 ^81^ | 9 | Smoking cessation advice plus spirometry, exhaled CO, and uniform discussion of test results. | 102 | Smoking cessation advice: completion of baseline questionnaire/assessment of motivational stage. Subjects encouraged to quit smoking and received cessation plan based on motivational stage (3 or 10 min.). All participants given self-help pamphlet and list of community programs. Some received telephone followup calls at 1 and 4 weeks after their quit date and/or assistance in obtaining NRT. | 103 | Male and female outpatients who were smokers, English-speaking, over the age of 18 (age range = 19–75), and were not being seen for an emergency.
(U.S.)
Richmond et al., 1985 ^82^ | 6 | Six visits to primary care provider, including blood tests and spirometry at baseline and 6 months, discussion of baseline test results and counseling and smoking cessation support. Manual provided. | 100 | Two visits (baseline and 6 month followup) to primary care provider for counseling and smoking cessation support (blood tests and spirometry performed, but patients not provided with results). | 100 | Male and female patients (age range = 16–65 years) who were smokers, proficient in English, and who did not intend to leave Sydney within 6 months.
(Australia)
Rose et al., 1978 ^84^ | 36 | Baseline screening including spirometry. Smoking cessation counseling and three followup visits. Two booklets provided. Smoking report cards completed by subjects. | 714 | Baseline screening including spirometry. Usual care (test results provided to primary care provider). | 731 | Men (age range = 40–59) who were smokers, participated in a cardiorespiratory screening of civil servants in London, and who were considered to have high cardiorespiratory risk.
(England)
Humerfelt et al., 1998 ^83^ | 12 | Baseline data collected at a community survey (included height, weight, spirometric values, and a questionnaire). Participants received a letter providing baseline test results, advice to quit, and a pamphlet emphasizing behavior modification. | 1300 | Baseline data collected at a community survey (included height, weight, spirometric values, and a questionnaire). No information/advice provided. | 1310 | Men (age range = 30–45) who were smokers, lived in 34 rural municipalities in western Norway, and participated in a cross-sectional community survey.
(Norway)
Li et al., 1984 ^85^ | 11 | Behavioral counseling: all components of minimal advice (see control group) plus 3–5 minutes of counseling to explain test results and to secure commitment to quit plan. Participants asked to set a quit date. | 215 | Minimal advice: testing (pulmonary function testing, chest x-ray, and a smoking assessment questionnaire). Participants received test results, warning to quit smoking, and pamphlet outlining quit plan. | 361 | Male smokers who were exposed to asbestos and were identified during an initial screening of naval shipyard workers.
(US)

Summary Table 6. Strengths and limitations of studies using spirometry as an aid in smoking cessation

Study (Reference) | Independent Assessment of Effects of Spirometry | Quality of Randomization | Length of Followup (Months) | Biochemical Validation of Smoking Cessation | Selection of Participants | Study Notes/Limitations
Independent effects of spirometry assessed
Segnan et al., 1991 ^79^ | Yes | Adequate | 12 | Yes | All smoking patients of volunteering physicians | Poor compliance by physicians administering interventions and poor compliance by participants in completing the followup visits and spirometry (<40% attendance for return visits, 50.2% subject compliance for spirometry in RC+spirometry group).
Effects of spirometry plus other interventions assessed
Risser et al., 1990 ^80^ | No | Unclear | 12 | Yes (63%) | Volunteers of a health promotion clinic | Small study size with large, uneven attrition (at t=12 mos., 13/45 lost in intervention group vs. 6/45 in control group). Results may not be very generalizable because subjects had an average of five active medical conditions, 1/4 were enrolled in psychiatric programs and 21% consumed 4+ drinks daily.
Sippel et al., 1999 ^81^ | No | Inadequate | 9 | No | All outpatient smokers of two family practice clinics | Some subjects used NRT; no NRT use data by intervention group provided.
Richmond et al., 1985 ^82^ | No | Inadequate | 36 | Yes | All outpatient smokers of a family practice clinic
Rose et al., 1978 ^84^ | No | Unclear | 36 | No | Participants in another screening study (employees) | Unclear whether the intervention group was told their spirometric results; patients may have been given spirometric results only if they asked for more details. The control group was not told their baseline spirometric results by researchers, but these data were given to the primary care practitioners. Participants selected for study based on high cardiorespiratory risk.
Humerfelt et al., 1998 ^83^ | No | Unclear | 12 | Yes (subset) | All smokers attending community health survey (73% of population in attendance) had equal chance of being selected | Smokers included in study were at high risk for obstructive lung disease (previous occupational asbestos exposure, and/or adjusted FEV_1_ in the lowest quartile). Control group did not receive any advice to stop smoking.
Li et al., 1984 ^85^ | No | Unclear | 11 | Yes | All naval shipyard employees who were smokers | Both control and intervention subjects received the results of their PFTs and CO tests (it is unclear how much information was given to the control group). Therefore, the effect of spirometry cannot be assessed. Researchers disregarded the randomization performed initially such that study groups were reconstructed in the analysis phase due to poor compliance by the physicians administering the interventions. Three subjects were omitted from the reconstructed groups because it was unclear what treatment was received. Subjects may have additional motivation to quit because they were exposed to asbestos.

Summary Table 7. Outcomes data for studies using spirometry as an aid in smoking cessation

Study | Group | Self-Reported Abstinence Rate | | Biologically Verified Quit Rate | | Continuously Abstinent Over Course of Study | | One or More Quit Attempts | Notes
| | 6-Month | 12-Month | Quit Rate | Time | Quit Rate | Time
Independent effects of spirometry assessed
Segnan et al., 1991 ^79^ | Control (Minimal Intervention) | | | 4.8% | 12 months | | | | Subjects with cotinine/creatinine ratios >100 ng/mg classified as smokers. Unverified self-reported quitters counted as smokers. Three months of abstinence required to be considered an abstainer. Prevalence of self-reported abstinence (no data provided) was twice that of biologically verified abstinence. If followup data not available, subjects assumed to be smokers.
| Repeated Counseling (RC) | | | 5.5% | 12 months
| RC plus NRT | | | 7.5% | 12 months
| RC plus spirometry | | | 6.5% | 12 months
Effects of spirometry plus other interventions assessed
Risser et al., 1990 ^80^ | Control (50-min. educational intervention) | | 11.1% | 6.7% | 12 months | | | 15.6% | Biochemical validation of smoking status occurred in 63% of subjects. Subjects with CO levels >10 ppm were classified as smokers. If followup data not available, subjects assumed to be smokers.
| 50-min intervention + spirometry + CO + symptom discussion | | 24.4% | 20.0% | 12 months | | | 35.6%
Sippel et al., 1999 ^81^ | Control (Advice) | 14%* | | | | | | 36% | *Self-reported abstinence at 9 months followup. Subjects with CO levels >5 ppm were classified as smokers. If followup data not available, subjects assumed to be smokers. Mean length of followup was 260 ± 45 days.
| Advice + spirometry + CO | 9%* | | | | | | 48%
Richmond et al., 1985 ^82^ | Control (2 visits) | 3.0% | | 8.0% | 36 months | 2.0% | 36 months | | Subjects with cotinine levels ≥50 nmol/L or carboxyhemoglobin concentration ≥2.0% classified as smokers. Smoking status verified by friends/relatives in three cases. If followup data not available, subjects assumed to be smokers.
| 6 visits + spirometry + blood tests | 35.0% | | 35.7% | 36 months | 23.5% | 36 months
Rose et al., 1978 ^84^ | Control (Usual care) | | 8.9% ^‡^ | | | | | | ^‡^ Self-reported abstinence rates at 36 months of followup were 14.5% in the control group and 35.5% in the intervention group. Denominators are number responding to questionnaire.
| 4 visits + spirometry + booklets + report cards | | 39.3% ^‡^
Humerfelt et al., 1998 ^83^ | Control (No intervention) | | 9.1% | | | 3.2% | 12 months | | Validation study performed in 114 subjects (non-representative sample) via CO measurement. Subjects with CO levels >10 ppm were classified as smokers. Intention-to-treat data presented.
| Letter + pamphlet + spirometry + questionnaire | | 11.4% | | | 4.7% | 12 months
Li et al., 1984 ^85^ | Control (Minimal advice + PFT + chest x-ray + questionnaire) | | | 2.8% | 11 months | 3.6% | 11 months | | Subjects with CO levels ≥9 ppm were classified as smokers. Outcomes data from reconstructed groups based on compliance of physicians providing interventions, not groups created in original randomization.
| Behavioral counseling + PFT + chest x-ray + questionnaire | | | 6.5% | 11 months | 8.4% | 11 months

Summary Table 8. Outcomes of studies of tiotropium for COPD using spirometry

Study | Intervention | Exacerbations: Total Subjects With >1 Episode n / N (%) | Exacerbations - Other/ Hospitalizations Due to COPD / or Other | Mortality: n / N (%) | St George's Respiratory Questionnaire
Brusasco et al., 2003 ^89^ | | | Use of oral steroid bursts in management of COPD | | Change per group
| 1) Tiotropium 18 ug q.d. (n=402) | 129 / 402 (32) | 45 / 402 (11.2) | 1 / 402 (<1) | 4.2 (0.7)
| 2) placebo (n=400) | 156 / 400 (39) | 58 / 400 (14.5) | 5 / 400 (1.3) | 1.5 (0.7)
Casaburi et al., 2002 ^104^ | | | Patients hospitalized for exacerbation | | Change per group
| 1) Tiotropium 18 ug q.d. (n=550) | 198 / 550 (36) | 30 / 550 (5.5) | 7 / 550 (1.3) | -3.2 (p<0.05)
| 2) placebo (n=371) | 156 / 371 (42) | 35 / 371 (9.4) | 7 / 371 (1.9) | 0.58
Donohue et al., 2002 ^95^ | | | | | Change per group
| 1) Tiotropium 18 ug q.d. (n=209) | 77 / 209 (36.8) | Not reported | 0 / 209 | -5.14 (p<0.05 vs. pbo)
| 2) placebo (n=201) | 92 / 201 (45.8) | Not reported | 4 / 201 (2) | -2.43
Vincken et al., 2002 ^105^ | | | Patients hospitalized for exacerbation | | Treatment difference vs. Ipratropium
| 1) Tiotropium 18 ug q.d. (n=356); | 125 / 356 (35.1) | 26 / 356 (7.3) | 9 / 356 (2.5) | -3.3 (1.13) (p=0.004)
| 2) Ipratropium bromide 40 ug q.i.d. (n=179) | 82 / 179 (45.8) | 21 / 179 (11.7) | 3 / 179 (1.7)
van Noord et al., 2000 ^106^ | 1) Tiotropium 18 ug q.d. (n=191); | 21 / 191 (11) | Not reported | Not reported | Not reported
| 2) Ipratropium 40 ug q.i.d. (n=97) | 12 / 97 (12.4) | Not reported | Not reported | Not reported

Summary Table 9. Summary of outcomes for interventions for COPD using spirometry - tiotropium

Studies | N | Duration | Tiotropium Events, % | Control Events, % | ARR % [95%CI] | Relative Risk [95%CI] | Baseline Spirometry Range (FEV_1_; %) Predicted
[underlined: Exacerbation vs. Placebo]
Brusasco, 2003 ^89^ | 802 | 6 month | 32.1 | 39 | -7 [-14 to 0] | 0.82 [0.68 to 0.99] | 1.1; 39%
Casaburi, 2002 ^104^ | 921 | 1 year | 36 | 42 | -6 [-12 to 0] | 0.86 [0.73 to 1.01] | 1.0; 39%
OVERALL | 1723 | 6 months – 1 year | 34.3 | 40.6 | -6 [-11 to -2] | 0.83 [0.75 to 0.93] | 1.0 to 1.1; 39%
[underlined: Exacerbation vs. Ipratropium]
Vincken, 2002 ^ 105 ^ | 535 | 1 year | 35.1 | 45.8 | -11 [-20 to -2] | 0.77 [0.62 to 0.95] | 1.2; 41%
[underlined: Exacerbation vs. Long-Acting β2 Agonists (Salmeterol)]
Brusasco, 2003 ^ 89 ^ | 807 | 6 months | 32.1 | 35.1 | -3 [-9 to 4] | 0.92 (0.75 to 1.11) | 1.1; 39%
[underlined: Mortality vs. Placebo;]
Brusasco, 2003 ^89^ | 802 | 6 month | 0.25 | 1.3 | -1 [-2 to 0] | 0.20 [0.02 to 1.70] | 1.1; 39%
Casaburi, 2002 ^104^ | 921 | 1 year | 1.3 | 1.9 | -1 [-2 to 1] | 0.67 [0.24 to 1.91] | 1.0; 39%
OVERALL | 1723 | 6 months – 1 year | 0.69 | 1.6 | -1 [-2 to 0] | 0.40 [0.17 to 0.93] | 1.0 to 1.1; 39%
[underlined: Mortality vs. Ipratropium]
Vincken, 2002 ^ 105 ^ | 535 | 1 year | 2.5 | 1.7 | 1 [-2 to 3] | 1.51 [0.41 to 5.50] | 1.2; 41%
[underlined: Mortality vs. Long-Acting β Agonists (Salmeterol)]
Brusasco, 2003 ^ 89 ^ | 807 | 6 months | 0.0025 | 1.5 | -1 [-3 to 0] | 0.17 [0.02 to 1.39] | 1.1; 39%
Studies | N | Duration | Tiotropium: Mean Change | Control: Change | | Weighted Mean Difference (95%CI) | Baseline Spirometry Range (FEV_1_; %) Predicted
[underlined: St George's Respiratory Questionnaire - Mean units of change: vs. Placebo]
Brusasco, 2003 ^89^ | 802 | 6 months | -4.2 | -1.5 | Not Applicable | -2.70 [-4.64 to -0.76] | 1.1; 39%
Casaburi, 2002 ^104^ | 921 | 1 year | -3.2 | 0.58 | Not Applicable | -3.7 [-7.2 to -0.2] | 1.0; 39%
OVERALL | Studies not pooled, WMDs from Casaburi and Brusasco reported in study without additional data to allow pooling
[underlined: St George's Respiratory Questionnaire - Mean units of change: vs. Ipratropium]
Vincken, 2002 ^105^ | 535 | 1 year | No Response | No Response | Not Applicable | -3.3 [-6.5 to -0.2] | 1.2; 41%
OVERALL | Studies not pooled, Casaburi, Brusasco and Vincken reported in study without additional data to allow pooling

Summary Table 10. Outcomes of studies of ipratropium for COPD using spirometry

Study | Intervention | Exacerbations: Total Subjects with >1 episode n / N (%) | Exacerbations -Other/ Hospitalizations Due to COPD / or Other | Mortality: n / N (%) | St George's Respiratory Questionnaire
Vincken et al., 2002 ^105^ | | | Patients hospitalized for exacerbation; n/N % | | Treatment difference vs. Ipratropium
| 1) Ipratropium bromide 40 ug q.i.d. (n=179) | 82 / 179 (45.8) | 21 / 179 (11.7) | 3 / 179 (1.7)
| 2) Tiotropium 18 ug q.d. (n=356) | 125 / 356 (35.1) | 26 / 356 (7.3) | 9 / 356 (2.5) | -3.3 (1.13) (p=0.004)
Wadbo et al., 2002 ^98^ | | “Adverse Events related to COPD” | “Deterioration of COPD leading to withdrawal”; n/N % | | Change per group
| 1) Ipratropium bromide 80 ug, t.i.d. (n=62) | 22 / 62 (35.5) | 3 / 62 (4.8) | Not reported | -0.5% (95%CI -2.8 to 1.7)
| 2) placebo (n=60) | 23 / 60 (38.3) | 6 / 60 (10.0) | Not reported | 1.5% (95%CI -0.8 to 3.7)
Dahl et al., 2001 ^99^ | | “COPD Adverse Events” - includes exacerbations | COPD hospitalizations; n/N % | | Treatment difference vs. pbo
| 1) Ipratropium bromide 40 ug, t.i.d. (n=194) | 37 / 194 (19.1) | 6 / 194 (3.1) | 0 / 194 | 1.33 (est.) (p=0.314)
| 2) placebo (n=200) | 37 / 200 (18.5) | 4 / 200 (2) | 0 / 200
Rennard et al., 2001 ^100^ | | | First exacerbation during week 1; n/N % | | Chronic Respiratory Disease Questionnaire; Change per group
| 1) Ipratropium 36 ug, t.i.d. (n=138) | 37 / 138 (26.8) | 6 / 138 (4.3) | 0 / 138 | 9.2
| 2) placebo (n=135) | 41 / 135 (30.4) | 20 / 135 (14.8) | 1 / 135 | 6.8
van Noord et al., 2000 ^106^ | 1) Ipratropium 40 ug q.i.d. (n=97) | 12 / 97 (12.4) | Not reported | Not reported | Not reported
| 2) Tiotropium 18 ug q.d. (n=191) | 21 / 191 (11) | Not reported | Not reported | Not reported
Mahler et al, 1999 ^102^ | | | First exacerbation during week 1; n/N % | | Chronic Respiratory Disease Questionnaire; Change per group
| 1) Ipratropium 36 ug, q.i.d. (n=133) | 41 / 133 (30.8) | 7 / 133 (5.3) | 0 / 133 | 6.8 (1.2) (p=0.007 vs. pbo)
| 2) placebo (n=143) | 47 / 143 (32.9) | 21 / 143 (14.7) | 0 / 143 | 2.1 (1.3)
COMBIVENT Inhalation Study Group, 1997 ^109^ | | ≥1 adverse event - “worsening of the lower respiratory tract symptoms was the most frequently reported event” | Discontinuations due to deterioration of COPD; n/N %
| 1) Ipratropium 50 ug, t.i.d. (n=214) | 112 / 214 (52.3) | 8 / 214 (3.7) | 1 / 214 (<1) | Not reported
| 2) Ipratropium 50 ug plus Albuterol 3mg t.i.d. (n=222) | 126 / 222 (56.8) | 9 / 222 (4.1) | 3 / 222 (1.4) | Not reported
| 3) Albuterol 3 mg t.i.d. (n=216) | 124 / 216 (57.4) | 8 / 216 (3.7) | 4 / 216 (1.9) | Not reported
COMBIVENT Inhalation Study Group, 1994 ^108^ | | “Subjects reporting adverse events or worsening of a pre-existing condition” (excluding AEs that were possibly drug-related
| 1) Ipratropium 21 ug, q.i.d. (n=179) | 77 / 179 (43.0) | Not reported | 0 / 179 | Not reported
| 2) Ipratropium 21 ug plus Albuterol 100ug q.i.d. (n=182) | 76/182 (41.8) | Not reported | 2 / 182 (1.1) | Not reported
| 3) Albuterol 120 ug q.i.d. (n=173) | 82 1 73 (47.4) | Not reported | 0 / 173 | Not reported

Summary Table 11. Summary of outcomes for interventions for COPD using spirometry - ipratropium

Studies | N | Duration | Ipratropium Events, % | Placebo Events, % | ARR % [95% CI ] | Relative Risk [95% CI] | Mean Baseline Spirometry (FEV_1_; %) Predicted
[underlined: Exacerbations: vs. Placebo]
Wadbo, 2002 ^98^ | 122 | 3 months | 35.5 | 38.3 | -3 [-20 to 14] | 0.93 [0.58 to 1.47] | 33%
Dahl, 2001 ^99^ | 394 | 3 months | 19.1 | 18.5 | 1 [-7 to 8] | 1.03 [0.68 to 1.55] | 1.3; 45%
Rennard, 2001 ^100^ | 273 | 3 months | 26.8 | 30.4 | -4 [-14 to 7] | 0.88 [0.61 to 1.29] | 1.3
Mahler, 1999 ^102^ | 280 | 3 months | 30.8 | 32 | -1 [-12 to 10] | 0.96 [0.68 to 1.36] | 39%
OVERALL | 1069 | 3 months | 26 | 27.3 | -1 [-7 to 4] | 0.95 [0.78 to 1.16] | 1.3; 33–45%
[underlined: Exacerbations: vs. Tiotropium]
Vincken, 2002 ^105^ | 535 | 1 year | 45.8 | 35.1 | -11 [-20 to -2] | 1.30 [1.05 to 1.61] | 1.2; 41%
[underlined: Mortality: vs. Placebo]
Dahl, 2001 ^99^ | 394 | 3 months | 0 | 0 | 0 [-1 to 1] | Not estimable | 1.3; 45%
Rennard, 2001 ^100^ | 273 | 3 months | 0 | 0.74 | -1 [-3 to 1] | 0.33 [ 0.01 to 7.94] | 1.3
Mahler, 1999 ^102^ | 280 | 3 months | 0 | 0 | 0 [-1 to 1] | Not estimable | 39%
LH-1 ^114^ | 3923 | 5 year | 2.8 | 2.2 | 1 [0 to 1] | 1.23 [0.83 to 1.82] | 2.6; 75%
OVERALL | 4870 | 3 months - 5 year | 2.2 | 1.8 | 0 [0 to 1] | 1.20 [0.81 to 1.77] | 1.3 to 2.6; 39–75%
[underlined: Mortality: vs. Tiotropium]
Vincken, 2002 ^ 105 ^ | 535 | 1 year | 1.7 | 2.5 | -1 [-3 to 2] | 0.66 [0.18 to 2.42] | 1.2; 41%
Studies | N | Duration | Ipratropium: Mean Change | Control: Change | ARR | Weighted Mean Difference (95%CI) | Baseline Spirometry Range (FEV_1_; %) Predicted
[underlined: St George's Respiratory Questionnaire - Mean units of change: vs. Placebo]
Dahl, 2001 ^99^ | 394 | 3 months | Not reported | Not reported | Not Applicable | -1.2 [-3.8 to 1.4] | 1.3; 45%
Wadbo et al., 2002 ^98^ | 122 | 3 months | -0.5 | 1.5 | Not Applicable | -1 | 33 to 34%
[underlined: St George's Respiratory Questionnaire - Mean units of change: vs. Tiotropium]
Vincken, 2002 ^105^ | 535 | 1 year | Not reported | Not reported | Not Applicable | 3.3 [1.09 to 5.51] | 1.2; 41%
Studies not pooled, studies did not report data to allow pooling

Summary Table 12. Outcomes of studies of inhaled corticosteroids for COPD using spirometry

Study | Intervention | Exacerbations: Total Subjects with >1 Episode n / N (%) | Exacerbations - Other/ Hospitalizations Due to COPD / or Other | Mortality: n / N (%) | St George's Respiratory Questionnaire
van der Valk et al., 2002 ^86^ | | | Rapid recurrent; n/N % | | Treatment difference vs. pbo
| 1) Fluticasone 500 ug, b.i.d. (n=123) | 58 / 123 (47.2) | 6 / 123 (4.9) | 1 / 123 | 2.48 (95% CI 0.37 to 4.58)
| 2) placebo (n=121) | 69 / 121 (57.0) | 26 / 121 (21.5) | 1 / 121
Burge et al., 2000 ^111^ | | | Median annual rates | | Change per group
| 1) Fluticasone 500 ug, b.i.d. (n=376) | Not reported | 0.99 (range 0 to 26) | 32 / 376 (8.5) | 2.00 (0.29)
| 2) placebo (n=375) | Not reported | 1.32 (0 to 30) | 36 / 375 (9.6) | 3.17 (0.31)
| | | Treatment difference | | Treatment difference vs. pbo
| | | -0.3 (-0.4 to 0.0) | | -1.17 (-1.95 to -0.39); p=0.004
LHS Research Group, 2000 ^114^ | | | Respiratory Symptoms during course of study
| 1) Triamcinolone 600 ug, b.i.d. (n=559) | Not reported | 21.1 per 100 person yrs | 15 / 559 (2.9) | Not reported
| 2) placebo (n=557) | Not reported | 28.2 per 100 person yrs | 19 / 557 (3.4) | Not reported
Pauwels et al., 1999 ^115^ | 1) Budesonide 400 ug, b.i.d. (n=634) | Not reported | Not reported | 8 / 634 (1.3) | Not reported
| 2) placebo (n=643) | Not reported | Not reported | 10 / 643 (1.6) | Not reported
Vestbo et al., 1999 ^112^ | | | Discontinuations due to deterioration of COPD; n / N %
| 1) Budesonide (800 ug, 400 ug; b.i.d.) for 6 months and (400 ug, b.i.d.) for 30 months, (n=145) | 155 total | 3 / 145 (2.1) | 4 / 145 (2.8) | Not reported
| 2) placebo (n=145) | 161 total | 7 / 145 (4.8) | 5 / 145 (3.4) | Not reported
Weir et al., 1999 ^117^ | | | Mean exacerbation rate/year
| 1) Beclomethasone dipropionate (750 ug for less than 50 kg) and (1000 ug for greater than 50 kg), b.i.d., (n=49) | Not reported | 0.36 (0.09 SE) | Not reported | Not reported
| 2) placebo (n=49) | Not Reported | 0.57 (0.13 SE) | Not reported | Not reported
Bourbeau et al., 1998 ^116^ | | “Adverse events, respiratory in origin” | Discontinuations due to deterioration of COPD; n/N %
| 1) Budesonide 800 ug, b.i.d, (n=39) | 10 / 39 (25.6) | 0 / 39 | Not reported | Not reported
| 2) placebo (n=40) | 15 / 40 (37.5) | 1 / 40 (2.5) | Not reported | Not reported
Paggiaro et al., 1998 ^113^ | | | Number of exacerbations
| 1) Fluticasone 500 ug, b.i.d. (n=142) | 45 / 142 (31.7) | 76 | Not reported | Not reported
| | mild 17 / 45 (38)
| | moderate/severe 27 / 45 (60)
| 2) placebo (n=139) | 51 / 139 (36.7) | 111 | Not reported | Not reported
| | mild 7 / 51 (14)
| | moderate/severe 44 / 51 (86)

Summary Table 13. Summary of outcomes for interventions for COPD using spirometry - corticosteroids

Studies | N | Duration | Steroid Events, % | Placebo Events, % | ARR % [95% CI] | Relative Risk [95% CI] | Baseline Spirometry Range (FEV_1_; %) Predicted
[underlined: Exacerbations: Fluticasone]
Burge, 2000 ^111^ | 751 | 3 years | 10.5 | 14.3 | -4 [-9 to 1] | 0.73 [0.50 to 1.08] | Post 1.4; 50%
Calverley, 2003 ^87^ | 735 | 1 year | 2.5 | 5.3 | -3 [-5 to 0] | 0.51 [0.24 to 1.08] | 1.3; 45%
Mahler, 2002 ^96^ | 349 | 6 months | 10.1 | 8.8 | 1 [-5 to 7] | 1.14 [0.60 to 2.19] | 1.3; 41%
van der Valk, 2002 ^86^ | 244 | 6 months | 47.2 | 57 | -10 [-22 to 3] | 0.83 [0.65 to 1.05] | Post 1.7; 57%
Paggiaro, 1998 ^113^ | 281 | 6 months | 31.7 | 36.7 | -5 [-16 to 6] | 0.86 [0.62 to 1.20] | 1.6; 57%
Overall | 2360 | 6 months to 3 years | 14.3 | 17.7 | -3 [-6 to -1] | 0.81 [0.68 to 0.95] | 1.3 to 1.7; 45 to 57%
[underlined: Exacerbations: Budesonide]
Calverley, 2003 ^88^ | 513 | 1 year | 24.1 | 30.9 | -7 [-14 to 1] | 0.78 [0.59 to 1.04] | 1.0; 36%
Bourbeau, 1998 ^116^ | 79 | 6 months | 5.1 | 10 | -5 [-16 to 7] | 0.51 [0.10 to 2.64] | 0.9; 37%
Vestbo, 1999 ^112^ | 290 | 3 years | 51.7 | 53.8 | -2 [-14 to 9] | 0.96 [0.77 to 1.20] | Post 2.4; 87%
Szafranski, 2003 ^92^ | 406 | 1 year | 13.1 | 25.9 | -13 [-20 to -5] | 0.51 [0.33 to 0.78] | 1.0; 36%
Overall | 1288 | 6 months to 3 years | 25.6 | 33.1 | -7 [-12 to -3] | 0.78 [0.66 to 0.91] | 0.9; 37%
[underlined: Exacerbations: Beclomethasone]
Weir et al., 1999 ^117^ | 98 | 2 year | 36.7 | 57.1 | -20 [-40 to -1] | 0.64 [0.41 to 1.00] | 1.1; 41%
OVERALL | 3746 | 6 months to 3 years | 18.9 | 24.1 | -5 [-8 to -3] | 0.78 [0.70 to 0.88] | 0.9 to 2.4; 37 to 87%
[underlined: Mortality: Fluticasone]
Burge, 2000 ^111^ | 751 | 3 years | 8.5 | 9.6 | -1 [-5 to 3] | 0.89 [0.56 to 1.40] | Post 1.4; 50%
van der Valk, 2002 ^86^ | 244 | 6 months | 0.81 | 0.83 | 0 [-2 to 2] | 0.98 [0.06 to 15.55] | Post 1.7; 57%
Hanania, 2003 ^91^ | 368 | 6 months | 0 | 0 | 0 [-1 to 1] | Not estimable | 1.3; 42%
Mahler, 2002 ^96^ | 349 | 6 months | 0 | 1.7 | -2 [-4 to 0] | 0.15 [0.01 to 2.96] | 1.3; 41%
Overall | 1712 | 6 months to 3 years | 3.9 | 4.6 | -0.7 | 0.83 [0.53 to 1.28] | 1.3 to 1.7; 41 to 57%
[underlined: Mortality: Budesonide]
Calverley, 2003 ^88^ | 513 | 1 year | 2.3 | 2.0 | 0 [-2 to 3] | 1.20 [0.37 to 3.87] | 1.0; 36%
Pauwels, 1999 ^115^ | 1277 | 3 years | 1.3 | 1.6 | -0 [-2 to 1] | 0.81 [0.32 to 2.04] | 2.5; 77%
Vestbo, 1999 ^112^ | 290 | 3 years | 2.8 | 3.4 | -1 [-5 to 3] | 0.80 [0.22 to 2.92] | Post 2.4; 87%
Szafranski, 2003 ^92^ | 406 | 1 year | 2.5 | 4.4 | -2 [-5 to 2] | 0.58 [0.20 to 1.69] | 1.0; 36%
Overall | 2486 | 1 to 3 years | 1.5 | 1.9 | 0 [-2 to 1] | 0.72 [0.39 to 1.33] | 2.4 to 2.5; 77 to 87%
[underlined: Mortality: Triamcinolone]
LHS-2 ^114^ | 1116 | 4.5 years | 2.7 | 3.4 | -1 [-3 to 1] | 0.79 [0.40 to 1.53] | 2.1; 64%
OVERALL | 5314 | 6 months to 4.5 years | 2.7 | 3.3 | -1 [-2 to 0] | 0.81 [0.60 to 1.10] | 1.3 to 2.5; 41 to 87%
Studies | N | Duration | Long-Acting β2 Agonists: Mean Change | Placebo: Change | ARR | Weighted Mean Difference [95%CI] | Baseline Spirometry Range (FEV_1_; %) Predicted
[underlined: St George's Respiratory Questionnaire - Mean units of change:]
Calverley, 2003 ^88^ | 513 | 1 year | Not reported | Not reported | Not applicable | -3 | 1.0; 36%
Burge, 2000 ^111^ | 751 | 3 years | Not reported | Not reported | Not applicable | -1.17 [-1.95 to -0.39] | Post 1.4; 50%
van der Valk, 2002 ^86^ | 244 | 6 months | Not reported | Not reported | Not applicable | -2.48 [-4.58 to -0.37] | Post 1.7; 57%
Studies not pooled, studies did not report data to allow pooling

Summary Table 14. Summary of outcomes for interventions for COPD using spirometry - Combination of long-acting β2 agonists plus corticosteroids

Studies | N | Duration | Combo events, % | Control events, % | ARR % [95% CI] | Relative Risk [95%CI] | Baseline Spirometry range (FEV_1_; %) predicted
Exacerbations: Salmeterol+Fluticasone vs. Placebo
Calverley, 2003 ^87^ | 719 | 1 year | 2.5 | 5.3 | -3 [-6 to 0] | 0.48 [0.22 to 1.04] | 1.3; 45%
Mahler, 2002 ^96^ | 349 | 6 months | 8.5 | 8.8 | 0 [-6 to 6] | 0.96 [0.48 to 1.91] | 1.3; 41%
Overall | 1065 | 6 months to 1 year | 4.4 | 6.5 | -2 [-5 to 1] | 0.69 [0.42 to 1.15] | 1.3; 41–45%
Exacerbations: Formeterol+Budesonide vs. Placebo
Szafranski, 2003 ^92^ | 413 | 1 year | 16.8 | 25.9 | -9 [-17 to -1] | 0.65 [0.44 to 0.95] | 1.0; 36%
Calverley 2003 ^88^ | 510 | 1 year | 18.9 | 30.9 | -12 [-19 to -5] | 0.61 [0.45 to 0.84] | 1.0; 36%
Overall | 923 | 1 year | 18 | 28.6 | -11 [-16 to -5] | 0.63 [0.49 to 0.80] | 1.0; 36%
OVERALL | 1988 | 6 months to 1 year | 10.8 | 16.7 | -6 [-9 to -3] | 0.64 [0.52 to 0.80] | 1.0–1.3; 36–45%
Exacerbations: Salmeterol+Fluticasone vs.Salmeterol
Calverley, 2003 ^87^ | 730 | 1 year | 2.5 | 2.2 | 0 [-2 to 3] | 1.17 [0.46 to 3.00] | 1.3; 45%
Mahler, 2002 ^96^ | 325 | 6 months | 8.5 | 5.6 | 3 [-3 to 8] | 1.51 [0.67 to 3.39] | 1.3; 41%
Overall | 1055 | 6 months to 1 year | 4.4 | 3.2 | 1 [-1 to 3] | 1.35 [0.73 to 2.49] | 1.3; 41–45%
Exacerbations: Formeterol+Budesonide vs. Formeterol
Szafranski, 2003 ^92^ | 409 | 1 year | 16.8 | 18.9 | -2 [-10 to 5] | 0.89 [0.59 to 1.35] | 1.0; 36%
Calverley 2003, ^88^ | 509 | 1 year | 18.9 | 28.6 | -10 [-17 to -2] | 0.66 [0.48 to 0.91] | 1.0; 36%
Overall | 918 | 1 year | 18 | 24.3 | -6 [-12 to -1] | 0.74 [0.57 to 0.95] | 1.0; 36%
OVERALL | 1973 | 6 months to 1 year | 10.8 | 13 | -2 [-5 to 0] | 0.82 [0.65 to 1.04] | 1.0–1.3; 36–45%
Exacerbations: Salmeterol+Fluticasone vs.Fluticasone
Calverley, 2003 ^87^ | 732 | 1 year | 2.5 | 2.7 | 0 [-2 to 2] | 0.94 [0.39 to 2.29] | 1.3; 45%
Mahler, 2002 ^96^ | 333 | 6 months | 8.5 | 10.1 | -2 [-8 to 5] | 0.84 [0.43 to 1.65] | 1.3; 41%
Overall | 1065 | 6 months to 1 year | 4.4 | 5 | -1 [-3 to 2] | 0.88 [0.51 to 1.50] | 1.3; 41–45%
Exacerbations: Formeterol+Budesonide vs. Budesonide
Szafranski, 2003 ^92^ | 406 | 1 year | 16.8 | 13.1 | 4 [-3 to 11] | 1.28 [0.80 to 2.05] | 1.0; 36%
Calverley 2003, ^88^ | 511 | 1 year | 18.9 | 24.1 | -5 [-12 to 2] | 0.78 [0.56 to 1.09] | 1.0; 36%
Overall | 917
OVERALL | 1982 | 6 months to 1 year | 10.8 | 11.5 | -1 [-4 to 2] | 0.92 [0.72 to 1.17] | 1.0–1.3; 36–45%
Mortality: Salmeterol+Fluticasone vs. Placebo
Hanania, 2003 ^91^ | 363 | 6 months | 0 | 0 | 0 [-1 to 1] | Not estimable | 1.3; 42%
Mahler, 2002 ^96^ | 346 | 6 months | 0 | 1.7 | -2 [-4 to 1] | 0.16 [0.01 to 3.01] | 1.3; 41%
Overall | 709 | 6 months | 0 | <1 | -1 [-2 to 0] | 0.16 [0.01 to 3.01] | 1.3; 42%
Mortality: Formeterol+Budesonide vs. Placebo
Szafranski, 2003 ^92^ | 413 | 1 year | 2.9 | 4.4 | -2 [-5 to 2] | 0.66 [0.24 to 1.81] | 1.0; 36%
Calverley 2003, ^88^ | 510 | 1 year | 2 | 2 | 0 [-2 to 2] | 1.01 [0.30 to 3.44] | 1.0; 36%
Overall | 923 | 1 year | 2.4 | 3.0 | -1 [-3 to 1] | 0.78 [0.36 to 1.70] | 1.0; 36%
OVERALL | 1632 | 6 months to 1 year | 1.4 | 2.1 | -1 [-2 to 1] | 0.66 [0.32 to 1.38] | 1.0–1.3; 36–42%
Mortality: Salmeterol+Fluticasone vs.Salmeterol
Hanania, 2003 ^91^ | 355 | 6 months | 0 | 0 | 0 [-1 to 1] | Not estimable | 1.3; 42%
Mahler, 2002 ^96^ | 325 | 6 months | 0 | 0 | 0 [-1 to 1] | Not estimable | 1.3; 41%
Overall | 680 | 6 months | Not applicable | Not applicable | 0 [-1 to 1] | Not estimable | 1.3; 41–42%
Mortality: Formeterol+Budesonide vs. Formeterol
Szafranski, 2003 ^92^ | 409 | 1 year | 2.9 | 3 | 0 [-3 to 3] | 0.97 [0.32 to 2.95] | 1.0; 36%
Calverley 2003, ^88^ | 509 | 1 year | 2 | 5.1 | -3 [-6 to 0] | 0.39 [0.14 to 1.07] | 1.0; 36%
Overall | 918 | 1 year | [underlined: 2.4] | [underlined: 4.2] | [underlined: 2 [-4 to 1]] | [underlined: 0.57 [0.27 to 1.19]] | 1.0; 36%
OVERALL | 1598 | 6 months to 1 year | 1.4 | 2.4 | -1 [-2 to 0] | 0.56 [0.26 to 1.19] | 1.0–1.3; 36–42%
Mortality: Salmeterol+Fluticasone vs.Fluticasone
Hanania, 2003 ^91^ | 361 | 6 months | 0 | 0 | 0 [-1 to 1] | Not estimable | 1.3; 42%
Mahler, 2002 ^96^ | 333 | 6 months | 0 | 0 | 0 [-1 to 1] | Not estimable | 1.3; 41%
Overall | 694 | 6 months | Not applicable | Not applicable | 0 [-1 to 1] | Not estimable | 1.3; 41–42%
Mortality: Formeterol+Budesonide vs. Budesonide
Szafranski, 2003 ^92^ | 406 | 1 year | 2.9 | 2.5 | 0 [-3 to 4] | 1.14 [0.35 to 3.68] | 1.0; 36%
Calverley 2003 ^88^ | 511 | 1 year | 2 | 2.3 | 0 [-3 to 2] | 0.84 [0.26 to 2.73] | 1.0; 36%
Overall | 917 | 1 year | 2.4 | 2.4 | 0 [-2 to 2] | 0.98 [0.43 to 2.24] | 1.0; 36%
OVERALL | 1611 | 6 months to 1 year | 1.4 | 1.4 | 0 [-1 to 1] | 0.98 [0.43 to 2.24] | 1.0–1.3; 36–42%
Studies | N | Duration | Combination: mean change | Control: change | | Weighted Mean Difference (95%CI) | Baseline Spirometry range (FEV1; %) predicted
St George's Respiratory Questionnaire - Mean units of change: Salmeterol+Fluticasone vs. Placebo
Calverley, 2003 ^87^ | 719 | 1 year | Not applicable | Not applicable | Not applicable | -2.2 [-3.3 to -1.1] | 1.3; 45%
Exacerbations: Formeterol+Budesonide vs. Placebo
Szafranski, 2003 ^92^ | 413 | 1 year | Not applicable | Not applicable | Not applicable | -3.9 [-6.8 to -1.0] | 1.0; 36%
Calverley 2003 ^88^ | 510 | 1 year | Not applicable | Not applicable | Not applicable | -7.5 | 1.0; 36%
OVERALL | from SIN | | | | | -2.4 [-3.4 to -1.4] | 1.0–1.3; 36–45%

Summary Table 15. Summary of outcomes for trials using combination of long-acting β2 agonists plus corticosteroids: Monotherapies and combination therapy in comparison to placebo

Outcome / study | Treatment n / N (%) | Placebo n / N (%) | Absolute Risk Reduction (%) [95% CI] | Relative Risk [95% CI] | Baseline FEV_1_; % predicted* | Exacerbation definition
Exacerbations
Calverley 2003 ^87^
Salmeterol | 8 / 372 (2.2) | 19 / 361 (5.3) | -3 [-6 to 0] | 0.41 [0.18, 0.92] | 1.3; 45 | Treatment-related COPD exacerbation
Fluticasone | 10 / 374 (2.7) | | -3 [-5 to 0] | 0.51 [0.24, 1.08]
Combination | 9 / 358 (2.5) | | -3 [-6 to 0] | 0.48 [0.22, 1.04]
Mahler 2002 ^96^
Salmeterol | 9 / 160 (5.6) | 16 / 181 (8.8) | -3 [-9 to 2] | 0.64 [0.29, 1.40] | 1.3; 41 | Exacerbation of COPD leading to study withdrawal
Fluticasone | 17 / 168 (10.1) | | 1 [-5 to 7] | 1.14 [0.60, 2.19]
Combination | 14 / 165 (8.5) | | 0 [-6 to 6] | 0.96 [0.48, 1.91]
Calverley 2003 ^88^
Formoterol | 73 / 255 (28.6) | 79 / 256 (30.9) | -2 [-10 to 6] | 0.93 [0.71, 1.21] | 1.0; 36 | Serious COPD adverse event leading to death, hospitalization, disability or withdrawal from study
Budesonide | 62 / 257 (24.1) | | -7 [-14 to 1] | 0.78 [0.59, 1.04]
Combination | 48 / 254 (18.9) | | -11 [-16 to -5] | 0.61 [0.45, 0.84]
Szafranski, 2003 ^92^
Formoterol | 38 / 201 (18.9) | 53 / 205 (25.9) | -7[-15 to 1] | 0.73 [0.51, 1.06] | 1.0; 36 | COPD event
Budesonide | 26 / 198 (13.1) | | -13 [-20 to -5] | 0.51 [0.33, 0.78]
Combination | 35 / 208 (16.8) | | -9 [-17 to -1] | 0.65 [0.44, 0.95]
Mortality
Hanania, 2003 ^91^
Salmeterol | 0 / 177 | 0 / 185 | 0 [-1 to 1] | | 1.3; 42
Fluticasone | 0 / 183 | | 0 [-1 to 1]
Combination | 0 / 178 | | 0 [-1 to 1]
Mahler 2002 ^96^
Salmeterol | 0 / 160 | 3 / 181 | -2 [-4 to 1] | 0.16 [0.01, 3.10] | 1.3; 41
Fluticasone | 0 / 168 | | -2 [-4 to 0] | 0.15 [0.01, 2.96]
Combination | 0 / 165 | | -2 [-4 to 1] | 0.16 [0.01, 3.01]
Calverley 2003 ^88^
Salmeterol | 13 / 255 (5.1) | 5 / 256 (2.0) | 3 [0 to 6] | 2.61 [0.94, 7.21] | 1.0; 36
Budesonide | 6 / 257 (2.3) | | 0 [-2 to 3] | 1.20 [0.37, 3.87]
Combination | 5 / 254 (2.0) | | 0 [-2 to 2] | 1.01 [0.30, 3.44]
Szafranski, 2003 ^92^
Salmeterol | 6 / 201 (3.0) | 9 / 205 (4.4) | -1 [-5 to 2] | 0.68 [0.25, 1.88] | 1.0; 36
Budesonide | 5 / 198 (2.5) | | -2 [-5 to 2] | 0.58 [0.20, 1.69]
Combination | 6 / 208 (2.9) | | -2 [-5 to 2] | 0.66 [0.24, 1.81]

* Pooled for all treatment arms