# Listing of Excluded Studies

### Q2—Smoking Cessation and Spirometry

Ames RG, Hall DS. Smoking cessation among coal miners as predicted by baseline respiratory function and symptoms: a 5-year prospective study. Preventive Medicine. 1985;14(2):181-6. Not randomized controlled trial. [pmid: 4048080].
Amin M. The role of alpha-1-antitrypsin in generating chronic obstructive pulmonary disorder. Respirology. 2001;6(Suppl):S39-43. Not smoking cessation and/or spirometry study. [pmid: 11438024].
Anonymous. Guidelines for the management of chronic obstructive pulmonary disease. Working Group of the South African Pulmonology Society. South African Medical Journal. 1998; 88(8):999–1002, 1004, 1006–10. Not smoking cessation and/or spirometry study.
Anonymous. No medication for COPD patients who do not stop smoking? “Fat diabetics are treated, too”. MMW Fortschritte der Medizin. 2003; 145(44):45. Not in English.
Anthonisen NR, Connett JE, Murray RP. Smoking and lung function of Lung Health Study participants after 11 years. American Journal of Respiratory & Critical Care Medicine. 2002;166(5):675-9. Not relevant. [pmid: 12204864].
Anto JM, Vermeire P, Vestbo J, Sunyer J. Epidemiology of chronic obstructive pulmonary disease. European Respiratory Journal. 2001;17(5):982-94. Review article. [pmid: 11488336].
Badgett B, Tanaka D. Smoking cessation in primary care clinics. Journal of General Internal Medicine. 2000;15(4):273. Letter. [pmid: 10841668].
Badgett RG, Tanaka DJ. Is screening for chronic obstructive pulmonary disease justified?. Preventive Medicine. 1997;26(4):466-72. Review article. [pmid: 9245668].
Bake B, Oxhoj H, Sixt R, Wilhelmsen L. Ventilatory lung function following two years of tobacco abstinence. Scandinavian Journal of Respiratory Diseases. 1977;58(6):311-8. Not randomized controlled trial. [pmid: 607396].
Barr RG, Herbstman J, Speizer FE, Camargo CA Jr. Validation of self-reported chronic obstructive pulmonary disease in a cohort study of nurses. American Journal of Epidemiology. 2002;155(10):965-71. Not smoking cessation and/or spirometry study. [pmid: 11994237].
Bateman ED, Feldman C, O'Brien J, Plit M, Joubert JR. COPD Guideline Working Group of the South African Thoracic Society. Guideline for the management of chronic obstructive pulmonary disease (COPD): 2004 revision. South African Medical Journal. 2004;94(7 Pt 2):559-75. Not smoking cessation. [pmid: 15283307].
Begin R, Filion R, Ostiguy G. Emphysema in silica- and asbestos-exposed workers seeking compensation. A CT scan study. Chest. 1995;108(3):647-55. Less than 25 subjects per arm. [pmid: 7656611].
Bendstrup KE, Ingemann Jensen J, Holm S, Bengtsson B. Out-patient rehabilitation improves activities of daily living, quality of life and exercise tolerance in chronic obstructive pulmonary disease. European Respiratory Journal. 1997;10(12):2801-6. Less than 25 subjects per arm. [pmid: 9493664].
Bener A, Lestringant GG, Beshwari MM, Pasha MA. Respiratory symptoms, skin disorders and serum IgE levels in farm workers. Allergie et Immunologie. 1999;31(2):52-6. Not smoking cessation and/or spirometry study. [pmid: 10219428].
Bennett RH, Cherek DR. Human avoidance responding with added point loss: effects of tobacco and abstinence. Pharmacology, Biochemistry & Behavior. 1992;41(1):139-44. Not smoking cessation and/or spirometry study.
Blanchard AR. Treatment of COPD exacerbations. Pharmacologic options and modification of risk factors. Postgraduate Medicine. 2002; 111(6):65–8, 71–2, 75. Review article.
Blaski CA, Watt JL, Quinn TJ, Thorne PS, Schwartz DA. Nasal lavage cellularity, grain dust, and airflow obstruction. Chest. 1996;109(4):1086-92. Not randomized controlled trial. [pmid: 8635334].
Boothman-Burrell D, Delany SG, Flannery EM, Hancox RJ, Taylor DR. The efficacy of inhaled corticosteroids in the management of non asthmatic chronic airflow obstruction. New Zealand Medical Journal. 1997;110(1053):370-3. Less than 25 subjects per arm. [pmid: 9364183].
Boyle AH, Waters HF. COPD: focus on prevention: recommendations of the National Lung Health Education Program. Chronic obstructive pulmonary disease. Heart & Lung: Journal of Acute & Critical Care. 2000;29(6):446-9. Less than 25 subjects per arm.
Brenner M, McKenna R Jr, Gelb A, Osann K, Schein MJ, Panzera J, et al. Objective predictors of response for staple versus laser emphysematous lung reduction. American Journal of Respiratory & Critical Care Medicine. 1997;155(4):1295-301. Not smoking cessation and/or spirometry study. [pmid: 9105070].
Buist AS. The US Lung Health Study. Respirology. 1997;2(4):303-7. Not relevant. [pmid: 9525302].
Buist AS, Nagy JM, Sexton GJ. The effect of smoking cessation on pulmonary function: a 30-month follow-up of two smoking cessation clinics. American Review of Respiratory Disease. 1979;120(4):953-7. Not randomized controlled trial. [pmid: 507517].
Buist AS, Sexton GJ, Nagy JM, Ross BB. The effect of smoking cessation and modification on lung function. American Review of Respiratory Disease. 1976;114(1):115-22. Not randomized controlled trial. [pmid: 937828].
Burrows B, Knudson RJ, Camilli AE, Lyle SK, Lebowitz MD. The “horse-racing effect” and predicting decline in forced expiratory volume in one second from screening spirometry. American Review of Respiratory Disease. 1987;135(4):788-93. Not randomized controlled trial. [pmid: 3565926].
Butler MW, O'Mahony MJ, Donnelly SC, McDonnell TJ. Managing exacerbations of COPD: room for improvement. Irish Medical Journal. 2004;97(4):108-10. Not smoking cessation. [pmid: 15200219].
Calverley PM, Walker P. Chronic obstructive pulmonary disease. Lancet. 2003;362(9389):1053-61. Review article. [pmid: 14522537].
Carey IM, Cook DG, Strachan DP. The effects of adiposity and weight change on forced expiratory volume decline in a longitudinal study of adults. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 1999;23(9):979-85. Not randomized controlled trial. [pmid: 10490805].
Carta P, Aru G, Manca P. Mortality from lung cancer among silicotic patients in Sardinia: an update study with 10 more years of follow up. Occupational & Environmental Medicine. 2001;58(12):786-93. Not randomized controlled trial. [pmid: 11706145]. [pmcid: 1740084].
Cazzola M, Boveri B, Carlucci P, Santus P, DiMarco F, Centanni S, et al. Lung function improvement in smokers suffering from COPD with zafirlukast, a CysLT(1)-receptor antagonist. Pulmonary Pharmacology & Therapeutics. 2000;13(6):301-5. Less than 25 subjects per arm. [pmid: 11061985].
Celedon JC, Speizer FE, Drazen JM, Weiss ST, Campbell EJ, Carey VJ, et al. Bronchodilator responsiveness and serum total IgE levels in families of probands with severe early-onset COPD. European Respiratory Journal. 1999;14(5):1009-14. Not randomized controlled trial. [pmid: 10596682].
Cheng YJ, Macera CA, Addy CL, Sy FS, Wieland D, Blair SN. Effects of physical activity on exercise tests and respiratory function. British Journal of Sports Medicine. 2003;37(6):521-8. Not randomized controlled trial. [pmid: 14665592]. [pmcid: 1724716].
Chinn DJ, Cotes JE, Reed JW. Longitudinal effects of change in body mass on measurements of ventilatory capacity. Thorax. 1996;51(7):699-704. Not randomized controlled trial. [pmid: 8882076]. [pmcid: 472492].
Christensen SB, Kjer J, Ryskjaer S, Arseth-Hansen P, Christensen F. Mucolytic treatment of chronic bronchitis during two winter periods. Scandinavian Journal of Respiratory Diseases. 1971;52(1):48-57. Not smoking cessation and/or spirometry study. [pmid: 5566508].
Clark KD, Wardrobe-Wong N, Elliott JJ, Gill PT, Tait NP, Snashall PD. Cigarette smoke inhalation and lung damage in smoking volunteers. European Respiratory Journal. 1998;12(2):395-9. Not randomized controlled trial. [pmid: 9727791].
Clotet J, Gomez-Arbones X, Ciria C, Albalad JM. Spirometry is a good method for detecting and monitoring chronic obstructive pulmonary disease in high-risk smokers in primary health care. Archivos de Bronconeumologia. 2004;40(4):155-9. Not English language. [pmid: 15030729].
Connett JE, Kusek JW, Bailey WC, O'Hara P, Wu M. Design of the Lung Health Study: a randomized clinical trial of early intervention for chronic obstructive pulmonary disease. Controlled Clinical Trials. 1993;14(2 Suppl):3S-19S. Not relevant. [pmid: 8500311].
Connett JE, Murray RP, Buist AS, Wise RA, Bailey WC, Lindgren PG, et al. Changes in smoking status affect women more than men: results of the Lung Health Study. American Journal of Epidemiology. 2003;157(11):973-9. Not relevant. [pmid: 12777360].
Corden Z, Rees PJ. The effect of oral corticosteroids on bronchodilator responses in COPD. Respiratory Medicine. 1998;92(2):279-82. Less than 25 subjects per arm. [pmid: 9616526].
Corradi M, Montuschi P, Donnelly LE, Pesci A, Kharitonov SA, Barnes PJ. Increased nitrosothiols in exhaled breath condensate in inflammatory airway diseases. American Journal of Respiratory & Critical Care Medicine. 2001;163(4):854-8. Not smoking cessation and/or spirometry study. [pmid: 11282756].
Corradi M, Rubinstein I, Andreoli R, Manini P, Caglieri A, Poli D, et al. Aldehydes in exhaled breath condensate of patients with chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 2003;167(10):1380-6. Not smoking cessation and/or spirometry study. [pmid: 12522029].
Curull V, Orozco-Levi M, Moyes D, Balcells E, Palacio J, Lloreta J, et al. Fiber-optic bronchoscopic biopsy of bronchial smooth muscle. Efficacy of the technique in individuals with normal lung function and patients with COPD. Archivos de Bronconeumologia. 2002;38(11):515-22. Not English language. [pmid: 12435317].
Czajkowska-Malinowska M, Nowinski A, Gorecka D, Zielinski J. Effects of spirometric screening in the community on smoking cessation. Pneumonologia i Alergologia Polska. 2001;69(910):524-9. Not English language. [pmid: 11928658].
Dahlen I, Janson C, Bjornsson E, Stalenheim G, Peterson CG, Venge P. Changes in inflammatory markers following treatment of acute exacerbations of obstructive pulmonary disease. Respiratory Medicine. 2001;95(11):891-7. Less than 25 subjects per arm. [pmid: 11716203].
Dal Negro R, Rossi A, Cerveri I. The burden of COPD in Italy: results from the Confronting COPD survey. Respiratory Medicine. 2003;97(Suppl C):S43-50. Not randomized controlled trial. [pmid: 12647942].
Das TK, Moutquin JM, Lindsay C, Parent JG, Fraser W. Effects of smoking cessation on maternal airway function and birth weight. Obstetrics & Gynecology. 1998;92(2):201-5. Not randomized controlled trial. [pmid: 9699751].
Decramer M, Bartsch P, Pauwels R, Yernault JC. Management of COPD according to guidelines. A national survey among Belgian physicians. Monaldi Archives for Chest Disease. 2003;59(1):62-80. Not randomized controlled trial. [pmid: 14533285].
DeJong SR, Veltman RH. The effectiveness of a CNS-led community-based COPD screening and intervention program. Clinical Nurse Specialist. 2004;18(2):72-9. No control group. [pmid: 15164668].
Dement JM, Welch L, Bingham E, Cameron B, Rice C, Quinn P, et al. Surveillance of respiratory diseases among construction and trade workers at Department of Energy nuclear sites. American Journal of Industrial Medicine. 2003;43(6):559-73. Less than 25 subjects per arm. Not randomized controlled trial. [pmid: 12768606].
Dheda K, Crawford A, Hagan G, Roberts CM. Implementation of British Thoracic Society guidelines for acute exacerbation of chronic obstructive pulmonary disease: impact on quality of life. Postgraduate Medical Journal. 2004;80(941):169-71. Less than 25 subjects per arm. [pmid: 15016940]. [pmcid: 1742943].
Diaz PT, King MA, Pacht ER, Wewers MD, Gadek JE, Nagaraja HN, et al. Increased susceptibility to pulmonary emphysema among HIV-seropositive smokers. Annals of Internal Medicine. 2000;132(5):369-72. Not randomized controlled trial. [pmid: 10691587].
Dippolito R, Foresi A, Chetta A, Castagnaro A, Malorgio R, Marangio E, et al. Eosinophils in induced sputum from asymptomatic smokers with normal lung function. Respiratory Medicine. 2001;95(12):969-74. Less than 25 subjects per arm. [pmid: 11778794].
Dirksen H, Janzon L, Lindell SE. Influence of smoking and cessation of smoking on lung function: a population study of closing volume and nitrogen wash-out. Scandinavian Journal of Respiratory Diseases - Supplementum. 1974;85:266-74. Not randomized controlled trial. [pmid: 4534918].
Doherty DE. Early detection and management of COPD. What you can do to reduce the impact of this disabling disease. Postgraduate Medicine. 2002; 111(6):41–4, 49–50, 53 passim. Review article.
Dompeling E, van Schayck CP, van Grunsven PM, van Herwaarden CL, Akkermans R, Molema J, et al. Slowing the deterioration of asthma and chronic obstructive pulmonary disease observed during bronchodilator therapy by adding inhaled corticosteroids. A 4-year prospective study. Annals of Internal Medicine. 1993;118(10):770-8. Not smoking cessation and/or spirometry study. [pmid: 8470851].
Doyle JJ, Eliasson AH, Argyros GJ, Dennis GJ, Finger DR, Hurwitz KM, et al. Prevalence of pulmonary disorders in patients with newly diagnosed rheumatoid arthritis. Clinical Rheumatology. 2000;19(3):217-21. Less than 25 subjects per arm. [pmid: 10870658].
Emmons KM, Weidner G, Foster WM, Collins RL. Improvement in pulmonary function following smoking cessation. Addictive Behaviors. 1992;17(4):301-6. Not randomized controlled trial. [pmid: 1502964].
Enright PL, Connett JE, Kanner RE, Johnson LR, Lee WW. Spirometry in the Lung Health Study: II. Determinants of short-term intraindividual variability. American Journal of Respiratory & Critical Care Medicine. 1995;151(2 Pt 1):406-11. Not relevant. [pmid: 7842199].
Enright PL, Crapo RO. Controversies in the use of spirometry for early recognition and diagnosis of chronic obstructive pulmonary disease in cigarette smokers. Clinics in Chest Medicine. 2000;21(4):645-52. Review article. [pmid: 11194776].
Enright PL, Johnson LR, Connett JE, Voelker H, Buist AS. Spirometry in the Lung Health Study. 1. Methods and quality control. American Review of Respiratory Disease. 1991;143(6):1215-23. Not relevant. [pmid: 2048803].
Enright PL, Kaminsky DA. Strategies for screening for chronic obstructive pulmonary disease. Respiratory Care. 2003;48(12):1194-201. Review article. [pmid: 14651760].
Enright RL, Connett JE, Bailey WC. The FEV1/FEV6 predicts lung function decline in adult smokers. Respiratory Medicine. 2002;96(6):444-9. Not relevant. [pmid: 12117045].
Erkinjuntti-Pekkanen R, Slater T, Cheng S, Fishwick D, Bradshaw L, Kimbell-Dunn M, et al. Two year follow up of pulmonary function values among welders in New Zealand. Occupational & Environmental Medicine. 1999;56(5):328-33. Not randomized controlled trial. [pmid: 10472307]. [pmcid: 1757732].
Evans JA, Morrison IM, Saunders KB. A controlled trial of prednisone, in low dosage, in patients with chronic airways obstruction. Thorax. 1974;29(4):401-6. Not randomized controlled trial. [pmid: 4603999]. [pmcid: 470171].
Evers H, Herrmann H, Ohme G. Value of the maximal expiratory flow-volume diagram in a longitudinal study. 2. Results in young adults. Zeitschrift fur Erkrankungen der Atmungsorgane. 1986;167(12):79-86. Not English language. [pmid: 3765718].
Fagerstrom KO. From reduced smoking to quitting: improvements in COPD symptoms and lung function: a case report. Nicotine & Tobacco Research. 2001;3(1):93-4. Less than 25 subjects per arm. [pmid: 11260816].
Faulkner MA, Hilleman DE. Pharmacologic treatment of chronic obstructive pulmonary disease: past, present, and future. Pharmacotherapy. 2003;23(10):1300-15. Review article. [pmid: 14594347].
Fehrenbach C. Chronic obstructive pulmonary disease. Nursing Standard. 2002;17(10):45-51. Review article. [pmid: 12494849].
Fehrenbach C. NICE guidelines for chronic obstructive pulmonary disease--a review. Nursing Times. 2004;100(24):48-51. Review article. [pmid: 15224493].
Ferguson GT, Enright PL, Buist AS, Higgins MW. Office spirometry for lung health assessment in adults: a consensus statement from the National Lung Health Education Program. Respiratory Care. 2000;45(5):513-30. Review article. [pmid: 10813228].
Ferguson GT, Enright PL, Buist AS, Higgins MW. Office spirometry for lung health assessment in adults: A consensus statement from the National Lung Health Education Program. Chest. 2000;117(4):1146-61. Review article. [pmid: 10767253].
Ferguson GT, Petty TL. Screening and early intervention for COPD. Hospital Practice (Office Edition). 1998; 33(4): 67–72, 79–80, 83. Review article.
Finkelstein R, Ma HD, Ghezzo H, Whittaker K, Fraser RS, Cosio MG. Morphometry of small airways in smokers and its relationship to emphysema type and hyperresponsiveness. American Journal of Respiratory & Critical Care Medicine. 1995;152(1):267-76. Not randomized controlled trial. [pmid: 7599834].
Fraser KL, Chapman KR. Chronic obstructive pulmonary disease. Prevention, early detection, and aggressive treatment can make a difference. Postgraduate Medicine. 2000; 108(7):103–4, 107–10, 113–6. Review article.
Fukuchi Y. Physiopathology of chronic obstructive lung disease and progress in its therapy. Nippon Naika Gakkai Zasshi - Journal of Japanese Society of Internal Medicine. 2002;91(Suppl):10-4. Not English language.
Garcia-Aymerich J, Barreiro E, Farrero E, Marrades RM, Morera J, Anto JM. Patients hospitalized for COPD have a high prevalence of modifiable risk factors for exacerbation (EFRAM study). European Respiratory Journal. 2000;16(6):1037-42. Not randomized controlled trial. [pmid: 11292102].
Garcia-Aymerich J, Monso E, Marrades RM, Escarrabill J, Felez MA, Sunyer J, et al. Risk factors for hospitalization for a chronic obstructive pulmonary disease exacerbation. EFRAM study. American Journal of Respiratory & Critical Care Medicine. 2001;164(6):1002-7. Not randomized controlled trial. [pmid: 11587986].
Gene RJ, Giugno ER, Abbate EH, Figueroa-Casas JC, Mazzei JA, Schiavi EA. Updated Argentine consensus on chronic obstructive pulmonary disease. Medicina. 2003;63(5):419-46. Not English language. [pmid: 14628655].
Gentry SE, Hodge RH, Kaiser D, Walker FB 4th, Suratt PM. Pulmonary function testing in a general medical practice. Journal of Community Health. 1983;8(4):263-8. Not randomized controlled trial. [pmid: 6643711].
Goel A, Suri JC, Aggarwal K. Role of corticosteroids in the management of chronic obstructive lung disease: factors predicting response. Indian Journal of Chest Diseases & Allied Sciences. 1992;34(1):11-7. Not smoking cessation and/or spirometry study. [pmid: 1521875].
Goldsmith JR, Scharf SM, Israeli R. Pulmonary function screening and monitoring in occupational health. Journal of Occupational Medicine. 1986;28(8):656-63. Not randomized controlled trial. [pmid: 3746487].
Gorecka D, Bednarek M, Kislo A, Zalewska A, Czechowska U, Jedrzejczak M, et al. Awareness of airflow obstruction together with antismoking advice increases success in cessation smoking. Pneumonologia i Alergologia Polska. 2001;69(1112):617-25. Not English language. [pmid: 12134437].
Gorecka D, Bednarek M, Nowinski A, Kaminski D, Bielen P, Kolakowski J, et al. Predictors of success in smoking cessation among participants of spirometric screening for COPD. Pneumonologia i Alergologia Polska. 2001;69(1112):611-6. Not English language. [pmid: 12134436].
Gorecka D, Bednarek M, Nowinski A, Puscinska E, Goljan-Geremek A, Zielinski J. Diagnosis of airflow limitation combined with smoking cessation advice increases stop-smoking rate. Chest. 2003;123(6):1916-23. Not randomized controlled trial. [pmid: 12796168].
Gorecka D, Bednarek M, Nowinski A, Puscinska E, Goljan-Geremek A, Zielinski J. Effect of treatment for nicotine dependence in patients with COPD. Pneumonologia i Alergologia Polska. 2003;71(910):411-7. Not English language. [pmid: 15052977].
Gottlieb DJ, Stone PJ, Sparrow D, Gale ME, Weiss ST, Snider GL, et al. Urinary desmosine excretion in smokers with and without rapid decline of lung function: the Normative Aging Study. American Journal of Respiratory & Critical Care Medicine. 1996;154(5):1290-5. Not randomized controlled trial. [pmid: 8912738].
Greenberg JA, Singhal S, Kaiser LR. Giant bullous lung disease: evaluation, selection, techniques, and outcomes. Chest Surgery Clinics of North America. 2003;13(4):631-49. Review article. [pmid: 14682599].
Guatura SB, Martinez JA, Santos Bueno PC, Santos ML. Increased exhalation of hydrogen peroxide in healthy subjects following cigarette consumption. Sao Paulo Medical Journal = Revista Paulista de Medicina. 2000;118(4):93-8. Not randomized controlled trial. [pmid: 10887384].
Habib MP, Tank LJ, Lane LC, Garewal HS. Effect of vitamin E on exhaled ethane in cigarette smokers. Chest. 1999;115(3):684-90. Not randomized controlled trial. [pmid: 10084476].
Hessel PA, Herbert FA, Melenka LS, Yoshida K, Michaelchuk D, Nakaza M. Lung health in sawmill workers exposed to pine and spruce. Chest. 1995;108(3):642-6. Not randomized controlled trial. [pmid: 7656610].
Holland WW, Ashford JR, Colley JR, Morgan DC, Pearson NJ. A comparison of two respiratory symptoms questionnaires. British Journal of Preventive & Social Medicine. 1966;20(2):76-96. Not smoking cessation and/or spirometry study. [pmid: 5959678]. [pmcid: 1059031].
Holmen TL, Barrett-Connor E, Clausen J, Holmen J, Bjermer L. Physical exercise, sports, and lung function in smoking versus nonsmoking adolescents. European Respiratory Journal. 2002;19(1):8-15. Not smoking cessation and/or spirometry study. [pmid: 11843331].
Huang SL, Su CH, Chang SC. Tumor necrosis factor-alpha gene polymorphism in chronic bronchitis. American Journal of Respiratory & Critical Care Medicine. 1997;156(5):1436-9. Not smoking cessation and/or spirometry study. [pmid: 9372657].
Jaakkola MS, Jaakkola JJ. Effects of environmental tobacco smoke on the respiratory health of adults. Scandinavian Journal of Work, Environment & Health. 2002;28(Suppl 2):52-70. Review article.
Jimenez-Ruiz CA, Masa F, Miravitlles M, Gabriel R, Viejo JL, Villasante C, et al. Smoking characteristics: differences in attitudes and dependence between healthy smokers and smokers with COPD. Chest. 2001;119(5):1365-70. Not randomized controlled trial. [pmid: 11348940].
Johnston RN, McNeill RS, Smith DH, Dempster MB, Nairn JR, Purvis MS, et al. Five-year winter chemoprophylaxis for chronic bronchitis. British Medical Journal. 1969;4(678):265-9. Not smoking cessation and/or spirometry study. [pmid: 4899454]. [pmcid: 1629696].
Joy M. Management of chronic obstructive pulmonary disease. New England Journal of Medicine. 2004;351(14):1461-3. Not smoking cessation. [pmid: 15459997].
Kanner RE, Anthonisen NR, Connett JE. Lung Health Study Research Group. Lower respiratory illnesses promote FEV(1) decline in current smokers but not ex-smokers with mild chronic obstructive pulmonary disease: results from the lung health study. American Journal of Respiratory & Critical Care Medicine. 2001;164(3):358-64. Not relevant. [pmid: 11500333].
Kanner RE, Connett JE, Williams DE, Buist AS. Effects of randomized assignment to a smoking cessation intervention and changes in smoking habits on respiratory symptoms in smokers with early chronic obstructive pulmonary disease: the Lung Health Study. American Journal of Medicine. 1999;106(4):410-6. Not relevant. [pmid: 10225243].
Karakatsani A, Andreadaki S, Katsouyanni K, Dimitroulis I, Trichopoulos D, Benetou V, et al. Air pollution in relation to manifestations of chronic pulmonary disease: a nested case-control study in Athens, Greece. European Journal of Epidemiology. 2003;18(1):45-53. Not randomized controlled trial. [pmid: 12705623].
Karnak D, Beng-sun S, Beder S, Kayacan O. Chlamydia pneumoniae infection and acute exacerbation of chronic obstructive pulmonary disease (COPD). Respiratory Medicine. 2001;95(10):811-6. Not randomized controlled trial. [pmid: 11601747].
Kehrl HR, Hazucha MJ, Solic JJ, Bromberg PA. Responses of subjects with chronic obstructive pulmonary disease after exposures to 0.3 ppm ozone. American Review of Respiratory Disease. 1985;131(5):719-24. Not smoking cessation and/or spirometry study. [pmid: 4003916].
Kilburn KH, Warshaw RH. Airways obstruction from asbestos exposure. Effects of asbestosis and smoking. Chest. 1994;106(4):1061-70. Not randomized controlled trial. [pmid: 7924474].
Kips JC. Preoperative pulmonary evaluation. Acta Clinica Belgica. 1997;52(5):301-5. Not randomized controlled trial. [pmid: 9489124].
Knudson RJ, Kaltenborn WT, Burrows B. The effects of cigarette smoking and smoking cessation on the carbon monoxide diffusing capacity of the lung in asymptomatic subjects. American Review of Respiratory Disease. 1989;140(3):645-51. Not randomized controlled trial. [pmid: 2782738].
Kornmann O, Beeh KM, Beier J, Geis UP, Ksoll M, Buhl R, et al. Newly diagnosed chronic obstructive pulmonary disease. Clinical features and distribution of the novel stages of the Global Initiative for Obstructive Lung Disease. Respiration. 2003;70(1):67-75. Not smoking cessation and/or spirometry study. [pmid: 12584394].
Kossmann S, Konieczny B, Hoffmann A. The role of respiratory muscles in the impairment of the respiratory system function in the workers of a chemical plant division producing pesticides. Przeglad Lekarski. 1997;54(10):702-6. Not randomized controlled trial. [pmid: 9478089].
Krahn M, Chapman KR. Economic issues in the use of office spirometry for lung health assessment. Canadian Respiratory Journal. 2003;10(6):320-6. Not smoking cessation and/or spirometry study. [pmid: 14530824].
Kurosawa H. Clinical examinations for COPD. Rinsho Byori - Japanese Journal of Clinical Pathology. 2000;48(12):1118-24. Not English language.
Lam S, leRiche JC, Zheng Y, Coldman A, MacAulay C, Hawk E, et al. Sex-related differences in bronchial epithelial changes associated with tobacco smoking. Journal of the National Cancer Institute. 1999;91(8):691-6. Not randomized controlled trial. [pmid: 10218506].
Law M, Tang JL. An analysis of the effectiveness of interventions intended to help people stop smoking. Archives of Internal Medicine. 1995;155(18):1933-41. Review article. [pmid: 7575046].
Lebowitz MD, Holberg CJ, Knudson RJ, Burrows B. Longitudinal study of pulmonary function development in childhood, adolescence, and early adulthood. Development of pulmonary function. American Review of Respiratory Disease. 1987;136(1):69-75. Not randomized controlled trial. [pmid: 3605844].
Lilis R, Miller A, Godbold J, Chan E, Selikoff IJ. Radiographic abnormalities in asbestos insulators: effects of duration from onset of exposure and smoking. Relationships of dyspnea with parenchymal and pleural fibrosis. American Journal of Industrial Medicine. 1991;20(1):1-15. Not randomized controlled trial. [pmid: 1867212].
Linn WS, Adkins RH, Gong H Jr, Waters RL. Pulmonary function in chronic spinal cord injury: a cross-sectional survey of 222 southern California adult outpatients. Archives of Physical Medicine & Rehabilitation. 2000;81(6):757-63. Not randomized controlled trial. [pmid: 10857520].
Lofdahl CG, Postma DS, Laitinen LA, Ohlsson SV, Pauwels RA, Pride NB. The European Respiratory Society study on chronic obstructive pulmonary disease (EUROSCOP): recruitment methods and strategies. Respiratory Medicine. 1998;92(3):467-72. Not relevant. [pmid: 9692107].
Lubinski W, Targowski T, Frank-Piskorska A. Evaluation of the influence of tobacco smoking on pulmonary function in youg men. Pneumonologia i Alergologia Polska. 2000;68(56):226-31. Not English language. [pmid: 11004860].
Lundqvist G, Persson A, Widman L, Lundgren R, Linden G. Chronic obstructive lung disease. Early diagnosis in primary health care requires well-functioning spirometry routines. Lakartidningen. 2001;98(43):4702-3. Not English language. [pmid: 11715246].
Maesen BL, Westermann CJ, Duurkens VA, van den Bosch JM. Effects of formoterol in apparently poorly reversible chronic obstructive pulmonary disease. European Respiratory Journal. 1999;13(5):1103-8. Less than 25 subjects per arm. [pmid: 10414411].
Man SF, McAlister FA, Anthonisen NR, Sin DD. Contemporary management of chronic obstructive pulmonary disease: clinical applications. JAMA. 2003;290(17):2313-6. Review article. [pmid: 14600190].
Mapel DW, Picchi MA, Hurley JS, Frost FJ, Petersen HV, Mapel VM, et al. Utilization in COPD: patient characteristics and diagnostic evaluation. Chest. 2000;117(5 Suppl 2):346S-53S. Not randomized controlled trial. [pmid: 10843975].
Marcisz C, Jonderko G, Wieczorek-Latka U, Jonderko K, Kotulska A. The respiratory system of workers employed in the casting and processing of copper. Pneumonologia i Alergologia Polska. 1998;66(910):433-9. Not English language. [pmid: 10354692].
Martin RR, Lindsay D, Despas P, Bruce D, Leroux M, Anthonisen NR, et al. The early detection of airway obstruction. American Review of Respiratory Disease. 1975;111(2):119-25. Not randomized controlled trial. [pmid: 1111399].
Massasso DH, Salome CM, King GG, Seale JP, Woolcock AJ. Perception of bronchodilation in subjects with asthma and smokers with airflow limitation. Respirology. 1999;4(2):117-24. Not randomized controlled trial. [pmid: 10382229].
McIvor RA, Tashkin DP. Underdiagnosis of chronic obstructive pulmonary disease: a rationale for spirometry as a screening tool. Canadian Respiratory Journal. 2001;8(3):153-8. Review article. [pmid: 11420591].
McLeod SJ, Pearce MJ, Rigby SA, Begg EJ, Beard ME, Martin IR, et al. Asthma management at Christchurch Hospital: compliance with guidelines. New Zealand Medical Journal. 1996;109(1019):115-8. Not randomized controlled trial. [pmid: 8618737].
Mengesha YA, Bekele A. Relative chronic effects of different occupational dusts on respiratory indices and health of workers in three Ethiopian factories. American Journal of Industrial Medicine. 1998;34(4):373-80. Not smoking cessation and/or spirometry study. [pmid: 9750944].
Mitsunobu F, Ashida K, Hosaki Y, Tsugeno H, Okamoto M, Nishida N, et al. Influence of long-term cigarette smoking on immunoglobulin E-mediated allergy, pulmonary function, and high-resolution computed tomography lung densitometry in elderly patients with asthma. Clinical & Experimental Allergy. 2004;34(1):59-64. Not smoking cessation. [pmid: 14720263].
Moreno R, Gonzalez P. Ambulatory management of chronic obstructive pulmonary disease (COPD): a consensus report. Revista Medica de Chile. 1999;127(2):229-34. Not English language. [pmid: 10436705].
Morris JF, Temple W. Spirometric “lung age” estimation for motivating smoking cessation. Preventive Medicine. 1985;14(5):655-62. Not randomized controlled trial. [pmid: 4070195].
Murray RP, Anthonisen NR, Connett JE, Wise RA, Lindgren PG, Greene PG, et al. Effects of multiple attempts to quit smoking and relapses to smoking on pulmonary function. Lung Health Study Research Group. Journal of Clinical Epidemiology. 1998;51(12):1317-26. Not relevant. [pmid: 10086826].
Nagai A. Diagnosis and treatment of COPD. Nippon Naika Gakkai Zasshi - Journal of Japanese Society of Internal Medicine. 2002;91(Suppl):137-40. Not English language.
Naunheim KS, Hazelrigg SR, Kaiser LR, Keenan RJ, Bavaria JE, Landreneau RJ, et al. Risk analysis for thoracoscopic lung volume reduction: a multi-institutional experience. European Journal of Cardio-Thoracic Surgery. 2000;17(6):673-9. Not randomized controlled trial. [pmid: 10856858].
Noertjojo HK, Dimich-Ward H, Peelen S, Dittrick M, Kennedy SM, Chan-Yeung M. Western red cedar dust exposure and lung function: a dose-response relationship. American Journal of Respiratory & Critical Care Medicine. 1996;154(4 Pt 1):968-73. Not smoking cessation and/or spirometry study. [pmid: 8887593].
Nowinski A, Plywaczewski R, Kolakowski J, Zielinski J. Early detection of airflow limitation in smokers in remote areas of Poland. Pneumonologia i Alergologia Polska. 2002;70(34):148-54. Not English language. [pmid: 12271962].
O'Donnell DE, Aaron S, Bourbeau J, Hernandez P, Marciniuk D, Balter M, et al. Canadian Thoracic Society recommendations for management of chronic obstructive pulmonary disease--2003. Canadian Respiratory Journal. 2003;10(Suppl A):11A-65A. Review article.
On LS, Boonyongsunchai P, Webb S, Davies L, Calverley PM, Costello RW. Function of pulmonary neuronal M(2) muscarinic receptors in stable chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 2001;163(6):1320-5. Not smoking cessation and/or spirometry study. [pmid: 11371395].
Osinubi OY, Afilaka AA, Doucette J, Golden A, Soriano T, Rovner E, et al. Study of smoking behavior in asbestos workers. American Journal of Industrial Medicine. 2002;41(1):62-9. Not smoking cessation and/or spirometry study. [pmid: 11757056].
Paiva SA, Godoy I, Vannucchi H, Favaro RM, Geraldo RR, Campana AO. Assessment of vitamin A status in chronic obstructive pulmonary disease patients and healthy smokers. American Journal of Clinical Nutrition. 1996;64(6):928-34. Less than 25 subjects per arm. [pmid: 8942419].
Pauwels RA, Rabe KF. Burden and clinical features of chronic obstructive pulmonary disease (COPD). Lancet. 2004;364(9434):613-20. Review article. [pmid: 15313363].
Petrie GR, Palmer KN. Comparison of aerosol ipratropium bromide and salbutamol in chronic bronchitis and asthma. British Medical Journal. 1975;1(5955):430-2. Not smoking cessation and/or spirometry study. [pmid: 1090337]. [pmcid: 1672418].
Petty TL. Can ‘old’ lungs be restored? Strategies for preserving lung health and preventing and treating COPD. Postgraduate Medicine. 1998; 104(4):173–8, 181–2. Review article.
Petty TL. Chronic obstructive pulmonary disease--can we do better?. Chest. 1990;97(2 Suppl):2S-5S. Review article. [pmid: 2404709].
Petty TL. Commentary: quality of spirometry testing. American Journal of Medical Quality. 2001;16(6):216-8. Commentary. [pmid: 11816853].
Petty TL. COPD in perspective. Chest. 2002;121(5 Suppl):116S-120S. Review article. [pmid: 12010838].
Petty TL. COPD. Interventions for smoking cessation and improved ventilatory function. Geriatrics. 2000; 55(12):30–2, 35–9. Review article.
Petty TL. Early diagnosis of COPD. Hospital Practice (Office Edition). 2001;36(4):7-8. Editorial.
Petty TL. The National Lung Health Education Program. A new healthcare initiative for America. Journal of Cardiopulmonary Rehabilitation. 2001;21(3):149-51. Review article. [pmid: 11409224].
Petty TL. Scope of the COPD problem in North America: early studies of prevalence and NHANES III data: basis for early identification and intervention. Chest. 2000;117(5 Suppl 2):326S-31S. Review article. [pmid: 10843971].
Petty TL. The worldwide epidemiology of chronic obstructive pulmonary disease. Current Opinion in Pulmonary Medicine. 1996;2(2):84-9. Review article. [pmid: 9363121].
Petty TL, Doherty DE. National Lung Health Education Program. The National Lung Health Education Program: roots, mission, future directions. Respiratory Care. 2004;49(6):678-83. Review article. [pmid: 15165302].
Pierson DJ. Translating new understanding into better care for the patient with chronic obstructive pulmonary disease. Respiratory Care. 2004;49(1):99-109. Review article. [pmid: 14733626].
Pride NB. Smoking cessation: effects on symptoms, spirometry and future trends in COPD. Thorax. 2001;56(Suppl 2):ii7-10. Review article. [pmid: 11514700].
Puscinska E, Klimaszewski A, Gorecka D, Zielinski J. Evaluation of the effectiveness of medical consultation regarding smoking cessation. Pneumonologia i Alergologia Polska. 1991;59(34):91-5. Not English language. [pmid: 1843914].
Remiszewski W, Lupina T, Mackiewicz B, Golebiowska I, Milanowski J. Evaluation of the effectiveness of short-term smoking cessation treatment in patients of the Pulmonary Department, Medical University of Lublin. Annales Universitatis Mariae Curie-Sklodowska - Sectio d - Medicina. 2003;58(1):306-9. No control group. [pmid: 15315004].
Richter ED, Tuch H, Sarel O, Shabbat Z, Weiler D. Smoking, morbidity, and pulmonary function in a group of ex-asbestos workers: a pilot study. American Journal of Industrial Medicine. 1986;10(56):515-23. Not randomized controlled trial. [pmid: 3812491].
Rubinstein I, Zamel N, DuBarry L, Hoffstein V. Airflow limitation in morbidly obese, nonsmoking men. Annals of Internal Medicine. 1990;112(11):828-32. Not smoking cessation and/or spirometry study. [pmid: 2378649].
Rutgers SR, Koeter GH, Van Der Mark TW, Postma DS. Protective effect of oral terfenadine and not inhaled ipratropium on adenosine 5'-monophosphate-induced bronchoconstriction in patients with COPD. Clinical & Experimental Allergy. 1999;29(9):1287-92. Not smoking cessation and/or spirometry study. [pmid: 10469040].
Sachs AP, Koeter GH, Groenier KH, van der Waaij D, Schiphuis J, Meyboom-de Jong B. Changes in symptoms, peak expiratory flow, and sputum flora during treatment with antibiotics of exacerbations in patients with chronic obstructive pulmonary disease in general practice. Thorax. 1995;50(7):758-63. Not smoking cessation and/or spirometry study. [pmid: 7570411]. [pmcid: 474649].
Sachs DP, Hall RG, Hall SM. Effects of rapid smoking. Physiologic evaluation of a smoking-cessation therapy. Annals of Internal Medicine. 1978;88(5):639-41. Not smoking cessation and/or spirometry study. [pmid: 646248].
Saetta M, Mariani M, Panina-Bordignon P, Turato G, Buonsanti C, Baraldo S, et al. Increased expression of the chemokine receptor CXCR3 and its ligand CXCL10 in peripheral airways of smokers with chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 2002;165(10):1404-9. Not smoking cessation and/or spirometry study. [pmid: 12016104].
Sampablo I, Lores L, Coll-Klein F, Jimenez C, Rebasa P. Predictive factors in smoking cessation with combined therapy with bupropion and nicotine patches. Monaldi Archives for Chest Disease. 2003;59(2):171-6. Not smoking cessation and/or spirometry study. [pmid: 14635510].
Sansores RH, Pare P, Abboud RT. Effect of smoking cessation on pulmonary carbon monoxide diffusing capacity and capillary blood volume. American Review of Respiratory Disease. 1992;146(4):959-64. Not smoking cessation and/or spirometry study. [pmid: 1416425].
Scullion J. COPD guidelines to reflect changes. Professional Nurse. 2004;19(7):370. News article.
Seersholm N, Kok-Jensen A, Dirksen A. Decline in FEV1 among patients with severe hereditary alpha 1-antitrypsin deficiency type PiZ. American Journal of Respiratory & Critical Care Medicine. 1995;152(6 Pt 1):1922-5. Not smoking cessation and/or spirometry study. [pmid: 8520756].
Senore C, Battista RN, Shapiro SH, Segnan N, Ponti A, Rosso S, et al. Predictors of smoking cessation following physicians' counseling. Preventive Medicine. 1998;27(3):412-21. No relevant outcomes. [pmid: 9612831].
Sherman CB. Late-onset asthma: making the diagnosis, choosing drug therapy. Geriatrics 1995; 50(12):24–6, 29–30, 33. Review article.
Siafakas NM, Tzanakis N. Diagnosis and treatment of chronic obstructive pulmonary disease: evidence-based medicine. Monaldi Archives for Chest Disease. 1998;53(6):704-8. Review article. [pmid: 10063350].
Siekmeier R, Buhl R, Schultze-Werninghaus G, Kronenberger H. Unspecific bronchial reactivity to carbachol in healthy subjects--effect of age and smoking habits. Respiration. 1994;61(4):199-203. Not smoking cessation and/or spirometry study. [pmid: 7973104].
Societe de pneumologie de langue francaise. Recommendations for the management of COPD. Essential points/general medicine version. Presse Medicale. 2003;32(25):1187-94. Not English language.
Stucki A, Bolliger CT. Evaluation of surgical risk in patients with COPD. Therapeutische Umschau. 1999;56(3):151-6. Not English language. [pmid: 10218438].
Swan GE, Roby TJ, Hodgkin JE, Mittman C, Peters JA, Jacobo N. Relationship of cytomorphology to spirometric findings in cigarette smokers. Acta Cytologica. 1994;38(4):547-53. Not randomized controlled trial. [pmid: 8042421].
Takahashi T, Ichinose M, Inoue H, Shirato K, Hattori T, Takishima T. Underdiagnosis and undertreatment of COPD in primary care settings. Respirology. 2003;8(4):504-8. Not smoking cessation and/or spirometry study. [pmid: 14629656].
Tashkin D, Kanner R, Bailey W, Buist S, Anderson P, Nides M, et al. Smoking cessation in patients with chronic obstructive pulmonary disease: a double-blind, placebo-controlled, randomised trial. Lancet. 2001;357(9268):1571-5. Not smoking cessation and/or spirometry study. [pmid: 11377644].
Tashkin DP, Altose MD, Connett JE, Kanner RE, Lee WW, Wise RA. Methacholine reactivity predicts changes in lung function over time in smokers with early chronic obstructive pulmonary disease. The Lung Health Study Research Group. American Journal of Respiratory & Critical Care Medicine. 1996;153(6 Pt 1):1802-11. Not relevant. [pmid: 8665038].
Thompson AB, Mueller MB, Heires AJ, Bohling TL, Daughton D, Yancey SW, et al. Aerosolized beclomethasone in chronic bronchitis. Improved pulmonary function and diminished airway inflammation. American Review of Respiratory Disease. 1992;146(2):389-95. Not smoking cessation and/or spirometry study. [pmid: 1489129].
Thompson WH, Carvalho P, Souza JP, Charan NB. Controlled trial of inhaled fluticasone propionate in moderate to severe COPD. Lung. 2002;180(4):191-201. Not smoking cessation and/or spirometry study. [pmid: 12391509].
Todisco T, Baglioni S, Amir E, Palumbo R. Effect of bamiphylline on tracheobronchial mucus clearance in subjects with smokers' simple chronic bronchitis. Respiration. 1995;62(1):16-20. Not smoking cessation and/or spirometry study. [pmid: 7716349].
Tonnesen P, Mikkelsen KL. Smoking cessation with four nicotine replacement regimes in a lung clinic. European Respiratory Journal. 2000;16(4):717-22. Not smoking cessation and/or spirometry study. [pmid: 11106218].
Toyoshima H, Yoshida M. Management of patients with stable COPD. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2003;61(12):2163-9. Not English language. [pmid: 14674327].
Ulrik CS. Efficacy of inhaled salmeterol in the management of smokers with chronic obstructive pulmonary disease: a single centre randomised, double blind, placebo controlled, crossover study. Thorax. 1995;50(7):750-4. Not smoking cessation and/or spirometry study. [pmid: 7570409]. [pmcid: 474647].
Ulvestad B, Bakke B, Eduard W, Kongerud J, Lund MB. Cumulative exposure to dust causes accelerated decline in lung function in tunnel workers. Occupational & Environmental Medicine. 2001;58(10):663-9. Not smoking cessation and/or spirometry study. [pmid: 11555688]. [pmcid: 1740057].
Unalacak M, Altin R, Kart L, Tor M, Ornek T, Altunel H. Smoking prevalence, behaviour and nicotine addiction among coal workers in Zonguldak, Turkey. Journal of Occupational Health. 2004;46(4):289-95. Not smoking cessation. [pmid: 15308828].
van Belle AF, Lamers RJ, ten Velde GP, Wouters EF. Diagnostic yield of computed tomography and densitometric measurements of the lung in thoracoscopically-defined idiopathic spontaneous pneumothorax. Respiratory Medicine. 2001;95(4):292-6. Not smoking cessation and/or spirometry study. [pmid: 11316112].
van Schayck CP. The revised Dutch College of General Practitioners' standard on COPD and the first international WHO standard: differences and similarities. Nederlands Tijdschrift voor Geneeskunde. 2002;146(8):353-6. Not English language. [pmid: 11887619].
Vandentorren S, Baldi I, Annesi Maesano I, Charpin D, Neukirch F, Filleul L, et al. Long-term mortality among adults with or without asthma in the PAARC study. European Respiratory Journal. 2003;21(3):462-7. Not smoking cessation and/or spirometry study. [pmid: 12662002].
Verbanck S, Schuermans D, Meysman M, Paiva M, Vincken W. Noninvasive assessment of airway alterations in smokers: the small airways revisited. American Journal of Respiratory & Critical Care Medicine. 2004;170(4):414-9. Not smoking cessation. [pmid: 15130906].
Vergnenegre A, Pugnere N, Antonini MT, Arnaud M, Melloni B, Treves R, et al. Airway obstruction and rheumatoid arthritis. European Respiratory Journal. 1997;10(5):1072-8. Not smoking cessation and/or spirometry study. [pmid: 9163649].
Verhoeven GT, Garrelds IM, Hoogsteden HC, Zijlstra FJ. Effects of fluticasone propionate inhalation on levels of arachidonic acid metabolites in patients with chronic obstructive pulmonary disease. Mediators of Inflammation. 2001;10(1):21-6. Not smoking cessation and/or spirometry study. [pmid: 11324900]. [pmcid: 1781690].
Vogelmeier C. Chronic obstructive lung disease. Internist. 2003; 44( Suppl 1):S16–22, S24–7. Not English language.
Wacker J. Chronic obstructive syndromes. The practitioner's hope. Schweizerische Rundschau fur Medizin Praxis. 1991;80(18):489-91. Not English language. [pmid: 2047627].
Walter RE, Beiser A, Givelber RJ, O'Connor GT, Gottlieb DJ. Association between glycemic state and lung function: the Framingham Heart Study. American Journal of Respiratory & Critical Care Medicine. 2003;167(6):911-6. Not smoking cessation and/or spirometry study. [pmid: 12623860].
Warner MA, Offord KP, Warner ME, Lennon RL, Conover MA, Jansson-Schumacher U. Role of preoperative cessation of smoking and other factors in postoperative pulmonary complications: a blinded prospective study of coronary artery bypass patients. Mayo Clinic Proceedings. 1989;64(6):609-16. Not smoking cessation and/or spirometry study. [pmid: 2787456].
Watson L, Margetts B, Howarth P, Dorward M, Thompson R, Little P. The association between diet and chronic obstructive pulmonary disease in subjects selected from general practice. European Respiratory Journal. 2002;20(2):313-8. Not smoking cessation and/or spirometry study. [pmid: 12212961].
Wells AU, King AD, Rubens MB, Cramer D, du Bois RM, Hansell DM. Lone cryptogenic fibrosing alveolitis: a functional-morphologic correlation based on extent of disease on thin-section computed tomography. American Journal of Respiratory & Critical Care Medicine. 1997;155(4):1367-75. Not smoking cessation and/or spirometry study. [pmid: 9105081].
Wepner U. Deemed harmless, underdiagnosed, insufficiently treated. Underestimated killer COPD. MMW Fortschritte der Medizin. 2003;145(8):4-5. Not English language.
Willemse BW, Postma DS, Timens W, ten Hacken NH. The impact of smoking cessation on respiratory symptoms, lung function, airway hyperresponsiveness and inflammation. European Respiratory Journal. 2004;23(3):464-76. Review article. [pmid: 15065840].
Wise RA, Connett J, Kurnow K, Grill J, Johnson L, Kanner R, et al. Selection of spirometric measurements in a clinical trial, the Lung Health Study. American Journal of Respiratory & Critical Care Medicine. 1995;151(3 Pt 1):675-81. Not relevant. [pmid: 7881655].
Woehlck HJ, Connolly LA, Cinquegrani MP, Dunning MB 3rd, Hoffmann RG. Acute smoking increases ST depression in humans during general anesthesia. Anesthesia & Analgesia. 1999;89(4):856-60. Not smoking cessation and/or spirometry study. [pmid: 10512255].
Wurtemberger G, Schumacher H. Prevalence of obstructive airway disease in middle-age adults. Cross sectional study in three different occupations. Pneumologie. 2002;56(5):288-92. Not English language. [pmid: 12089645].
Yamamoto C, Yoneda T, Yoshikawa M, Fu A, Tokuyama T, Tsukaguchi K, et al. Airway inflammation in COPD assessed by sputum levels of interleukin-8. Chest. 1997;112(2):505-10. Not smoking cessation and/or spirometry study. [pmid: 9266891].
Yang SC. Relationship between smoking habits and lung function changes with conventional spirometry. Journal of the Formosan Medical Association. 1993;92(Suppl 4):S225-31. Not English language. [pmid: 7910080].
Yang SC, Yang SP. Bronchial responsiveness and lung function related to cigarette smoking and smoking cessation. Chang Gung Medical Journal. 2002;25(10):645-55. Not randomized controlled trial. [pmid: 12518776].
Ye TT, Huang JX, Shen YE, Lu PL, Christiani DC. Respiratory symptoms and pulmonary function among Chinese rice-granary workers. International Journal of Occupational & Environmental Health. 1998;4(3):155-9. Not smoking cessation and/or spirometry study. [pmid: 10026476].
Yohannes AM, Hardy CC. Treatment of chronic obstructive pulmonary disease in older patients: a practical guide. Drugs & Aging. 2003;20(3):209-28. Review article. [pmid: 12578401].

### Listing of Excluded Studies: Q3—Sin Update

Abad Santos F, Novalbos J, Gallego Sandin S, Galvez Mugica MA. Regulation of bronchial tone in chronic obstructive pulmonary disease (COPD): role of muscarinic receptors. Anales de Medicina Interna. 2003;20(4):201-5. Not English language. [pmid: 12768836].
Adcock IM, Chung KF. Overview: why are corticosteroids ineffective in COPD?. Current Opinion in Investigational Drugs. 2002;3(1):58-60. Review article. [pmid: 12054074].
Alsaeedi A, Sin DD, McAlister FA. The effects of inhaled corticosteroids in chronic obstructive pulmonary disease: a systematic review of randomized placebo-controlled trials. American Journal of Medicine. 2002;113(1):59-65. Review article. [pmid: 12106623].
Altman EE. Update on COPD. Today's strategies improve quality of life. Advance for Nurse Practitioners. 2004;12(3):49-54. Review article. [pmid: 15038185].
Altose MD. Approaches to slowing the progression of COPD. Current Opinion in Pulmonary Medicine. 2003;9(2):125-30. Review article. [pmid: 12574692].
Ambrosino N, Clini E. Long-term mechanical ventilation and nutrition. Respiratory Medicine. 2004;98(5):413-20. Review article. [pmid: 15139570].
Ambrosino N, Rossi A. Proportional assist ventilation (PAV): a significant advance or a futile struggle between logic and practice?. Thorax. 2002;57(3):272-6. Review article. [pmid: 11867835]. [pmcid: 1746276].
Anderson FE, Kingshott RN, Taylor DR, Jones DR, Kline LR, Whyte KF. A randomized crossover efficacy trial of oral CPAP (Oracle) compared with nasal CPAP in the management of obstructive sleep apnea. Sleep. 2003;26(6):721-6. Not COPD patients. [pmid: 14572126].
Andrus MR, Holloway KP, Clark DB. Use of beta-blockers in patients with COPD. Annals of Pharmacotherapy. 2004;38(1):142-5. Review article. [pmid: 14742808].
Annesi-Maesano I. Contribution of cohort studies on exacerbations and their management. Revue de Pneumologie Clinique. 2004;60(Spec no 1):S13-6. Review article. [pmid: 15192514].
Anonymous. Are Seretide and Symbicort useful in COPD? Drug & Therapeutics Bulletin. 2004; 42(3):18–21. Review article.
Anonymous. Arformoterol: (R,R)-eformoterol, (R,R)-formoterol, arformoterol tartrate, eformoterol-sepracor, formoterol-sepracor, R,R-eformoterol, R,R-formoterol. Drugs in R & D 2004; 5(1):25–7. Review article.
Anonymous. Reports from the Swedish council on technology assessment in health care (SBU). Treatment of asthma and COPD: an evidence-based review. International Journal of Technology Assessment in Health Care. 2002; 18(4):832–60. Review article.
Anonymous. Tiotropium for chronic obstructive pulmonary disease. Drug & Therapeutics Bulletin. 2003; 41(2):15–6. Review article.
Antonelli M, Conti G, Pelosi P, Gregoretti C, Pennisi MA, Costa R, et al. New treatment of acute hypoxemic respiratory failure: noninvasive pressure support ventilation delivered by helmet--a pilot controlled trial. Critical Care Medicine. 2002;30(3):602-8. Not COPD patients. [pmid: 11990923].
Antonucci R, Berton E, Huertas A, Laveneziana P, Palange P. Exercise physiology in COPD. Monaldi Archives for Chest Disease. 2003;59(2):134-9. Review article. [pmid: 14635502].
Appleton S, Poole P, Smith B, Veale A, Bara A. Long-acting beta2-agonists for chronic obstructive pulmonary disease patients with poorly reversible airflow limitation. Cochrane Database of Systematic Reviews. 2002; (3) CD001104. Review article.
Attarian HP, Sabri AN. When to suspect obstructive sleep apnea syndrome. Symptoms may be subtle, but treatment is straightforward. Postgraduate Medicine. 2002;111(3):70-6. Review article. [pmid: 11912998].
Ayas NT, Patel SR, Malhotra A, Schulzer M, Malhotra M, Jung D, et al. Auto-titrating versus standard continuous positive airway pressure for the treatment of obstructive sleep apnea: results of a meta-analysis. Sleep. 2004;27(2):249-53. Not COPD patients. [pmid: 15124718].
Ayres JG, Price MJ, Efthimiou J. Cost-effectiveness of fluticasone propionate in the treatment of chronic obstructive pulmonary disease: a double-blind randomized, placebo-controlled trial. Respiratory Medicine. 2003;97(3):212-20. Cost-effectiveness article. [pmid: 12645827].
Balter MS, La Forge J, Low DE, Mandell L, Grossman RF. Canadian Thoracic Society, et al. Canadian guidelines for the management of acute exacerbations of chronic bronchitis. Canadian Respiratory Journal. 2003;10(Suppl B):3B-32B. Review article.
Bandi VD, Munnur U, Matthay MA. Acute lung injury and acute respiratory distress syndrome in pregnancy. Critical Care Clinics. 2004;20(4):577-607. Review article. [pmid: 15388190].
Bao X, Nelesen RA, Loredo JS, Dimsdale JE, Ziegler MG. Blood pressure variability in obstructive sleep apnea: role of sympathetic nervous activity and effect of continuous positive airway pressure. Blood Pressure Monitoring. 2002;7(6):301-7. Not COPD patients. [pmid: 12488649].
Barnes M, Houston D, Worsnop CJ, Neill AM, Mykytyn IJ, Kay A, et al. A randomized controlled trial of continuous positive airway pressure in mild obstructive sleep apnea. American Journal of Respiratory & Critical Care Medicine. 2002;165(6):773-80. Not COPD patients. [pmid: 11897643].
Barnes PJ. Cytokine-directed therapies for the treatment of chronic airway diseases. Cytokine & Growth Factor Reviews. 2003;14(6):511-22. Review article. [pmid: 14563353].
Barnes PJ. Therapy of chronic obstructive pulmonary disease. Pharmacology & Therapeutics. 2003;97(1):87-94. Review article. [pmid: 12493536].
Barnes PJ, Ito K, Adcock IM. Corticosteroid resistance in chronic obstructive pulmonary disease: inactivation of histone deacetylase. Lancet. 2004;363(9410):731-3. Review article. [pmid: 15001333].
Bartels MN, Jelic S, Basner RC, Ngai P, Gonzalez JM, De Meersman RE. Supplemental oxygen increases arterial stiffness in chronic obstructive pulmonary disease. Respiratory Medicine. 2004;98(1):84-9. Study duration less than 3 months. [pmid: 14959818].
Beckett PA, Howarth PH. Pharmacotherapy and airway remodelling in asthma?. Thorax. 2003;58(2):163-74. Review article. [pmid: 12554904]. [pmcid: 1746582].
Beeh KM, Welte T, Buhl R. Anticholinergics in the treatment of chronic obstructive pulmonary disease. Respiration. 2002;69(4):372-9. Review article. [pmid: 12169757].
Beeh KM, Welte T, Buhl R. Tiotropium (Spiriva) - a long-acting inhaled anticholinergic for the treatment of chronic obstructive pulmonary disease (COPD). Pneumologie. 2003;57(9):519-25. Not English language. [pmid: 13680472].
Behnke M, Jorres RA, Kirsten D, Magnussen H. Clinical benefits of a combined hospital and home-based exercise programme over 18 months in patients with severe COPD. Monaldi Archives for Chest Disease. 2003;59(1):44-51. Less than 50 subjects per arm. [pmid: 14533282].
Beier J, Beeh KM, Troger K, Stenglein S, Brautigam M, Buhl R, et al. Onset of action of formoterol in patients with moderate to severe, partially reversible airflow obstruction assessed by bodyplethysmography. Pneumologie. 2002;56(9):535-41. Not English language. [pmid: 12215911].
Bellia V, Foresi A, Bianco S, Grassi V, Olivieri D, Bensi G, et al. Efficacy and safety of oxitropium bromide, theophylline and their combination in COPD patients: a double-blind, randomized, multicentre study (BREATH Trial). Respiratory Medicine. 2002;96(11):881-9. Study duration less than 3 months. [pmid: 12418585].
Bellone A, Spagnolatti L, Massobrio M, Bellei E, Vinciguerra R, Barbieri A, et al. Short-term effects of expiration under positive pressure in patients with acute exacerbation of chronic obstructive pulmonary disease and mild acidosis requiring non-invasive positive pressure ventilation. Intensive Care Medicine. 2002;28(5):581-5. Study duration less than 3 months. [pmid: 12029406].
Belvisi MG, Hele DJ. Soft steroids: a new approach to the treatment of inflammatory airways diseases. Pulmonary Pharmacology & Therapeutics. 2003;16(6):321-5. Review article. [pmid: 14580922].
Bennett WD. Effect of beta-adrenergic agonists on mucociliary clearance. Journal of Allergy & Clinical Immunology. 2002;110(6 Suppl):S291-7. Review article. [pmid: 12464938].
Berry JK, Baum C. Reversal of chronic obstructive pulmonary disease-associated weight loss: are there pharmacological treatment options?. Drugs. 2004;64(10):1041-52. Review article. [pmid: 15139785].
Berry RB, Parish JM, Hartse KM. The use of auto-titrating continuous positive airway pressure for treatment of adult obstructive sleep apnea. An American Academy of Sleep Medicine review. Sleep. 2002;25(2):148-73. Review article. [pmid: 11902425].
Bestall JC, Paul EA, Garrod R, Garnham R, Jones RW, Wedzicha AJ. Longitudinal trends in exercise capacity and health status after pulmonary rehabilitation in patients with COPD. Respiratory Medicine. 2003;97(2):173-80. Less than 50 subjects per arm. Study duration less than 3 months. Not COPD patients. [pmid: 12587969].
Bianchi L, Foglio K, Porta R, Baiardi R, Vitacca M, Ambrosino N. Lack of additional effect of adjunct of assisted ventilation to pulmonary rehabilitation in mild COPD patients. Respiratory Medicine. 2002;96(5):359-67. Study duration less than 3 months. Not COPD patients. [pmid: 12113387].
Birring SS, Berry M, Brightling CE, Pavord ID. Eosinophilic bronchitis: clinical features, management and pathogenesis. American Journal of Respiratory Medicine. 2003;2(2):169-73. Review article. [pmid: 14720015].
Blackler L, Mooney C, Jones C. Palliative care in the management of chronic obstructive pulmonary disease. British Journal of Nursing. 2004;13(9):518-21. Review article. [pmid: 15215727].
Blanchard AR. Treatment of COPD exacerbations. Pharmacologic options and modification of risk factors. Postgraduate Medicine. 2002; 111(6):65–8, 71–2, 75. Review article.
Bledsoe GH, Schexnayder SM. Pediatric rapid sequence intubation: a review. Pediatric Emergency Care. 004; 20(5):339–44. Review article.
Bonay M, Bancal C, Crestani B. Benefits and risks of inhaled corticosteroids in chronic obstructive pulmonary disease. Drug Safety. 2002;25(1):57-71. Review article. [pmid: 11820912].
Booth S, Wade R, Johnson M, Kite S, Swannick M, Anderson H, et al. The use of oxygen in the palliation of breathlessness. A report of the expert working group of the Scientific Committee of the Association of Palliative Medicine. Respiratory Medicine. 2004;98(1):66-77. Review article. [pmid: 14959816].
Borger P, Black JL, Roth M. Asthma and the CCAAT-enhancer binding proteins: a holistic view on airway inflammation and remodeling. Journal of Allergy & Clinical Immunology. 2002;110(6):841-6. Review article. [pmid: 12464948].
Bourbeau J, Nault D, Dang-Tan T. Self-management and behaviour modification in COPD. Patient Education & Counseling. 2004;52(3):271-7. Review article. [pmid: 14998597].
Bourgain JL. Preoxygenation and upper airway patency control. Annales Francaises d Anesthesie et de Reanimation. 2003;22(Suppl 1):41s-52s. Not English language. [pmid: 12943861].
Bourjeily-Habr G, Rochester CL, Palermo F, Snyder P, Mohsenin V. Randomised controlled trial of transcutaneous electrical muscle stimulation of the lower extremities in patients with chronic obstructive pulmonary disease. Thorax. 2002;57(12):1045-9. Study duration less than 3 months. [pmid: 12454299]. [pmcid: 1758803].
Bouros D, Kottakis J, Le Gros V, Overend T, Della Cioppa G, Siafakas N. Effects of formoterol and salmeterol on resting inspiratory capacity in COPD patients with poor FEV(1) reversibility. Current Medical Research & Opinion. 2004;20(5):581-6. Study duration less than 3 months. [pmid: 15140323].
Boyer A, Thiery G, Lasry S, Pigne E, Salah A, de Lassence A, et al. Long-term mechanical ventilation with hygroscopic heat and moisture exchangers used for 48 hours: a prospective clinical, hygrometric, and bacteriologic study. Critical Care Medicine. 2003;31(3):823-9. Study duration less than 3 months. [pmid: 12626991].
Bradley J, Moran F, Greenstone M. Physical training for bronchiectasis. Cochrane Database of Systematic Reviews 2002; (3)CD002166. Review article.
Brenes GA. Anxiety and chronic obstructive pulmonary disease: prevalence, impact, and treatment. Psychosomatic Medicine. 2003;65(6):963-70. Review article. [pmid: 14645773].
Brimacombe J, Keller C, Brimacombe L. A comparison of the laryngeal mask airway ProSeal and the laryngeal tube airway in paralyzed anesthetized adult patients undergoing pressure-controlled ventilation. Anesthesia & Analgesia. 2002;95(3):770-6. Not COPD patients. [pmid: 12198070].
Brochard L. Mechanical ventilation: invasive versus noninvasive European Respiratory Journal - Supplement. 2003; 4731s–37s. Review article.
Brochard L. Non-invasive ventilation for acute respiratory insufficiency. Revue du Praticien. 2003;53(9):980-4. Not English language. [pmid: 12816037].
Brochard L. Noninvasive ventilation for acute respiratory failure. JAMA. 2002;288(8):932-5. Review article. [pmid: 12190351].
Brochard L, Mancebo J, Elliott MW. Noninvasive ventilation for acute respiratory failure. European Respiratory Journal. 2002;19(4):712-21. Review article. [pmid: 11999003].
Brodsky JB. Bronchoscopic procedures for central airway obstruction. Journal of Cardiothoracic & Vascular Anesthesia. 2003;17(5):638-46. Review article. [pmid: 14579222].
Broeders ME, Molema J, Hop WC, Folgering HT. Inhalation profiles in asthmatics and COPD patients: reproducibility and effect of instruction. Journal of Aerosol Medicine. 2003;16(2):131-41. Study duration less than 3 months. [pmid: 12823907].
Brooks D, Sidani S, Graydon J, McBride S, Hall L, Weinacht K. Evaluating the effects of music on dyspnea during exercise in individuals with chronic obstructive pulmonary disease: a pilot study. Rehabilitation Nursing. 2003;28(6):192-6. Study duration less than 3 months. [pmid: 14649167].
Brug J, Schols A, Mesters I. Dietary change, nutrition education and chronic obstructive pulmonary disease. Patient Education & Counseling. 2004;52(3):249-57. Review article. [pmid: 14998594].
Brunner JX, Iotti GA. Adaptive Support Ventilation (ASV). Minerva Anestesiologica. 2002;68(5):365-8. Review article. [pmid: 12029247].
Buhl R. Budesonide/formoterol for the treatment of asthma. Expert Opinion on Pharmacotherapy. 2003;4(8):1393-406. Review article. [pmid: 12877646].
Burge PS, Calverley PM, Jones PW, Spencer S, Anderson JA. Prednisolone response in patients with chronic obstructive pulmonary disease: results from the ISOLDE study. Thorax. 2003;58(8):654-8. Duplicate publication. [pmid: 12885977]. [pmcid: 1746769].
Burns KE, Adhikari NK, Meade MO. Noninvasive positive pressure ventilation as a weaning strategy for intubated adults with respiratory failure. Cochrane Database of Systematic Reviews. 2003; (4)CD004127. Review article.
Calverley P. Are inhaled corticosteroids systemic therapy for chronic obstructive pulmonary disease?. American Journal of Respiratory & Critical Care Medicine. 2004;170(7):721-2. Review article. [pmid: 15447948].
Calverley PM. Respiratory failure in chronic obstructive pulmonary disease. European Respiratory Journal - Supplement. 2003;47:26s-30s. Review article.
Calverley PM, Lee A, Towse L, van Noord J, Witek TJ, Kelsen S. Effect of tiotropium bromide on circadian variation in airflow limitation in chronic obstructive pulmonary disease. Thorax. 2003;58(10):855-60. Study duration less than 3 months. [pmid: 14514937]. [pmcid: 1746483].
Calverley PM, Spencer S, Willits L, Burge PS, Jones PW. ISOLDE Study Group. Withdrawal from treatment as an outcome in the ISOLDE study of COPD. Chest. 2003;124(4):1350-6. Treatment withdrawal report. [pmid: 14555565].
Camargo CA Jr, Spooner CH, Rowe BH. Continuous versus intermittent beta-agonists in the treatment of acute asthma. Cochrane Database of Systematic Reviews. 2003; (4)CD001115. Review article.
Caramori G, Adcock I. Pharmacology of airway inflammation in asthma and COPD. Pulmonary Pharmacology & Therapeutics. 2003;16(5):247-77. Review article. [pmid: 12877818].
Carone M, Bertolotti G, Cerveri I, De Benedetto F, Fogliani V, Nardini S, et al. EDU-CARE, a randomised, multicentre, parallel group study on education and quality of life in COPD. Monaldi Archives for Chest Disease. 2002;57(1):25-9. No clinical outcomes. [pmid: 12174697].
Cazzola M, Califano C, Di Perna F, D'Amato M, Terzano C, Matera MG, et al. Acute effects of higher than customary doses of salmeterol and salbutamol in patients with acute exacerbation of COPD. Respiratory Medicine. 2002;96(10):790-5. Less than 50 subjects per arm. [pmid: 12412978].
Cazzola M, D'Amato M, Califano C, Di Perna F, Calderaro E, Matera MG, et al. Formoterol as dry powder oral inhalation compared with salbutamol metered-dose inhaler in acute exacerbations of chronic obstructive pulmonary disease. Clinical Therapeutics. 2002;24(4):595-604. Less than 50 subjects per arm. [pmid: 12017404].
Cazzola M, Dahl R. Inhaled combination therapy with long-acting beta 2-agonists and corticosteroids in stable COPD. Chest. 2004;126(1):220-37. Review article. [pmid: 15249466].
Cazzola M, Di Marco F, Santus P, Boveri B, Verga M, Matera MG, et al. The pharmacodynamic effects of single inhaled doses of formoterol, tiotropium and their combination in patients with COPD. Pulmonary Pharmacology & Therapeutics. 2004;17(1):35-9. Less than 50 subjects per arm. Study duration less than 3 months. [pmid: 14643169].
Cazzola M, Grella E, Matera MG, Mazzarella G, Marsico SA. Onset of action following formoterol Turbuhaler and salbutamol pMDI in reversible chronic airway obstruction. Pulmonary Pharmacology & Therapeutics. 2002;15(2):97-102. Less than 50 subjects per arm. [pmid: 12090782].
Cazzola M, Matera MG. Long-acting beta(2) agonists as potential option in the treatment of acute exacerbations of COPD. Pulmonary Pharmacology & Therapeutics. 2003;16(4):197-201. Review article. [pmid: 12850121].
Cazzola M, Matera MG, D'Amato M, Califano C, Sanduzzi A, Vatrella A, et al. Bronchodilator response to formoterol Turbuhaler in patients with COPD under regular treatment with formoterol Turbuhaler. Pulmonary Pharmacology & Therapeutics. 2003;16(2):105-9. Less than 50 subjects per arm. [pmid: 12670779].
Cazzola M, Noschese P, Centanni S, Santus P, Di Marco F, Spicuzza L, et al. Salmeterol/fluticasone propionate in a Single Inhaler Device versus theophylline+fluticasone propionate in patients with COPD. Pulmonary Pharmacology & Therapeutics. 2004;17(3):141-5. Less than 50 subjects per arm. [pmid: 15123223].
Cazzola M, Santus P, Castagna F, Di Marco F, Terzano C, Matera MG, et al. Addition of an extra dose of salmeterol Diskus to conventional dose of salmeterol Diskus in patients with COPD. Respiratory Medicine. 2002;96(6):439-43. Less than 50 subjects per arm. [pmid: 12117044].
Cazzola M, Santus P, Di Marco F, Boveri B, Castagna F, Carlucci P, et al. Bronchodilator effect of an inhaled combination therapy with salmeterol + fluticasone and formoterol + budesonide in patients with COPD. Respiratory Medicine. 2003;97(5):453-7. Less than 50 subjects per arm. [pmid: 12735659].
Cazzola M, Santus P, Di Marco F, Carlucci P, Mondoni M, Matera MG, Ugo Di Maria G. Onset of action of formoterol/budesonide in single inhaler vs. formoterol in patients with COPD. Pulmonary Pharmacology & Therapeutics. 2004;17(3):121-5. Less than 50 subjects per arm. [pmid: 15123220].
Cazzola M, Santus P, Matera MG, Carlucci P, Belloli E, Di Marco F, et al. A single high dose of formoterol is as effective as the same dose administered in a cumulative manner in patients with acute exacerbation of COPD. Respiratory Medicine. 2003;97(5):458-62. Study duration less than 3 months. [pmid: 12735660].
Cegla UH. Pressure and inspiratory flow characteristics of dry powder inhalers. Respiratory Medicine. 2004;98(Suppl A):S22-8. Less than 50 subjects per arm. [pmid: 15139565].
Cegla UH, Jost HJ, Harten A, Weber T, Wissmann S. Course of Severe COPD with and without Physiotherapy with the RC-Cornet(R). Pneumologie. 2002;56(7):418-24. Not English language. [pmid: 12140795].
Celli B, ZuWallack R, Wang S, Kesten S. Improvement in resting inspiratory capacity and hyperinflation with tiotropium in COPD patients with increased static lung volumes. Chest. 2003;124(5):1743-8. Study duration less than 3 months. [pmid: 14605043].
Celli BR. Chronic respiratory failure after lung resection: the role of pulmonary rehabilitation. Thoracic Surgery Clinics. 2004;14(3):417-28. Review article. [pmid: 15382772].
Celli BR. Pulmonary rehabilitation. Israel Medical Association Journal: Imaj. 2003;5(6):443-8. Review article.
Centanni S, Santus P, Casanova F, Carlucci P, Boveri B, Castagna F, et al. Bronchodilating effect of oxitropium bromide in heart disease patients with exacerbations of COPD: double-blind, randomized, controlled study. Respiratory Medicine. 2002;96(3):137-41. Study duration less than 3 months. [pmid: 11905547].
Ceriana P, Navalesi P, Rampulla C, Prinianakis G, Nava S. Use of bronchodilators during non-invasive mechanical ventilation. Monaldi Archives for Chest Disease. 2003;59(2):123-7. Review article. [pmid: 14635500].
Cetinkaya F, Tufekci BS, Kutluk G. A comparison of nebulized budesonide, and intramuscular, and oral dexamethasone for treatment of croup. International Journal of Pediatric Otorhinolaryngology. 2004;68(4):453-6. Not adult patients. [pmid: 15013613].
Chabot F. Health status in patients with chronic obstructive pulmonary disease. Revue du Praticien. 2004;54(13):1451-4. Review article. [pmid: 15497800].
Chapman KR. Seretide for obstructive lung disease. Expert Opinion on Pharmacotherapy. 2002;3(3):341-50. Review article. [pmid: 11866683].
Chasens ER, Weaver TE, Umlauf MG. Insulin resistance and obstructive sleep apnea: is increased sympathetic stimulation the link?. Biological Research for Nursing. 2003;5(2):87-96. Review article. [pmid: 14531213].
Chavannes N, Vollenberg JJ, van Schayck CP, Wouters EF. Effects of physical activity in mild to moderate COPD: a systematic review. British Journal of General Practice. 2002;52(480):574-8. Review article. [pmid: 12120732]. [pmcid: 1314362].
Cheer SM, Scott LJ. Formoterol: a review of its use in chronic obstructive pulmonary disease. American Journal of Respiratory Medicine. 2002;1(4):285-300. Review article. [pmid: 14720051].
Chetta A, Marangio E, Olivieri D. Inhaled steroids and airway remodelling in asthma. Acta Bio-Medica de l Ateneo Parmense. 2003;74(3):121-5. Review article.
Chiang LL, Hung TC, Ho SC, Lin HC, Yu CT, Wang CH, et al. Respiratory response to carbon dioxide stimulation during low flow supplemental oxygen therapy in chronic obstructive pulmonary disease. Journal of the Formosan Medical Association. 2002;101(9):607-15. Less than 50 subjects per arm. [pmid: 12645187].
Chiang LL, Liu CY, Ho SC, Sheng TF, Yu CT, Lin HC, et al. Efficacy of nocturnal nasal positive pressure ventilation in hypercapnic patients with severe obstructive lung diseases. Chang Gung Medical Journal. 2004;27(2):98-106. Less than 50 subjects per arm. Study duration less than 3 months. [pmid: 15095954].
Chitkara RK, Sarinas PS. Recent advances in diagnosis and management of chronic bronchitis and emphysema. Current Opinion in Pulmonary Medicine. 2002;8(2):126-36. Review article. [pmid: 11845008].
Chojnowski D. “GOLD” standards for acute exacerbation in COPD. Nurse Practitioner. 2003;28(5):26-35. Review article. [pmid: 12792266].
Chorostowska-Wynimko J. Mechanism of B2-agonists action and safety aspects. Polski Merkuriusz Lekarski. 2002;12(72):441-4. Not English language. [pmid: 12362656].
Christopher KL. Transtracheal oxygen catheters. Clinics in Chest Medicine. 2003;24(3):489-510. Review article. [pmid: 14535222].
Chuchalin AG, Kremer HJ, Metzenauer P, O'Keefe E, Hermann R. Clinical equivalence trial on budesonide delivered either by the Novolizer multidose dry powder inhaler or the Turbuhaler in asthmatic patients. Respiration. 2002;69(6):502-8. Not COPD patients. [pmid: 12457002].
Chyrek-Borowska S, Rogalewska AM. New beta2-agonists in asthma and COPD. Pneumonologia i Alergologia Polska. 2002;70(Suppl 1):58-61. Not English language. [pmid: 12580164].
Ciappi G, Corbo G, Valente S. Functional diagnosis of chronic obstructive pulmonary disease. Annali Dell'Istituto Superiore di Sanita. 2003;39(4):529-47. Review article.
Cirio S, Piaggi GC, De Mattia E, Nava S. Muscle retraining in ICU patients. Monaldi Archives for Chest Disease. 2003;59(4):300-3. Review article. [pmid: 15148840].
Clini E, Bianchi L, Foglio K, Vitacca M, Ambrosino N. Exhaled nitric oxide and exercise tolerance in severe COPD patients. Respiratory Medicine. 2002;96(5):312-6. Study duration less than 3 months. [pmid: 12113380].
Clini E, Costi S, Lodi S, Rossi G. Non-pharmacological treatment for chronic obstructive pulmonary disease. Medical Science Monitor. 2003;9(12):RA300-5. Review article. [pmid: 14646985].
Clini E, Sturani C, Rossi A, Viaggi S, Corrado A, Donner CF, et al. The Italian multicentre study on noninvasive ventilation in chronic obstructive pulmonary disease patients. European Respiratory Journal. 2002;20(3):529-38. Less than 50 subjects per arm. [pmid: 12358325].
Collins EG, Fehr L, Bammert C, O'Connell S, Laghi F, Hanson K, et al. Effect of ventilation-feedback training on endurance and perceived breathlessness during constant work-rate leg-cycle exercise in patients with COPD. Journal of Rehabilitation Research & Development. 2003;40(5 Suppl 2):35-44. Less than 50 subjects per arm. Study duration less than 3 months. [pmid: 15074452].
Conti G, Antonelli M, Navalesi P, Rocco M, Bufi M, Spadetta G, et al. Noninvasive vs. conventional mechanical ventilation in patients with chronic obstructive pulmonary disease after failure of medical treatment in the ward: a randomized trial. Intensive Care Medicine. 2002;28(12):1701-7. Less than 50 subjects per arm. [pmid: 12447511].
Conti G, Costa R, Craba A, Festa V, Catarci S. Non-invasive ventilation in COPD patients. Minerva Anestesiologica. 2004;70(4):145-50. Review article. [pmid: 15173688].
Corrado A, Ginanni R, Villella G, Gorini M, Augustynen A, Tozzi D, et al. Iron lung versus conventional mechanical ventilation in acute exacerbation of COPD. European Respiratory Journal. 2004;23(3):419-24. Less than 50 subjects per arm. [pmid: 15065832].
Corrado A, Gorini M. Long-term negative pressure ventilation. Respiratory Care Clinics of North America. 2002;8(4):545-57. Review article. [pmid: 12602414].
Corsico A, Fulgoni P, Beccaria M, Zoia MC, Barisione G, Pellegrino R, et al. Effects of exercise and beta 2-agonists on lung function in chronic obstructive pulmonary disease. Journal of Applied Physiology. 2002;93(6):2053-8. Less than 50 subjects per arm. [pmid: 12391117].
Covey MK, Larson JL. Exercise and COPD. AJN, American Journal of Nursing. 2004;104(5):40-3. Review article.
Crawford Shearer NB, Reed PG. Empowerment: reformulation of a non-Rogerian concept. Nursing Science Quarterly. 2004;17(3):253-9. Review article. [pmid: 15200729].
Creutzberg EC, Wouters EF, Mostert R, Pluymers RJ, Schols AM. A role for anabolic steroids in the rehabilitation of patients with COPD? A double-blind, placebo-controlled, randomized trial. Chest. 2003;124(5):1733-42. Study duration less than 3 months. [pmid: 14605042].
Crocker I, Lawson N, Fletcher J. Effect of pregnancy and obstructive jaundice on inflammatory diseases: the work of P S Hench revisited. Annals of the Rheumatic Diseases. 2002;61(4):307-10. Review article. [pmid: 11874831]. [pmcid: 1754059].
Cros AM, Herve Y. Acute laryngeal dyspnea. Revue du Praticien. 2003;53(9):985-8. Not English language. [pmid: 12816038].
Cuvelier A, Benhamou D, Muir JF. Non-invasive ventilation of elderly patients in the intensive care unit. Revue des Maladies Respiratoires. 2003;20(3 Pt 1):399-410. Not English language. [pmid: 12910114].
Cuvelier A, Muir JF. Instrumental treatment of chronic obstructive bronchopneumonia. The place of non-invasive ventilation. Presse Medicale. 2003;32(27):1283-90. Not English language.
Cuvelier A, Nuir JF, Chakroun N, Aboab J, Onea G, Benhamou D. Refillable oxygen cylinders may be an alternative for ambulatory oxygen therapy in COPD. Chest. 2002;122(2):451-6. Less than 50 subjects per arm. [pmid: 12171816].
Dahl R, Backer V, Ollgaard B, Gerken F, Kesten S. Assessment of patient performance of the HandiHaler compared with the metered dose inhaler four weeks after instruction. Respiratory Medicine. 2003;97(10):1126-33. Study duration less than 3 months. [pmid: 14561020].
Dart RA, Gollub S, Lazar J, Nair C, Schroeder D, Woolf SH. Treatment of systemic hypertension in patients with pulmonary disease: COPD and asthma. Chest. 2003;123(1):222-43. Review article. [pmid: 12527626].
Datta D, Vitale A, Lahiri B, ZuWallack R. An evaluation of nebulized levalbuterol in stable COPD. Chest. 2003;124(3):844-9. Less than 50 subjects per arm. [pmid: 12970007].
Davey MJ. Understanding obstructive sleep apnoea. Nursing Times. 2003;99(22):26-7. Review article. [pmid: 12808745].
Davidson AC. The pulmonary physician in critical care. 11: critical care management of respiratory failure resulting from COPD. Thorax. 2002;57(12):1079-84. Review article. [pmid: 12454305]. [pmcid: 1758799].
Davies MW, Davis PG. Nebulized racemic epinephrine for extubation of newborn infants. Cochrane Database of Systematic Reviews 2002; (1)CD000506. Review article.
De Boer WI. Cytokines and therapy in COPD: a promising combination?. Chest. 2002;121(5 Suppl):209S-218S. Review article. [pmid: 12010854].
de Chazal I, Hubmayr RD. Novel aspects of pulmonary mechanics in intensive care. British Journal of Anaesthesia. 2003;91(1):81-91. Review article. [pmid: 12821568].
de Godoy DV, de Godoy RF. A randomized controlled trial of the effect of psychotherapy on anxiety and depression in chronic obstructive pulmonary disease. Archives of Physical Medicine & Rehabilitation. 2003;84(8):1154-7. Less than 50 subjects per arm. [pmid: 12917854].
Dekhuijzen PN. Inhaled corticosteroids for COPD. Nederlands Tijdschrift voor Geneeskunde. 2003;147(29):1398-404. Not English language. [pmid: 12894463].
DeKorte CJ. Current and emerging therapies for the management of chronic inflammation in asthma. American Journal of Health-System Pharmacy. 2003;60(19):1949-59. Review article. [pmid: 14531240].
DeMolles DA, Sparrow D, Gottlieb DJ, Friedman R. A pilot trial of a telecommunications system in sleep apnea management. Medical Care. 2004;42(8):764-9. Not COPD patients. [pmid: 15258478].
Devillier P. Physiopathology of COPD: choosing the right therapeutic targets. Revue de Pneumologie Clinique. 2003;59(2 Pt 2):S6-10. Not English language. [pmid: 12966779].
Dhein Y, Munks-Lederer C, Worth H. Evaluation of a structured education programme for patients with COPD under outpatient conditions-- a pilot study. Pneumologie. 2003;57(10):591-7. Not English language. [pmid: 14569530].
Di Marco F, Milic-Emili J, Boveri B, Carlucci P, Santus P, Casanova F, et al. Effect of inhaled bronchodilators on inspiratory capacity and dyspnoea at rest in COPD. European Respiratory Journal. 2003;21(1):86-94. Less than 50 subjects per arm. [pmid: 12570114].
Di Maria G, Spicuzza L, Mazzarella G. Future treatment of chronic obstructive pulmonary disease. Monaldi Archives for Chest Disease. 2002;57(34):200-5. Review article. [pmid: 12619385].
Diaz O, Begin P, Torrealba B, Jover E, Lisboa C. Effects of noninvasive ventilation on lung hyperinflation in stable hypercapnic COPD. European Respiratory Journal. 2002;20(6):1490-8. Less than 50 subjects per arm. [pmid: 12503709].
Diehl JL, Mercat A, Guerot E, Aissa F, Teboul JL, Richard C, et al. Helium/oxygen mixture reduces the work of breathing at the end of the weaning process in patients with severe chronic obstructive pulmonary disease. Critical Care Medicine. 2003;31(5):1415-20. Less than 50 subjects per arm. [pmid: 12771612].
Dikensoy O, Ikidag B, Filiz A, Bayram N. Comparison of non-invasive ventilation and standard medical therapy in acute hypercapnic respiratory failure: a randomised controlled study at a tertiary health centre in SE Turkey. International Journal of Clinical Practice. 2002;56(2):85-8. Not COPD patients. [pmid: 11926711].
Doherty DE. Early detection and management of COPD. What you can do to reduce the impact of this disabling disease. Postgraduate Medicine. 2002; 111(6):41–4, 49–50, 53 passim. Review article.
Donahue M. “Spare the cough, spoil the airway:” back to the basics in airway clearance. Pediatric Nursing. 2002;28(2):107-11. Review article. [pmid: 11962175].
Donohue JF. Therapeutic responses in asthma and COPD. Bronchodilators. Chest. 2004;126(2 Suppl):125S-137S. Review article. [pmid: 15302773].
Donohue JF, Kalberg C, Emmett A, Merchant K, Knobil K. A short-term comparison of fluticasone propionate/ salmeterol with ipratropium bromide/albuterol for the treatment of COPD. Treatments in Respiratory Medicine. 2004;3(3):173-81. Study duration less than 3 months. [pmid: 15219176].
Donohue JF, Menjoge S, Kesten S. Tolerance to bronchodilating effects of salmeterol in COPD. Respiratory Medicine. 2003;97(9):1014-20. No clinical outcomes. [pmid: 14509555].
Dougherty JA, Didur BL, Aboussouan LS. Long-acting inhaled beta 2-agonists for stable COPD. Annals of Pharmacotherapy. 2003;37(9):1247-55. Review article. [pmid: 12921509].
Douma WR, Kerstjens HA, de Gooijer A, Overbeek SE, Koeter GH, Postma DS, et al. Initial improvements in lung function and bronchial hyperresponsiveness are maintained during 5 years of treatment with inhaled beclomethasone dipropionate and terbutaline. Chest. 2002;121(1):151-7. Not COPD patients. [pmid: 11796444].
Drazen JM. Leukotrienes in asthma. Advances in Experimental Medicine & Biology. 2003;525:1-5. Review article. [pmid: 12751726].
Drummond GB, Stedul K, Kingshott R, Rees K, Nimmo AF, Wraith P, et al. Automatic CPAP compared with conventional treatment for episodic hypoxemia and sleep disturbance after major abdominal surgery. Anesthesiology. 2002;96(4):817-26. Not COPD patients. [pmid: 11964587].
Dubin MG, Senior BA. The limitations of isolated palatal surgery for patients with obstructive sleep apnea. Otolaryngologic Clinics of North America. 2003;36(3):511-7. Review article. [pmid: 12956098].
Duckett K. The right assessments = the right PPS payment. Home Healthcare Nurse. 2004;22(5):312-6. Review article. [pmid: 15131419].
Durlach J, Pages N, Bac P, Bara M, Guiet-Bara A. Beta-2 mimetics and magnesium: true or false friends?. Magnesium Research. 2003;16(3):218-33. Review article. [pmid: 14596327].
Dziedziczko A, Palgan K. Role of fibroblasts in bronchial asthma. Polski Merkuriusz Lekarski. 2003;14(79):59-61. Not English language. [pmid: 12712832].
Eaton T, Garrett JE, Young P, Fergusson W, Kolbe J, Rudkin S, et al. Ambulatory oxygen improves quality of life of COPD patients: a randomised controlled study. European Respiratory Journal. 2002;20(2):306-12. Less than 50 subjects per arm. [pmid: 12212960].
Ecklund MM, Kurlak SA. Caring for the bariatric patient with obstructive sleep apnea. Critical Care Nursing Clinics of North America. 2004;16(3):311-7. Review article. [pmid: 15358380].
Eichenhorn MS, Wise RA, Madhok TC, Gerald LB, Bailey WC, Tashkin DP, et al. Lack of long-term adverse adrenal effects from inhaled triamcinolone: Lung Health Study II. Chest. 2003;124(1):57-62. No clinical outcomes. [pmid: 12853502].
Elliott MW, Confalonieri M, Nava S. Where to perform noninvasive ventilation?. European Respiratory Journal. 2002;19(6):1159-66. Review article. [pmid: 12108872].
Emtner M, Porszasz J, Burns M, Somfay A, Casaburi R. Benefits of supplemental oxygen in exercise training in nonhypoxemic chronic obstructive pulmonary disease patients. American Journal of Respiratory & Critical Care Medicine. 2003;168(9):1034-42. Less than 50 subjects per arm. [pmid: 12869359].
Enright PL, Kaminsky DA. Strategies for screening for chronic obstructive pulmonary disease. Respiratory Care. 2003;48(12):1194-201. Review article. [pmid: 14651760].
Epstein SK. Decision to extubate. Intensive Care Medicine. 2002;28(5):535-46. Review article. [pmid: 12029399].
Ericsson CD. Travellers with pre-existing medical conditions. International Journal of Antimicrobial Agents. 2003;21(2):181-8. Review article. [pmid: 12615384].
Erler T, Paditz E. Obstructive sleep apnea syndrome in children: a state-of-the-art review. Treatments in Respiratory Medicine. 2004;3(2):107-22. Review article. [pmid: 15182212].
Esteban A, Frutos-Vivar F, Ferguson ND, Arabi Y, Apezteguia C, Gonzalez M, et al. Noninvasive positive-pressure ventilation for respiratory failure after extubation. New England Journal of Medicine. 2004;350(24):2452-60. Study duration less than 3 months. [pmid: 15190137].
Ewig S, Torres A. Severe community-acquired pneumonia. Current Opinion in Critical Care. 2002;8(5):453-60. Review article. [pmid: 12357115].
Farquhar D. Reducing antibiotic use for acute bronchitis by giving patients written information. CMAJ Canadian Medical Association Journal. 2002;166(6):776. Not COPD patients.
Faulkner MA, Hilleman DE. The economic impact of chronic obstructive pulmonary disease. Expert Opinion on Pharmacotherapy. 2002;3(3):219-28. Review article. [pmid: 11866672].
Faulkner MA, Hilleman DE. Pharmacologic treatment of chronic obstructive pulmonary disease: past, present, and future. Pharmacotherapy. 2003;23(10):1300-15. Review article. [pmid: 14594347].
Felez MA. Function of respiratory muscles in sleep apnea-hypopnea syndrome. Archivos de Bronconeumologia. 2002;38(6):278-80. Not English language. [pmid: 12106554].
Fenton C, Keating GM, Plosker GL. Novolizer: a multidose dry powder inhaler. Drugs. 2003;63(22):2437-45. Not adult patients. [pmid: 14609355].
Ferguson GT, Funck-Brentano C, Fischer T, Darken P, Reisner C. Cardiovascular safety of salmeterol in COPD. Chest. 2003;123(6):1817-24. Review article. [pmid: 12796155].
Ferini-Strambi L, Fantini ML, Castronovo C. Epidemiology of obstructive sleep apnea syndrome. Minerva Medica. 2004;95(3):187-202. Review article. [pmid: 15289748].
Fernandez Guerra J, Lopez-Campos Bodineau JL, Perea-Milla Lopez E, Pons Pellicer J, Rivera Irigoin R, Moreno Arrastio LF. Non invasive ventilation for acute exacerbation of chronic obstructive pulmonary disease: a meta-analysis. Medicina Clinica. 2003;120(8):281-6. Not English language. [pmid: 12636896].
Ferrer M, Bernadich O, Nava S, Torres A. Noninvasive ventilation after intubation and mechanical ventilation. European Respiratory Journal. 2002;19(5):959-65. Review article. [pmid: 12030739].
Ficker JH, Clarenbach CF, Neukirchner C, Fuchs FS, Wiest GH, Schahin SP, et al. Auto-CPAP therapy based on the forced oscillation technique. Biomedizinische Technik. 2003;48(3):68-72. Not COPD patients. [pmid: 12701337].
Fihn SD, McDonell MB, Diehr P, Anderson SM, Bradley KA, Au DH, et al. Effects of sustained audit/feedback on self-reported health status of primary care patients. American Journal of Medicine. 2004;116(4):241-8. No intervention. [pmid: 14969652].
Fink JB. Positive pressure techniques for airway clearance. Respiratory Care. 2002;47(7):786-96. Review article. [pmid: 12088549].
Fiorenza D, Vitacca M, Clini E. Hospital monitoring, setting and training for home non invasive ventilation. Monaldi Archives for Chest Disease. 2003;59(2):119-22. Review article. [pmid: 14635499].
Fishman A, Martinez F, Naunheim K, Piantadosi S, Wise R, Ries A, et al. A randomized trial comparing lung-volume-reduction surgery with medical therapy for severe emphysema. New England Journal of Medicine. 2003;348(21):2059-73. Not COPD patients. [pmid: 12759479].
Fitzpatrick MF, Alloway CE, Wakeford TM, MacLean AW, Munt PW, Day AG. Can patients with obstructive sleep apnea titrate their own continuous positive airway pressure?. American Journal of Respiratory & Critical Care Medicine. 2003;167(5):716-22. Not COPD patients. [pmid: 12598214].
Flemons WW. Clinical practice. Obstructive sleep apnea. New England Journal of Medicine. 2002;347(7):498-504. Review article. [pmid: 12181405].
Fraser J, Walls M, McGuire W. Respiratory complications of preterm birth. BMJ. 2004;329(7472):962-5. Review article. [pmid: 15499114]. [pmcid: 524111].
French J. Developing effective services for people with COPD. Nursing Times. 2003;99(20):48. Review article. [pmid: 12800646].
Friedman M, Della Cioppa G, Kottakis J. Formoterol therapy for chronic obstructive pulmonary disease: a review of the literature. Pharmacotherapy. 2002;22(9):1129-39. Review article. [pmid: 12222549].
Friedman M, Menjoge SS, Anton SF, Kesten S. Healthcare costs with tiotropium plus usual care versus usual care alone following 1 year of treatment in patients with chronic obstructive pulmonary disorder (COPD). Pharmacoeconomics. 2004;22(11):741-9. Cost-effectiveness study. [pmid: 15250751].
Fujisawa T, Aoshima M, Uchiyama N, Satoh T, Ohmagari N, Chonabayashi N, et al. A case of mediastinal metastasis of renal small cell carcinoma, performing CHOP therapy for an acute respiratory failure by the air way obstruction under the mechanical ventilation. Nihon Kokyuki Gakkai Zasshi. 2003;41(7):440-6. Not English language. [pmid: 12931670].
Fukkuda T. Recent study on pathogenesis of bronchial asthma and the therapeutic strategy. Nippon Naika Gakkai Zasshi - Journal of Japanese Society of Internal Medicine. 2004;93(3):532-7. Review article.
Fukuchi Y. Physiopathology of chronic obstructive lung disease and progress in its therapy. Nippon Naika Gakkai Zasshi - Journal of Japanese Society of Internal Medicine. 2002;91(Suppl):10-4. Not English language.
Gainnier M, Arnal JM, Gerbeaux P, Donati S, Papazian L, Sainty JM. Helium-oxygen reduces work of breathing in mechanically ventilated patients with chronic obstructive pulmonary disease. Intensive Care Medicine. 2003;29(10):1666-70. Less than 50 subjects per arm. [pmid: 12897990].
Gali B, Goyal DG. Positive pressure mechanical ventilation. Emergency Medicine Clinics of North America. 2003;21(2):453-73. Review article. [pmid: 12793624].
Gallefoss F. The effects of patient education in COPD in a 1-year follow-up randomised, controlled trial. Patient Education & Counseling. 2004;52(3):259-66. Less than 50 subjects per arm. [pmid: 14998595].
Gallefoss F, Bakke PS. Cost-benefit and cost-effectiveness analysis of self-management in patients with COPD--a 1-year follow-up randomized, controlled trial. Respiratory Medicine. 2002;96(6):424-31. Less than 50 subjects per arm. [pmid: 12117042].
Gay PC, Herold DL, Olson EJ. A randomized, double-blind clinical trial comparing continuous positive airway pressure with a novel bilevel pressure system for treatment of obstructive sleep apnea syndrome. Sleep. 2003;26(7):864-9. Not COPD patients. [pmid: 14655921].
George DL. Chronic obstructive pulmonary disease treatment options. Journal of Managed Care Pharmacy. 2004;10(4 Suppl):S11-6. Review article. [pmid: 15253682].
Gessner C, Stenglein S, Brautigam M, Muller A, Schauer J. Miflonide/Foradil via Aerolizer compared with other anti-inflammatory and anti-obstructive therapeutic regimens. Pneumologie. 2003;57(3):137-43. Not English language. [pmid: 12632292].
Gillissen A, Buhl R, Kardos P, Kenn K, Matthys H, Pfister R, et al. Management of acute exacerbation of chronic obstructive pulmonary disease (COPD). Deutsche Medizinische Wochenschrift. 2003;128(33):1721-7. Not English language. [pmid: 12920671].
Gillissen A, Lewis M, Worth H. Inhaled steroids and COPD mortality: limitation of epidemiological analysis of databases. Pneumologie. 2003;57(11):639-42. Not English language. [pmid: 14618505].
Gilon Y, Raskin S, Heymans O, Poirrier R. The role of maxillofacial surgery in obstructive sleep hypopnea and apnea syndrome. Revue Belge de Medecine Dentaire. 2002;57(2):93-110. Not English language. [pmid: 12649980].
Gizycki MJ, Hattotuwa KL, Barnes N, Jeffery PK. Effects of fluticasone propionate on inflammatory cells in COPD: an ultrastructural examination of endobronchial biopsy tissue. Thorax. 2002;57(9):799-803. Less than 50 subjects per arm. [pmid: 12200525]. [pmcid: 1746422].
Goldkorn A, Diotto P, Burgess C, Weatherall M, Holt S, Beasley R, et al. The pulmonary and extra-pulmonary effects of high-dose formoterol in COPD: a comparison with salbutamol. Respirology. 2004;9(1):102-8. Less than 50 subjects per arm. [pmid: 14982610].
Goldstein MF, Chervinsky P. Efficacy and safety of doxofylline compared to theophylline in chronic reversible asthma -- a double-blind randomized placebo-controlled multicentre clinical trial. Medical Science Monitor. 2002;8(4):CR297-304. Not COPD patients. [pmid: 11951074].
Gomersall CD, Joynt GM, Freebairn RC, Lai CK, Oh TE. Oxygen therapy for hypercapnic patients with chronic obstructive pulmonary disease and acute respiratory failure: a randomized, controlled pilot study. Critical Care Medicine. 2002;30(1):113-6. Less than 50 subjects per arm. [pmid: 11905405].
Gonzalez MM, Parreira VF, Rodenstein DO. Non-invasive ventilation and sleep. Sleep Medicine Reviews. 2002;6(1):29-44. Review article. [pmid: 12531140].
Gonzales R, Sauaia A, Corbett KK, Maselli JH, Erbacher K, Leeman-Castillo BA, et al. Antibiotic treatment of acute respiratory tract infections in the elderly: effect of a multidimensional educational intervention. Journal of the American Geriatrics Society. 2004;52(1):39-45. Not COPD patients. [pmid: 14687313].
Gorecka D. Education program in COPD. Pneumonologia i Alergologia Polska. 2002;70(Suppl 1):91-4. Not English language. [pmid: 12518648].
Gosselink R. Controlled breathing and dyspnea in patients with chronic obstructive pulmonary disease (COPD). Journal of Rehabilitation Research & Development. 2003;40(5 Suppl 2):25-33. Review article. [pmid: 15074451].
Green BT, Broughton WA, O'Connor JB. Marked improvement in nocturnal gastroesophageal reflux in a large cohort of patients with obstructive sleep apnea treated with continuous positive airway pressure. Archives of Internal Medicine. 2003;163(1):41-5. Not COPD patients. [pmid: 12523915].
Groeben H. Strategies in the patient with compromised respiratory function. Best Practice & Research. Clinical Anaesthesiology. 2004;18(4):579-94. Review article. [pmid: 15460547].
Guerin C, Lemasson S, La Cara MF, Fournier G. Physiological effects of constant versus decelerating inflation flow in patients with chronic obstructive pulmonary disease under controlled mechanical ventilation. Intensive Care Medicine. 2002;28(2):164-9. Less than 50 subjects per arm. [pmid: 11907659].
Guilleminault C, Abad VC. Obstructive sleep apnea syndromes. Medical Clinics of North America. 2004;88(3):611-30. Review article. [pmid: 15087207].
Gupta RK, Chhabra SK. An evaluation of salmeterol in the treatment of chronic obstructive pulmonary diseases. Indian Journal of Chest Diseases & Allied Sciences. 2002;44(3):165-72. Less than 50 subjects per arm. [pmid: 12206475].
Hackam DG. Treatment of chronic obstructive pulmonary disease: Combination or component therapy?. CMAJ Canadian Medical Association Journal. 2003;168(10):1296-7. Review article.
Hall CS, Kyprianou A, Fein AM. Acute exacerbations in chronic obstructive pulmonary disease: current strategies with pharmacological therapy. Drugs. 2003;63(14):1481-8. Review article. [pmid: 12834365].
Halpern MT, Schmier JK, Van Kerkhove MD, Watkins M, Kalberg CJ. Impact of long-term inhaled corticosteroid therapy on bone mineral density: results of a meta-analysis. Annals of Allergy, Asthma, & Immunology. 2004;92(2):201-7. Review article.
Han YY, Sun WZ. An evidence-based review on the use of corticosteroids in peri-operative and critical care. Acta Anaesthesiologica Sinica. 2002;40(2):71-9. Review article. [pmid: 12194394].
Hanania NA, Sharafkhaneh A, Barber R, Dickey BF. Beta-agonist intrinsic efficacy: measurement and clinical significance. American Journal of Respiratory & Critical Care Medicine. 2002;165(10):1353-8. Review article. [pmid: 12016095].
Hansel TT, Barnes PJ. Tiotropium bromide: a novel once-daily anticholinergic bronchodilator for the treatment of COPD. Drugs of Today. 2002;38(9):585-600. Review article. [pmid: 12582447].
Hasani A, Toms N, Agnew JE, Sarno M, Harrison AJ, Dilworth P. The effect of inhaled tiotropium bromide on lung mucociliary clearance in patients with COPD. Chest. 2004;125(5):1726-34. Less than 50 subjects per arm. [pmid: 15136383].
Hattotuwa KL, Gizycki MJ, Ansari TW, Jeffery PK, Barnes NC. The effects of inhaled fluticasone on airway inflammation in chronic obstructive pulmonary disease: a double-blind, placebo-controlled biopsy study. American Journal of Respiratory & Critical Care Medicine. 2002;165(12):1592-6. Less than 50 subjects per arm. [pmid: 12070058].
Hauck RW, Virchow JC. Anti-obstructive anti-inflammatory therapy: no problems in pneumology, problematic in cardiology?. Medizinische Klinik. 2002;97(6):350-6. Not English language. [pmid: 12136470].
Hawkins P, Johnson LC, Nikoletou D, Hamnegard CH, Sherwood R, Polkey MI, et al. Proportional assist ventilation as an aid to exercise training in severe chronic obstructive pulmonary disease. Thorax. 2002;57(10):853-9. Less than 50 subjects per arm. [pmid: 12324670]. [pmcid: 1746205].
Hein H. The sleep apnoea syndromes: alternative therapies. Pneumologie. 2004;58(5):325-9. Not English language. [pmid: 15162258].
Hendra K, Celli B. Physiologic responses to long-term ventilation. Respiratory Care Clinics of North America. 2002;8(3):447-62. Review article. [pmid: 12481966].
Hensley M. Sleep apnoea (obstructive sleep apnoea-hypopnoea syndrome). Clinical Evidence. 2002;7:1566-78. Review article. [pmid: 12230773].
Hentschel M, Becker J, Lepthin HJ. Effects of a high intensity training program on patients with chronic obstructive airways disease (COAD). Pneumologie. 2002;56(4):240-6. Not English language. [pmid: 11951158].
Hertegonne KB, Proot PM, Pauwels RA, Pevernagie DA. Comfort and pressure profiles of two auto-adjustable positive airway pressure devices: a technical report. Respiratory Medicine. 2003;97(8):903-8. Not COPD patients. [pmid: 12924516].
Hess DR. The evidence for noninvasive positive-pressure ventilation in the care of patients in acute respiratory failure: a systematic review of the literature. Respiratory Care. 2004;49(7):810-29. Review article. [pmid: 15222912].
Hickling KG. Permissive hypercapnia. Respiratory Care Clinics of North America. 2002;8(2):155-69. Review article. [pmid: 12481813].
Hida W, Tun Y, Kikuchi Y, Okabe S, Shirato K. Pulmonary hypertension in patients with chronic obstructive pulmonary disease: recent advances in pathophysiology and management. Respirology. 2002;7(1):3-13. Review article. [pmid: 11896895].
Highcock MP, Smith IE, Shneerson JM. The effect of noninvasive intermittent positive-pressure ventilation during exercise in severe scoliosis. Chest. 2002;121(5):1555-60. Not COPD patients. [pmid: 12006443].
Highland KB. Inhaled corticosteroids in chronic obstructive pulmonary disease: is there a long-term benefit?. Current Opinion in Pulmonary Medicine. 2004;10(2):113-9. Review article. [pmid: 15021180].
Highland KB, Strange C, Heffner JE. Long-term effects of inhaled corticosteroids on FEV1 in patients with chronic obstructive pulmonary disease. A meta-analysis. Annals of Internal Medicine. 2003;138(12):969-73. Review article. [pmid: 12809453].
Hilbert G. Noninvasive ventilation with helium-oxygen rather than air-oxygen in acute exacerbations of chronic obstructive disease?. Critical Care Medicine. 2003;31(3):990-1. Review article. [pmid: 12627027].
Hill NS. Noninvasive ventilation for chronic obstructive pulmonary disease. Respiratory Care. 2004;49(1):72-87. Review article. [pmid: 14733624].
Hockman RH. Pharmacologic therapy for acute exacerbations of chronic obstructive pulmonary disease: a review. Critical Care Nursing Clinics of North America. 2004;16(3):293-310. Review article. [pmid: 15358379].
Hoekema A, Wijkstra PJ, Buiter CT, van der Hoeven JH, Meinesz AF, de Bont LG. Treatment of the obstructive sleep-apnea syndrome in adults. Nederlands Tijdschrift voor Geneeskunde. 2003;147(49):2407-12. Not English language. [pmid: 14694548].
Hofhuis W, de Jongste JC, Merkus PJ. Beta 2 agonists in infants and young children with a wheeze: often infective. Nederlands Tijdschrift voor Geneeskunde. 2003;147(45):2212-5. Not English language. [pmid: 14640058].
Hoo GW. Nonpharmacologic adjuncts to training during pulmonary rehabilitation: the role of supplemental oxygen and noninvasive ventilation. Journal of Rehabilitation Research & Development. 2003;40(5 Suppl 2):81-97. Review article. [pmid: 15074455].
Hore CT. Non-invasive positive pressure ventilation in patients with acute respiratory failure. Emergency Medicine. 2002;14(3):281-95. Review article. [pmid: 12487046].
Howarth PH, Knox AJ, Amrani Y, Tliba O, Panettieri RA Jr, Johnson M. Synthetic responses in airway smooth muscle. Journal of Allergy & Clinical Immunology. 2004;114(2 Suppl):S32-50. Review article. [pmid: 15309017].
Hutton SF. Tiotropium (Spiriva) for COPD. American Family Physician. 2004;69(12):2901-2. Review article. [pmid: 15222656].
Hvizdos KM, Goa KL. Tiotropium bromide. Drugs. 2002;62(8):1195-203. Review article. [pmid: 12010082].
Iliescu C, Tillie-Leblond I, Deschildre A, de Blic J. Difficult asthma in children. Archives de Pediatrie. 2002;9(12):1264-73. Not English language. [pmid: 12536110].
Ind PW, Laitinen L, Laursen L, Wenzel S, Wouters E, Deamer L, et al. Early clinical investigation of Viozan (sibenadet HCl), a novel D2 dopamine receptor, beta2-adrenoceptor agonist for the treatment of chronic obstructive pulmonary disease symptoms. Respiratory Medicine. 2003;97(Suppl A):S9-21. Study duration less than 3 months. [pmid: 12564607].
Ip MS, Tse HF, Lam B, Tsang KW, Lam WK. Endothelial function in obstructive sleep apnea and response to treatment. American Journal of Respiratory & Critical Care Medicine. 2004;169(3):348-53. Not COPD patients. [pmid: 14551167].
Isono S, Tanaka A, Nishino T. Lateral position decreases collapsibility of the passive pharynx in patients with obstructive sleep apnea. Anesthesiology. 2002;97(4):780-5. Not COPD patients. [pmid: 12357140].
Izquierdo Alonso JL. Clinical benefits of tiotropium, a new anticholinergic bronchodilator. Anales de Medicina Interna. 2002;19(12):640-3. Not English language. [pmid: 12593035].
Jaber R. Respiratory and allergic diseases: from upper respiratory tract infections to asthma. Primary Care; Clinics in Office Practice. 2002;29(2):231-61. Review article.
Jafri HS. Treatment of respiratory syncytial virus: antiviral therapies. Pediatric Infectious Disease Journal. 2003;22(2 Suppl):S89-92. Review article. [pmid: 12671458].
Jeannin L. COPD in elderly patients. Revue des Maladies Respiratoires. 2003;20(1 Pt 1):105-15. Not English language. [pmid: 12709639].
Johannson AB, Biarent D. International liaison Committee on Resuscitation. Resuscitation of the newly born. Acta Anaesthesiologica Belgica. 2002;53(4):311-6. Review article. [pmid: 12503356].
Johnell O, Pauwels R, Lofdahl CG, Laitinen LA, Postma DS, Pride NB, et al. Bone mineral density in patients with chronic obstructive pulmonary disease treated with budesonide Turbuhaler. European Respiratory Journal. 2002;19(6):1058-63. No clinical outcomes. [pmid: 12108857].
Johnson JE, Gavin DJ, Adams-Dramiga S. Effects of training with heliox and noninvasive positive pressure ventilation on exercise ability in patients with severe COPD. Chest. 2002;122(2):464-72. Less than 50 subjects per arm. [pmid: 12171818].
Johnson MK, Stevenson RD. Management of an acute exacerbation of COPD: are we ignoring the evidence?. Thorax. 2002;57(Suppl 2):II15-II23. Review article. [pmid: 11809984]. [pmcid: 1746176].
Jolliet P, Tassaux D. Helium-oxygen ventilation. Respiratory Care Clinics of North America. 2002;8(2):295-307. Review article. [pmid: 12481821].
Jolliet P, Tassaux D. Usefulness of helium-oxygen mixtures in the treatment of mechanically ventilated patients. Current Opinion in Critical Care. 2003;9(1):45-50. Review article. [pmid: 12548029].
Jones PW, Willits LR, Burge PS, Calverley PM. Inhaled Steroids in Obstructive Lung Disease in Europe study investigators. Disease severity and the effect of fluticasone propionate on chronic obstructive pulmonary disease exacerbations. European Respiratory Journal. 2003;21(1):68-73. Duplicate publication. [pmid: 12570111].
Jones PW, Wilson K, Sondhi S. Cost-effectiveness of salmeterol in patients with chronic obstructive pulmonary disease: an economic evaluation. Respiratory Medicine. 2003;97(1):20-6. Cost-effectiveness study. [pmid: 12556006].
Joos GF, Brusselle G, Derom E, Pauwels R. Tiotropium bromide: a long-acting anticholinergic bronchodilator for the treatment of patients with chronic obstructive pulmonary disease. International Journal of Clinical Practice. 2003;57(10):906-9. Review article. [pmid: 14712894].
Joos L. COPD and genetics--what's new?. Swiss Medical Weekly. 2004;134(3132):437-9. Review article. [pmid: 15389346].
Kaditis AG, Gourgoulianis K, Winnie G. Anti-inflammatory treatment for recurrent wheezing in the first five years of life. Pediatric Pulmonology. 2003;35(4):241-52. Review article. [pmid: 12629619].
Kajaste S, Brander PE, Telakivi T, Partinen M, Mustajoki P. A cognitive-behavioral weight reduction program in the treatment of obstructive sleep apnea syndrome with or without initial nasal CPAP: a randomized study. Sleep Medicine. 2004;5(2):125-31. Not COPD patients. [pmid: 15033131].
Kaneko Y, Floras JS, Usui K, Plante J, Tkacova R, Kubo T, et al. Cardiovascular effects of continuous positive airway pressure in patients with heart failure and obstructive sleep apnea. New England Journal of Medicine. 2003;348(13):1233-41. Not COPD patients. [pmid: 12660387].
Kaplan RM, Ries AL, Reilly J, Mohsenifar Z. Measurement of health-related quality of life in the national emphysema treatment trial. Chest. 2004;126(3):781-9. No intervention treatment. [pmid: 15364757].
Karaman O, Sunneli L, Uzuner N, Islekel H, Turgut CS, Kose S, et al. Evaluation of montelukast in 8 to 14 year old children with mild persistent asthma and compared with inhaled corticosteroids. Allergologia et Immunopathologia. 2004;32(1):21-7. Not COPD patients. [pmid: 14980192].
Karbonskiene A. Anesthesia and obstructive pulmonary disease. Medicina (Kaunas). 2003;39(11):1029-37. Not English language. [pmid: 14646455].
Katsura H. End of life care for patients with COPD. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2003;61(12):2212-9. Not English language. [pmid: 14674335].
Kaufman JS, Cheek DJ. Men's cardiovascular and pulmonary health. Nursing Clinics of North America. 2004;39(2):283-300. Review article. [pmid: 15159180].
Keam SJ, Keating GM. Tiotropium bromide. A review of its use as maintenance therapy in patients with COPD. Treatments in Respiratory Medicine. 2004;3(4):247-68. Review article. [pmid: 15350163].
Keenan SP, Sinuff T, Cook DJ, Hill NS. Which patients with acute exacerbation of chronic obstructive pulmonary disease benefit from noninvasive positive-pressure ventilation? A systematic review of the literature. Annals of Internal Medicine. 2003;138(11):861-70. Review article. [pmid: 12779296].
Keller CA. Pathophysiology and classification of emphysema. Chest Surgery Clinics of North America. 2003;13(4):589-613. Review article. [pmid: 14682597].
Kerstjens H, Postma D. Chronic obstructive pulmonary disease. Clinical Evidence. 2002;7:1344-57. Review article. [pmid: 12243121].
Kerstjens H, Postma D. Chronic obstructive pulmonary disease. Clinical Evidence. 2002;8:1530-45. Review article. [pmid: 12603952].
Kerstjens H, Postma D. Chronic obstructive pulmonary disease. Clinical Evidence. 2003;9:1645-63. Review article. [pmid: 12967439].
Kerstjens HA, Postma DS. Medical maintenance treatment of chronic obstructive pulmonary disease (COPD). Nederlands Tijdschrift voor Geneeskunde. 2002;146(35):1631-5. Not English language. [pmid: 12233157].
Kessler R, Weitzenblum E, Chaouat A, Iamandi C, Alliotte T. Evaluation of unattended automated titration to determine therapeutic continuous positive airway pressure in patients with obstructive sleep apnea. Chest. 2003;123(3):704-10. Not COPD patients. [pmid: 12628866].
Khilnani GC, Bhatta N. Non-invasive ventilation: current status. National Medical Journal of India. 2002;15(5):269-74. Review article. [pmid: 12502139].
Kiely JL, Nolan P, McNicholas WT. Intranasal corticosteroid therapy for obstructive sleep apnoea in patients with co-existing rhinitis. Thorax. 2004;59(1):50-5. Not COPD patients. [pmid: 14694248]. [pmcid: 1758841].
Kino H. New drug therapy of chronic obstructive pulmonary disease. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2003;61(12):2175-80. Review article. [pmid: 14674329].
Kitamura S. COPD guideline of Japanese Respiratory Society. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2003;61(12):2077-81. Review article. [pmid: 14674313].
Knutson D, Aring A. Viral croup. American Family Physician. 2004;69(3):535-40. Review article. [pmid: 14971835].
Koh ES, Chapeikin G. Anterior infradiaphragmatic free gas following bronchial rupture: case report and literature review. Australasian Radiology. 2004;48(1):58-60. Review article. [pmid: 15027922].
Kohnlein T, Criee CP, Kohler D, Welte T, Laier-Groeneveld G. Multicenter study on “non-invasive ventilation in patients with severe chronic obstructive pulmonary disease and emphysema(COPD)”. Pneumologie. 2004;58(8):566-9. Not English language. [pmid: 15293170].
Kohnlein T, Welte T, Tan LB, Elliott MW. Assisted ventilation for heart failure patients with Cheyne-Stokes respiration. European Respiratory Journal. 2002;20(4):934-41. Not COPD patients. [pmid: 12412686].
Kottakis J, Cioppa GD, Creemers J, Greefhorst L, Lecler V, Pistelli R, et al. Faster onset of bronchodilation with formoterol than with salmeterol in patients with stable, moderate to severe COPD: results of a randomized, double-blind clinical study. Canadian Respiratory Journal. 2002;9(2):107-15. Less than 50 subjects per arm. [pmid: 11972164].
Kozielski J. Diversities in the treatment of patients with chronic obstructive lung disease. Polski Merkuriusz Lekarski. 2003;14(84):666-7. Not English language. [pmid: 14524298].
Krachman SL, Criner GJ. Sleep and long-term ventilation. Respiratory Care Clinics of North America. 2002;8(4):611-29. Review article. [pmid: 12602418].
Krishna G, Sankaranarayanan V, Chitkara RK. New therapies for chronic obstructive pulmonary disease. Expert Opinion on Investigational Drugs. 2004;13(3):255-67. Review article. [pmid: 15013944].
Kroegel C. Chronic Obstructive Pulmonary Disease (GOLD). Global strategy for chronic obstructive pulmonary disease (GOLD). Update for the GOLD recommendations. Pneumologie. 2004;58(2):65-8. Review article. [pmid: 14961431].
Kuczkowski KM, Reisner LS, Benumof JL. Airway problems and new solutions for the obstetric patient. Journal of Clinical Anesthesia. 2003;15(7):552-63. Review article. [pmid: 14698372].
Kumar P, Athanasiou T, Sarkar PK. Inhaled foreign bodies in children: diagnosis and treatment. Hospital Medicine (London). 2003;64(4):218-22. Review article.
Kuna P. Recent results of clinical studies of synergistic treatment in obstructive respiratory tract diseases. Polski Merkuriusz Lekarski. 2003;14(84):663-5. Not English language. [pmid: 14524297].
Kuna P, Kuprys I. Symbicort Turbuhaler: a new concept in asthma management. International Journal of Clinical Practice. 2002;56(10):797-803. Review article. [pmid: 12510955].
Kus J. New cholinergic drugs in asthma and COPD. Pneumonologia i Alergologia Polska. 2002;70(Suppl 1):61-3. Not English language. [pmid: 12518641].
Kutty K. Sleep and chronic obstructive pulmonary disease. Current Opinion in Pulmonary Medicine. 2004;10(2):104-12. Review article. [pmid: 15021179].
Kuwahira I, Iwamoto T. Pulmonary hypertension and cor pulmonale in COPD. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2003;61(12):2138-43. Not English language. [pmid: 14674323].
Kwok H, McCormack J, Cece R, Houtchens J, Hill NS. Controlled trial of oronasal versus nasal mask ventilation in the treatment of acute respiratory failure. Critical Care Medicine. 2003;31(2):468-73. Not COPD patients. [pmid: 12576953].
Laaban JP. Sleep apnea syndrome and obesity. Revue de Pneumologie Clinique. 2002;58(2):91-8. Not English language. [pmid: 12082447].
Lacasse Y, Brosseau L, Milne S, Martin S, Wong E, Guyatt GH, et al. Pulmonary rehabilitation for chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2002, (3)CD003793. Review article.
Laghi F. Effect of inspiratory time and flow settings during assist-control ventilation. Current Opinion in Critical Care. 2003;9(1):39-44. Review article. [pmid: 12548028].
Laghi F, Tobin MJ. Disorders of the respiratory muscles. American Journal of Respiratory & Critical Care Medicine. 2003;168(1):10-48. Review article. [pmid: 12826594].
Langmack EL, Make BJ. Survival of individuals receiving long-term mechanical ventilation. Respiratory Care Clinics of North America. 2002;8(3):355-77. Review article. [pmid: 12481962].
Larj MJ, Bleecker ER. Therapeutic responses in asthma and COPD. Corticosteroids. Chest. 2004;126(2 Suppl):138S-149S. Review article. [pmid: 15302774].
Larson JL, Covey MK, Corbridge S. Inspiratory muscle strength in chronic obstructive pulmonary disease. AACN Clinical Issues. 2002;13(2):320-32. Review article. [pmid: 12011602].
Lazaar AL, Panettieri RA Jr. Is airway remodeling clinically relevant in asthma?. American Journal of Medicine. 2003;115(8):652-9. Review article. [pmid: 14656618].
Leal Hernandez M, Abellan Aleman J, Martinez Crespo J, Nicolas Bastida A. Written information on the use of aerosols in COPD patients. Can we improve their use?. Atencion Primaria. 2004;33(1):6-10. Not English language. [pmid: 14746738].
Lee DK, Lipworth BJ. The presence of emphysema does not affect the systemic bioactivity of inhaled fluticasone in severe chronic obstructive pulmonary disease. British Journal of Clinical Pharmacology. 2004;57(4):388-92. Less than 50 subjects per arm. [pmid: 15025735]. [pmcid: 1884482].
Leguillette R. Recurrent airway obstruction--heaves. Veterinary Clinics of North America - Equine Practice. 2003;19(1):63-86. Review article.
Lemyre B, Davis PG, de Paoli AG. Nasal intermittent positive pressure ventilation (NIPPV) versus nasal continuous positive airway pressure (NCPAP) for apnea of prematurity. Cochrane Database of Systematic Reviews 2002, (1)CD002272. Review article.
Lewis CA, Eaton TE, Young P, Kolbe J. Short-burst oxygen immediately before and after exercise is ineffective in nonhypoxic COPD patients. European Respiratory Journal. 2003;22(4):584-8. Less than 50 subjects per arm. [pmid: 14582907].
Lewis MI. Apoptosis as a potential mechanism of muscle cachexia in chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 2002;166(4):434-6. Review article. [pmid: 12186814].
Li F, Feng Q, Zhang X, Liu Q. Treatment for erectile dysfunction patients with obstructive sleep apnea syndrome by nasal continual positive airway pressure. Zhong Hua Nan Ke Xue. 2004;10(5):355-7. Not English language.
Lieberman D, Lieberman D. Pseudomonal infections in patients with COPD: epidemiology and management. American Journal of Respiratory Medicine. 2003;2(6):459-68. Review article. [pmid: 14719985].
Liesching T, Kwok H, Hill NS. Acute applications of noninvasive positive pressure ventilation. Chest. 2003;124(2):699-713. Review article. [pmid: 12907562].
Liesker JJ, Van De Velde V, Meysman M, Vincken W, Wollmer P, Hansson L, et al. Effects of formoterol (Oxis Turbuhaler) and ipratropium on exercise capacity in patients with COPD. Respiratory Medicine. 2002;96(8):559-66. Less than 50 subjects per arm. [pmid: 12195835].
Liesker JJ, Wijkstra PJ, Ten Hacken NH, Koeter GH, Postma DS, Kerstjens HA. A systematic review of the effects of bronchodilators on exercise capacity in patients with COPD. Chest. Feb. 2002;121(2):597-608. Review article. [pmid: 11834677].
Lightowler JV, Wedzicha JA, Elliott MW, Ram FS. Non-invasive positive pressure ventilation to treat respiratory failure resulting from exacerbations of chronic obstructive pulmonary disease: Cochrane systematic review and meta-analysis. BMJ. 2003;326(7382):185. Review article. [pmid: 12543832]. [pmcid: 140272].
Liistro G. Conservative and non surgical treatments for the sleep disordered breathing adult. Acta Oto-Rhino-Laryngologica Belgica. 2002;56(2):145-8. Review article. [pmid: 12092323].
Lindqvist A, Karjalainen EM, Laitinen LA, Kava T, Altraja A, Pulkkinen M, et al. Salmeterol resolves airway obstruction but does not possess anti-eosinophil efficacy in newly diagnosed asthma: a randomized, double-blind, parallel group biopsy study comparing the effects of salmeterol, fluticasone propionate, and disodium cromoglycate. Journal of Allergy & Clinical Immunology. 2003;112(1):23-8. Not COPD patients. [pmid: 12847475].
Lipson DA. Redefining treatment in COPD: new directions in bronchodilator therapy. Treatments in Respiratory Medicine. 2004;3(2):89-95. Review article. [pmid: 15182210].
Lipton AJ, Gozal D. Treatment of obstructive sleep apnea in children: do we really know how?. Sleep Medicine Reviews. 2003;7(1):61-80. Review article. [pmid: 12586531].
Lipworth BJ. Antagonism of long-acting beta2-adrenoceptor agonism. British Journal of Clinical Pharmacology. 2002;54(3):231-45. Review article. [pmid: 12236842]. [pmcid: 1874422].
Livingston E, Thomson NC. Managing chronic obstructive pulmonary disease. Practitioner. 2003; 247(1645):289, 292, 296 passim. Review article.
Llewellyn-Jones C. Long-acting beta 2-agonists in chronic obstructive pulmonary disease. Hospital Medicine (London). 2002;63(1):20-3. Review article.
Lofaso F, Leroux K, Quera-Salva MA, Mroue G, D'Ortho MP, Isabey D, et al. Snoring detection during auto-nasal continuous positive airway pressure. European Respiratory Journal. 2002;19(1):108-12. Not COPD patients. [pmid: 11843308].
Louis PJ, Fernandes R. Negative pressure pulmonary edema. Oral Surgery, Oral Medicine, Oral Pathology, Oral Radiology, & Endodontics. 2002;93(1):4-6. Review article.
Lynes D, Riches A. Managing hypoxia and hypercapnia. Nursing Times. 2003;99(11):57-9. Review article. [pmid: 12683053].
Lyseng-Williamson KA, Keating GM. Inhaled salmeterol/fluticasone propionate combination in chronic obstructive pulmonary disease. American Journal of Respiratory Medicine. 2002;1(4):273-82. Review article. [pmid: 14720047].
Macfarlane J, Holmes W, Gard P, Thornhill D, Macfarlane R, Hubbard R. Reducing antibiotic use for acute bronchitis in primary care: blinded, randomised controlled trial of patient information leaflet. BMJ. 2002;324(7329):91-4. Not COPD patients. [pmid: 11786454].
Machida K. Efficacy of pulmonary rehabilitation and clinical practice. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2003;61(12):2187-92. Not English language. [pmid: 14674331].
MacIntyre NR. Chronic obstructive pulmonary disease: emerging medical therapies. Respiratory Care. 2004;49(1):64-9. Review article. [pmid: 14733623].
MacNee W, Calverley PM. Chronic obstructive pulmonary disease . 7: Management of COPD. Thorax. 2003;58(3):261-5. Review article. [pmid: 12612309]. [pmcid: 1746595].
Mador MJ, Bozkanat E, Aggarwal A, Shaffer M, Kufel TJ. Endurance and strength training in patients with COPD. Chest. 2004;125(6):2036-45. Less than 50 subjects per arm. [pmid: 15189919].
Magnussen H. COPD: an inflammatory disease of the airways?. Pneumologie. 2004;58(5):320-4. Not English language. [pmid: 15162257].
Magnussen H. Inhalation therapy for bronchial asthma: strategies and targets. Current Opinion in Pulmonary Medicine. 2003;9(Suppl 1):S3-7. Review article. [pmid: 12974535].
Magyar P. Recommended therapy in chronic obstructive lung disease. Orvosi Hetilap. 2004;145(14):777-80. Not English language. [pmid: 15131994].
Mahler DA. Dyspnea relief. Monaldi Archives for Chest Disease. 2003;59(4):331-4. Review article. [pmid: 15148848].
Mahler DA. The effect of inhaled beta2-agonists on clinical outcomes in chronic obstructive pulmonary disease. Journal of Allergy & Clinical Immunology. 2002;110(6 Suppl):S298-303. Review article. [pmid: 12464939].
Make BJ. Chronic obstructive pulmonary disease: developing comprehensive management. Respiratory Care. 2003;48(12):1225-34. Review article. [pmid: 14651763].
Malhotra A, White DP. Obstructive sleep apnoea. Lancet. 2002;360(9328):237-45. Review article. [pmid: 12133673].
Maltais F, Leblanc P, Jobin J, Casaburi R. Peripheral muscle dysfunction in chronic obstructive pulmonary disease. Revue des Maladies Respiratoires. 2002;19(4):444-53. Not English language. [pmid: 12417861].
Maltais F, Ostinelli J, Bourbeau J, Tonnel AB, Jacquemet N, Haddon J, et al. Comparison of nebulized budesonide and oral prednisolone with placebo in the treatment of acute exacerbations of chronic obstructive pulmonary disease: a randomized controlled trial. American Journal of Respiratory & Critical Care Medicine. 2002;165(5):698-703. Study duration less than 3 months. [pmid: 11874817].
Man WD, Mustfa N, Nikoletou D, Kaul S, Hart N, Rafferty GF, et al. Effect of salmeterol on respiratory muscle activity during exercise in poorly reversible COPD. Thorax. 2004;59(6):471-6. Less than 50 subjects per arm. [pmid: 15170026]. [pmcid: 1747047].
Mansfield DR, Gollogly NC, Kaye DM, Richardson M, Bergin P, Naughton MT. Controlled trial of continuous positive airway pressure in obstructive sleep apnea and heart failure. American Journal of Respiratory & Critical Care Medicine. 2004;169(3):361-6. Not COPD patients. [pmid: 14597482].
Mapel DW. Treatment implications on morbidity and mortality in COPD. Chest. 2004;126(2 Suppl):150S-158S. Review article. [pmid: 15302775].
Marvisi M, Brianti M, Marani G, Turrini G, Zambrelli P, Ajolfi C, et al. Acute antiarrhythmic effects of bi-level positive airway pressure ventilation in patients with acute respiratory failure caused by chronic obstructive pulmonary disease: a randomized clinical trial. Respiration. 2004;71(2):152-8. Less than 50 subjects per arm. [pmid: 15031570].
Masoli M, Holt S, Weatherall M, Beasley R. The dose-response relationship of inhaled corticosteroids in asthma. Current Allergy & Asthma Reports. 2004;4(2):144-8. Review article. [pmid: 14769264].
Massie CA, Hart RW. Clinical outcomes related to interface type in patients with obstructive sleep apnea/hypopnea syndrome who are using continuous positive airway pressure. Chest. 2003;123(4):1112-8. Not COPD patients. [pmid: 12684301].
Massie CA, McArdle N, Hart RW, Schmidt-Nowara WW, Lankford A, Hudgel DW, et al. Comparison between automatic and fixed positive airway pressure therapy in the home. American Journal of Respiratory & Critical Care Medicine. 2003;167(1):20-3. Not COPD patients. [pmid: 12406840].
Matthys H. Chronic obstructive lung diseases--indications for O(2)-longterm therapy. Pneumologie. 2002;56(7):443-7. Not English language. [pmid: 12140799].
McAllister J. Chronic obstructive pulmonary disease. Part 3. Nursing Times. 2002;98(37):43-6. Review article. [pmid: 12271716].
McCrory DC, Brown CD. Anti-cholinergic bronchodilators versus beta2-sympathomimetic agents for acute exacerbations of chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2002; (4)CD003900. Review article.
McDermott A. Pulmonary rehabilitation for patients with COPD. Professional Nurse. 2002;17(9):553-6. Review article.
McKenna RJ Jr, Benditt JO, DeCamp M, Deschamps C, Kaiser L, Lee SM, et al. Safety and efficacy of median sternotomy versus video-assisted thoracic surgery for lung volume reduction surgery. Journal of Thoracic & Cardiovascular Surgery. 2004;127(5):1350-60. Not a randomized controlled trial. [pmid: 15115992].
McMahon JP, Foresman BH, Chisholm RC. The influence of CPAP on the neurobehavioral performance of patients with obstructive sleep apnea hypopnea syndrome: a systematic review. WMJ. 2003;102(1):36-43. Review article. [pmid: 12679970].
McNicholas WT. Impact of sleep on respiratory muscle function. Monaldi Archives for Chest Disease. 2002;57(56):277-80. Review article. [pmid: 12814041].
McNicholas WT, Calverley PM, Lee A, Edwards JC. Tiotropium Sleep Study in COPD Investigators. Long-acting inhaled anticholinergic therapy improves sleeping oxygen saturation in COPD. European Respiratory Journal. 2004;23(6):825-31. Study duration less than 3 months. [pmid: 15218993].
Meek PM, Lareau SC. Critical outcomes in pulmonary rehabilitation: assessment and evaluation of dyspnea and fatigue. Journal of Rehabilitation Research & Development. 2003;40(5 Suppl 2):13-24. Review article. [pmid: 15074450].
Meston N, Davies RJ, Mullins R, Jenkinson C, Wass JA, Stradling JR. Endocrine effects of nasal continuous positive airway pressure in male patients with obstructive sleep apnoea. Journal of Internal Medicine. 2003;254(5):447-54. Not COPD patients. [pmid: 14535966].
Meyer P, Andersson M, Persson CG, Greiff L. Steroid-sensitive indices of airway inflammation in children with seasonal allergic rhinitis. Pediatric Allergy & Immunology. 2003;14(1):60-5. Not COPD patients. [pmid: 12603713].
Mineo TC, Ambrogi V, Pompeo E, Elia S, Mineo D, Bollero P, et al. Impact of lung volume reduction surgery versus rehabilitation on quality of life. European Respiratory Journal. 2004;23(2):275-80. Less than 50 subjects per arm. [pmid: 14979503].
Minoguchi H, Shibuya M, Miyagawa T, Kokubu F, Yamada M, Tanaka H, et al. Cross-over comparison between respiratory muscle stretch gymnastics and inspiratory muscle training. Internal Medicine. 2002;41(10):805-12. Less than 50 subjects per arm. [pmid: 12413000].
Monninkhof E, van der Valk P, van der Palen J, van Herwaarden C, Partridge MR, Zielhuis G. Self-management education for patients with chronic obstructive pulmonary disease: a systematic review. Thorax. 2003;58(5):394-8. Review article. [pmid: 12728158]. [pmcid: 1746688].
Monninkhof EM, van der Valk PD, van der Palen J, van Herwaarden CL, Partidge MR, Walters EH, et al. Self-management education for chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2003; (1)CD002990. Review article.
Montuschi P. Pharmacological therapy of chronic obstructive pulmonary disease. Annali Dell'Istituto Superiore di Sanita. 2003;39(4):557-72. Not English language.
Morgan MD, Britton JR. Chronic obstructive pulmonary disease 8: non-pharmacological management of COPD. Thorax. 2003;58(5):453-7. Review article. [pmid: 12728173]. [pmcid: 1746662].
Muir JF, Benhamou D, Cuvelier A, Le Gros V, Overend T, Till D, et al. FEV1 reversibility does not adequately predict effect of formoterol via Aerolizer in chronic obstructive pulmonary disease. International Journal of Clinical Practice. 2004;58(5):457-64. Review article. [pmid: 15206501].
Muir JF, Cuvelier A. Evaluation of candidates for long-term ventilation. Respiratory Care Clinics of North America. 2002;8(3):405-18. Review article. [pmid: 12481964].
Muir JF, Cuvelier A. Means and organisation of the management of severe forms of COPD. Revue du Praticien. 2004;54(13):1445-50. Not English language. [pmid: 15497799].
Muir JF, Portier F. Obstructive sleep apnea syndrome: medical treatment. Revue de Stomatologie et de Chirurgie Maxillo-Faciale. 2002;103(3):164-9. Not English language. [pmid: 12486890].
Murdoch RD, Cowley H, Kelly J, Higgins R, Webber D. Cilomilast (Ariflo) does not potentiate the cardiovascular effects of inhaled salbutamol. Pulmonary Pharmacology & Therapeutics. 2002;15(6):521-7. Less than 50 subjects per arm. [pmid: 12493339].
Nagai A. Diagnosis and treatment of COPD. Nippon Naika Gakkai Zasshi - Journal of Japanese Society of Internal Medicine. 2002;91(Suppl):137-40. Not English language.
Nandi K, Smith AA, Crawford A, MacRae KD, Garrod R, Seed WA, et al. Oxygen supplementation before or after submaximal exercise in patients with chronic obstructive pulmonary disease. Thorax. 2003;58(8):670-3. Less than 50 subjects per arm. [pmid: 12885981]. [pmcid: 1746761].
Nannini L, Lasserson TJ, Poole P. Combined corticosteroid and longacting beta-agonist in one inhaler for chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2003; (4)CD003794. Review article.
Narkiewicz K, Somers VK. Sympathetic nerve activity in obstructive sleep apnoea. Acta Physiologica Scandinavica. 2003;177(3):385-90. Review article. [pmid: 12609010].
Naunheim KS. Update on lung volume reduction. Journal of Surgical Research. 2004;117(1):134-43. Review article. [pmid: 15013724].
Newman SP. Spacer devices for metered dose inhalers. Clinical Pharmacokinetics. 2004;43(6):349-60. Review article. [pmid: 15086274].
Nicolai T. Therapeutic concepts in upper airway obstruction. Paediatric Respiratory Reviews. 2004;5(1):34-9. Review article. [pmid: 15222952].
Niewoehner DE. The role of systemic corticosteroids in acute exacerbation of chronic obstructive pulmonary disease. American Journal of Respiratory Medicine. 2002;1(4):243-8. Review article. [pmid: 14720044].
Ninot G, Brun A, Queiras G, Segi A, Moullec G, Desplan J. Psychosocial support for pulmonary rehabilitation in patients with Chronic Obstructive Pulmonary Disease. Revue des Maladies Respiratoires. 2003;20(4):549-57. Not English language. [pmid: 14528157].
Nishimura K. Corticosteroids for treatment of patients with chronic obstructive pulmonary disease. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2003;61(12):2181-6. Not English language. [pmid: 14674330].
Nixon GM, Brouillette RT. Obstructive sleep apnea in children: do intranasal corticosteroids help?. American Journal of Respiratory Medicine. 2002;1(3):159-66. Review article. [pmid: 14720053].
Noseda A. Drug therapies of COPD. Revue Medicale de Bruxelles. 2003;24(4):A354-7. Not English language. [pmid: 14606301].
Numata Y, Bourbeau J, Ernst P, Duquette G, Schwartzman K. Teaching time for metered-dose inhalers in the emergency setting. Chest. 2002;122(2):498-504. Study duration less than 3 months. [pmid: 12171822].
O'Brien JA, Ward AJ, Jones MK, McMillan C, Lordan N. Utilization of health care services by patients with chronic obstructive pulmonary disease. Respiratory Medicine. 2003;97(Suppl A):S53-8. No clinical outcomes. [pmid: 12564611].
O'Donnell DE, D'Arsigny C, Fitzpatrick M, Webb KA. Exercise hypercapnia in advanced chronic obstructive pulmonary disease: the role of lung hyperinflation. American Journal of Respiratory & Critical Care Medicine. 2002;166(5):663-8. Less than 50 subjects per arm. [pmid: 12204862].
O'Donnell DE, Fluge T, Gerken F, Hamilton A, Webb K, Aguilaniu B, et al. Effects of tiotropium on lung hyperinflation, dyspnoea and exercise tolerance in COPD. European Respiratory Journal. 2004;23(6):832-40. Study duration less than 3 months. [pmid: 15218994].
O'Shea SD, Taylor NF, Paratz J. Peripheral muscle strength training in COPD: a systematic review. Chest. 2004;126(3):903-14. Review article. [pmid: 15364773].
Oga T, Nishimura K, Tsukino M, Sato S. Exercise responses during endurance testing at different intensities in patients with COPD. Respiratory Medicine. 2004;98(6):515-21. Less than 50 subjects per arm. [pmid: 15191036].
Oga T, Nishimura K, Tsukino M, Sato S, Hajiro T, Mishima M. A comparison of the effects of salbutamol and ipratropium bromide on exercise endurance in patients with COPD. Chest. 2003;123(6):1810-6. Study duration less than 3 months. [pmid: 12796154].
Oguri K. Pharmacological action and clinical aspects of salmeterol. Nippon Yakurigaku Zasshi - Folia Pharmacologica Japonica. 2003;122(3):265-70. Not English language. [pmid: 12939544].
Oh EG. The effects of home-based pulmonary rehabilitation in patients with chronic lung disease. International Journal of Nursing Studies. 2003;40(8):873-9. Less than 50 subjects per arm. [pmid: 14568368].
Olson EJ, Moore WR, Morgenthaler TI, Gay PC, Staats BA. Obstructive sleep apnea-hypopnea syndrome. Mayo Clinic Proceedings. 2003;78(12):1545-52. Review article. [pmid: 14661684].
Oostenbrink JB, Al MJ, Rutten-van Molken MP. Methods to analyse cost data of patients who withdraw in a clinical trial setting. Pharmacoeconomics. 2003;21(15):1103-12. Cost-effectiveness study. [pmid: 14596629].
Oostenbrink JB, Rutten-van Molken MP, Al MJ, Van Noord JA, Vincken W. One-year cost-effectiveness of tiotropium versus ipratropium to treat chronic obstructive pulmonary disease. European Respiratory Journal. 2004;23(2):241-9. Cost efficiency evaluation of Vincken (2002). [pmid: 14979498].
Opperwall B. Asthma in toddlers and young children. Airway remodeling should be primary focus. Advance for Nurse Practitioners. 2002;10(4):67-70. Review article. [pmid: 12418352].
Ormiston TM, Salpeter SR. Beta-blocker use in patients with congestive heart failure and concomitant obstructive airway disease: moving from myth to evidence-based practice. Heart Failure Monitor. 2003;4(2):45-54. Review article. [pmid: 14724718].
Ouksel H, Le Guen Y, Racineux JL. Management of stable COPD. Revue du Praticien. 2004;54(13):1425-31. Not English language. [pmid: 15497796].
Palm KH, Decker WW. Acute exacerbations of chronic obstructive pulmonary disease. Emergency Medicine Clinics of North America. 2003;21(2):331-52. Review article. [pmid: 12793617].
Panettieri RA Jr. Airway smooth muscle: an immunomodulatory cell. Journal of Allergy & Clinical Immunology. 2002;110(6 Suppl):S269-74. Review article. [pmid: 12464935].
Panitch HB. Respiratory syncytial virus bronchiolitis: supportive care and therapies designed to overcome airway obstruction. Pediatric Infectious Disease Journal. 2003;22(2 Suppl):S83-7. Review article. [pmid: 12671457].
Panning CA, DeBisschop M. Tiotropium: an inhaled, long-acting anticholinergic drug for chronic obstructive pulmonary disease. Pharmacotherapy. 2003;23(2):183-9. Review article. [pmid: 12587807].
Panton LB, Golden J, Broeder CE, Browder KD, Cestaro-Seifer DJ, Seifer FD. The effects of resistance training on functional outcomes in patients with chronic obstructive pulmonary disease. European Journal of Applied Physiology. 2004;91(4):443-9. Less than 50 subjects per arm. [pmid: 14639479].
Parameswaran K, O'Byrne PM, Sears MR. Inhaled corticosteroids for asthma: common clinical quandaries. Journal of Asthma. 2003;40(2):107-18. Review article. [pmid: 12765311].
Parthasarathy S, Tobin MJ. Sleep in the intensive care unit. Intensive Care Medicine. 2004;30(2):197-206. Review article. [pmid: 14564378].
Patel SR, White DP, Malhotra A, Stanchina ML, Ayas NT. Continuous positive airway pressure therapy for treating sleepiness in a diverse population with obstructive sleep apnea: results of a meta-analysis. Archives of Internal Medicine. 2003;163(5):565-71. Not COPD patients. [pmid: 12622603].
Pavord ID, Sterk PJ, Hargreave FE, Kips JC, Inman MD, Louis R, et al. Clinical applications of assessment of airway inflammation using induced sputum. European Respiratory Journal - Supplement. 2002;37:40s-43s. Review article.
Pedersen ST, Lange P. Tiotropium. A new anti-cholinergic agent for treatment of chronic obstructive pulmonary disease. Ugeskrift for Laeger. 2003;165(22):2279-83. Not English language. [pmid: 12830753].
Peigang Y, Marini JJ. Ventilation of patients with asthma and chronic obstructive pulmonary disease. Current Opinion in Critical Care. 2002;8(1):70-6. Review article. [pmid: 12205409].
Pepperell JC, Davies RJ, Stradling JR. Systemic hypertension and obstructive sleep apnoea. Sleep Medicine Reviews. 2002;6(3):157-73. Review article. [pmid: 12531119].
Pepperell JC, Ramdassingh-Dow S, Crosthwaite N, Mullins R, Jenkinson C, Stradling JR, et al. Ambulatory blood pressure after therapeutic and subtherapeutic nasal continuous positive airway pressure for obstructive sleep apnoea: a randomised parallel trial. Lancet. 2002;359(9302):204-10. Not COPD patients. [pmid: 11812555].
Perez T. Bronchodilatators and exercise in COPD: effects, evaluation and strategy of use. Revue de Pneumologie Clinique. 2002;58(4 Pt 2):2S11-7. Not English language. [pmid: 12458313].
Peter JV, Moran JL, Phillips-Hughes J, Warn D. Noninvasive ventilation in acute respiratory failure--a meta-analysis update. Critical Care Medicine. 2002;30(3):555-62. Review article. [pmid: 11990914].
Petty TL. COPD in perspective. Chest. 2002;121(5 Suppl):116S-120S. Review article. [pmid: 12010838].
Phillips BG, Somers VK. Hypertension and obstructive sleep apnea. Current Hypertension Reports. 2003;5(5):380-5. Review article. [pmid: 12948430].
Pierson DJ. Indications for mechanical ventilation in adults with acute respiratory failure. Respiratory Care. 2002;47(3):249-62. Review article. [pmid: 11874605].
Pinnock H. Respiratory medicine. British Journal of General Practice. 2004;54(504):539-47. Review article. [pmid: 15239918]. [pmcid: 1324808].
Piszko P, Lewczuk J, Kowalska-Superlak M, Wrabec K. Oxygen saturation at rest, on exercise and during sleep in COPD patients undergoing pulmonary rehabilitation program. Two years prospective controlled study. Pneumonologia i Alergologia Polska. 2002;70(1112):566-72. Not English language. [pmid: 12884566].
Planes C, D'Ortho MP, Foucher A, Berkani M, Leroux K, Essalhi M, et al. Efficacy and cost of home-initiated auto-nCPAP versus conventional nCPAP. Sleep. 2003;26(2):156-60. Not COPD patients. [pmid: 12683473].
Plant PK, Elliott MW. Chronic obstructive pulmonary disease * 9: management of ventilatory failure in COPD. Thorax. 2003;58(6):537-42. Review article. [pmid: 12775872]. [pmcid: 1746710].
Plant PK, Owen JL, Parrott S, Elliott MW. Cost effectiveness of ward based non-invasive ventilation for acute exacerbations of chronic obstructive pulmonary disease: economic analysis of randomised controlled trial. BMJ. 2003;326(7396):956. Cost-effectiveness study. [pmid: 12727767]. [pmcid: 153850].
Plusa T. Changes of therapeutic dogma in obstructive lung diseases. Polski Merkuriusz Lekarski. 2003;14(84):672-3. Not English language. [pmid: 14524300].
Polkey MI. Muscle metabolism and exercise tolerance in COPD. Chest. 2002;121(5 Suppl):131S-135S. Review article. [pmid: 12010841].
Polla B, D'Antona G, Bottinelli R, Reggiani C. Respiratory muscle fibres: specialisation and plasticity. Thorax. 2004;59(9):808-17. Review article. [pmid: 15333861]. [pmcid: 1747126].
Porta R, Appendini L, Vitacca M, Bianchi L, Donner CF, Poggi R, et al. Mask proportional assist vs pressure support ventilation in patients in clinically stable condition with chronic ventilatory failure. Chest. 2002;122(2):479-88. Less than 50 subjects per arm. [pmid: 12171820].
Profant J, Ancoli-Israel S, Dimsdale JE. A randomized, controlled trial of 1 week of continuous positive airway pressure treatment on quality of life. Heart & Lung: Journal of Acute & Critical Care. 2003;32(1):52-8. Not COPD patients.
Puente-Maestu L, Luisa Sanz M, Sanz P, de Ona RJ, Arnedillo A, Casaburi R. Long-term effects of a maintenance program after supervised or self-monitored training programs in patients with COPD. Lung. 2003;181(2):67-78. Less than 50 subjects per arm. [pmid: 12953145].
Puhan MA, Behnke M, Laschke M, Lichtenschopf A, Brandli O, Guyatt GH, et al. Self-administration and standardisation of the chronic respiratory questionnaire: a randomised trial in three German-speaking countries. Respiratory Medicine. 2004;98(4):342-50. No treatment intervention. [pmid: 15072175].
Qureshi A, Ballard RD. Obstructive sleep apnea. Journal of Allergy & Clinical Immunology. 2003;112(4):643-51. Review article. [pmid: 14564340].
Rabe KF. State of the art in beta2-agonist therapy: a safety review of long-acting agents. International Journal of Clinical Practice. 2003;57(8):689-97. Review article. [pmid: 14627180].
Rabinovich RA, Vilaro J, Roca J. Evaluation exercise tolerance in COPD patients: the 6-minute walking test. Archivos de Bronconeumologia. 2004;40(2):80-5. Not English language. [pmid: 14746731].
Rabow MW, Dibble SL, Pantilat SZ, McPhee SJ. The comprehensive care team: a controlled trial of outpatient palliative medicine consultation. Archives of Internal Medicine. 2004;164(1):83-91. Less than 50 subjects per arm. [pmid: 14718327].
Radenne F, Verkindre C, Tonnel AB. Asthma in the elderly. Revue des Maladies Respiratoires. 2003;20(1 Pt 1):95-103. Not English language. [pmid: 12709638].
Ram FS, Lightowler JV, Wedzicha JA. Non-invasive positive pressure ventilation for treatment of respiratory failure due to exacerbations of chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2003; (1)CD004104. Review article.
Ram FS, Picot J, Lightowler J, Wedzicha JA. Non-invasive positive pressure ventilation for treatment of respiratory failure due to exacerbations of chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2004; (1)CD004104. Review article.
Ram FS, Sestini P. Regular inhaled short acting beta2 agonists for the management of stable chronic obstructive pulmonary disease: Cochrane systematic review and meta-analysis. Thorax. 2003;58(7):580-4. Review article. [pmid: 12832670]. [pmcid: 1746735].
Ram FS, Wedzicha JA. Ambulatory oxygen for chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2002; (2)CD000238. Review article.
Ramirez-Sarmiento A, Orozco-Levi M, Guell R, Barreiro E, Hernandez N, Mota S, et al. Inspiratory muscle training in patients with chronic obstructive pulmonary disease: structural adaptation and physiologic outcomes. American Journal of Respiratory & Critical Care Medicine. 2002;166(11):1491-7. Less than 50 subjects per arm. [pmid: 12406842].
Randerath W, Galetke W, Karl-Heinz R. Chronic-obstructive pulmonary disease. Medical treatment. Medizinische Monatsschrift fur Pharmazeuten 168. 2002;25(5):150-8. Not English language.
Randerath WJ, Heise M, Hinz R, Ruehle KH. An individually adjustable oral appliance vs continuous positive airway pressure in mild-to-moderate obstructive sleep apnea syndrome. Chest. 2002;122(2):569-75. Not COPD patients. [pmid: 12171833].
Rennard SI. New therapeutic drugs in the management of chronic obstructive pulmonary disease. Current Opinion in Pulmonary Medicine. 2002;8(2):106-11. Review article. [pmid: 11845005].
Reybet-Degat O, Massin F, Grangeon C, Hzam M, Merati M, Baudouin N, et al. Acute respiratory failure in obesity. Revue de Pneumologie Clinique. 2002;58(2):111-6. Not English language. [pmid: 12082450].
Reynolds NA, Perry CM, Keating GM. Budesonide/ formoterol: in chronic obstructive pulmonary disease. Drugs. 2004;64(4):431-41. Review article. [pmid: 14969576].
Riancho JA, Cubian I, Portero I. Effectiveness of inhaled corticosteroids in chronic obstructive lung disease: systematic review. Medicina Clinica. 2002;118(12):446-51. Not English language. [pmid: 11958761].
Rich A. Corticosteroids and chronic obstructive pulmonary disease in the nursing home. Journal of the American Medical Directors Association. 2004;5(1):31-7. Review article. [pmid: 14706126].
Riches A. Noninvasive ventilation and COPD. Nursing Times. 2003;99(20):49. Review article. [pmid: 12800647].
Richter F, Gillissen A. Spirometry, pulse oximetry, brochospasmolytic test. The pillars of COPD diagnosis. MMW Fortschritte der Medizin. 2002;144(15):30-3. Not English language. [pmid: 12004446].
Ringbaek TJ, Viskum K, Lange P. Does long-term oxygen therapy reduce hospitalisation in hypoxaemic chronic obstructive pulmonary disease?. European Respiratory Journal. 2002;20(1):38-42. No clinical outcomes. [pmid: 12166578].
Roberts SD, Mustafa M, Penrod M, Bills DN. Event and sideline management of sudden cardiac death. Current Sports Medicine Reports. 2002;1(3):141-8. Review article. [pmid: 12831706].
Robinson GV, Pepperell JC, Davies RJ, Stradling JR. Caffeine levels following treatment of obstructive sleep apnoea. Thorax. 2003;58(9):801-2. Not COPD patients. [pmid: 12947143]. [pmcid: 1746804].
Robinson JD, Angelini BL, Krahnke JS, Skoner DP. Inhaled steroids and the risk of adrenal suppression in children. Expert Opinion on Drug Safety. 2002;1(3):237-44. Review article. [pmid: 12904139].
Roche N. Bronchodilators in COPD: latest recommendations, recent data and perspectives. Presse Medicale. 2004;33(2):111-8. Not English language.
Rochester CL. Exercise training in chronic obstructive pulmonary disease. Journal of Rehabilitation Research & Development. 2003;40(5 Suppl 2):59-80. Review article. [pmid: 15074454].
Rodway GW, Sanders MH. The efficacy of split-night sleep studies. Sleep Medicine Reviews. 2003;7(5):391-401. Review article. [pmid: 14573375].
Rogers DF. Pulmonary mucus: Pediatric perspective. Pediatric Pulmonology. 2003;36(3):178-88. Review article. [pmid: 12910578].
Rooyackers JM, Berkeljon DA, Folgering HT. Eccentric exercise training in patients with chronic obstructive pulmonary disease. International Journal of Rehabilitation Research. 2003;26(1):47-9. Less than 50 subjects per arm. [pmid: 12601267].
Roque d'Orbcastel O, Polu JM. Home mechanical ventilation, another unique French phenomenon?. Revue des Maladies Respiratoires. 2004;21(2 Pt 1):345-9. Not English language. [pmid: 15211242].
Rosen CL. Obstructive sleep apnea syndrome in children: controversies in diagnosis and treatment. Pediatric Clinics of North America. 2004;51(1):153-67. Review article. [pmid: 15008587].
Rowe BH, Edmonds ML, Spooner CH, Diner B, Camargo CA Jr. Corticosteroid therapy for acute asthma. Respiratory Medicine. 2004;98(4):275-84. Review article. [pmid: 15072167].
Rubenfeld GD. Implementing effective ventilator practice at the bedside. Current Opinion in Critical Care. 2004;10(1):33-9. Review article. [pmid: 15166847].
Ruiz de Ona Lacasta JM, Garcia de Pedro J, Puente Maestu L, Llorente Inigo D, Celdran Gil J, Cubillo Marcos JM. Effects of muscle training on breathing pattern in patients with severe chronic obstructive pulmonary disease. Archivos de Bronconeumologia. 2004;40(1):20-3. Not English language. [pmid: 14718117].
Saey D, Debigare R, LeBlanc P, Mador MJ, Cote CH, Jobin J, et al. Contractile leg fatigue after cycle exercise: a factor limiting exercise in patients with chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 2003;168(4):425-30. Less than 50 subjects per arm. [pmid: 12714348].
Salman GF, Mosier MC, Beasley BW, Calkins DR. Rehabilitation for patients with chronic obstructive pulmonary disease: meta-analysis of randomized controlled trials. Journal of General Internal Medicine. 2003;18(3):213-21. Review article. [pmid: 12648254]. [pmcid: 1494836].
Salpeter SR. Cardiovascular safety of beta(2)-adrenoceptor agonist use in patients with obstructive airway disease: a systematic review. Drugs & Aging. 2004;21(6):405-14. Review article. [pmid: 15084142].
Salpeter SR, Ormiston TM, Salpeter EE. Cardioselective beta-blockers in patients with reactive airway disease: a meta-analysis. Annals of Internal Medicine. 2002;137(9):715-25. Review article. [pmid: 12416945].
Salpeter SR, Ormiston TM, Salpeter EE. Cardiovascular effects of beta-agonists in patients with asthma and COPD: a meta-analysis. Chest. 2004;125(6):2309-21. Review article. [pmid: 15189956].
Sandiumenge A, Diaz E, Bodi M, Rello J. Therapy of ventilator-associated pneumonia. A patient-based approach based on the ten rules of “The Tarragona Strategy”. Intensive Care Medicine. 2003;29(6):876-83. Review article. [pmid: 12677369].
Sanjuas C. Dyspnea and quality of life in chronic obstructive pulmonary disease. Archivos de Bronconeumologia. 2002;38(10):485-8. Not English language. [pmid: 12372199].
Sanner B, Hader C, Rasche K. Obstructive sleep apnea syndrome--therapy. Deutsche Medizinische Wochenschrift. 2004;129(11):570-6. Not English language. [pmid: 14997409].
Saura P, Blanch L. How to set positive end-expiratory pressure. Respiratory Care. 2002;47(3):279-92. Review article. [pmid: 11874607].
Scandroglio M, Piccolo U, Mazzone E, Agrati P, Aspesi M, Gamberoni C, et al. Use and nursing of the helmet in delivering non invasive ventilation. Minerva Anestesiologica. 2002;68(5):475-80. Review article. [pmid: 12029267].
Schibler A, Frey U. Role of lung function testing in the management of mechanically ventilated infants. Archives of Disease in Childhood Fetal & Neonatal Edition. 2002;87(1):F7-F10. Review article. [pmid: 12091280].
Schleufe P, Domurath H, Piepenbrock S. beta(2)-Agonist delivery via a resuscitator bag (Ambu MediBag): a comparison with a metered-dose inhaler using the Volumatic-Spacer. Resuscitation. 2004;61(3):327-31. Not COPD patients. [pmid: 15172712].
Schoeman JF, Springer P, van Rensburg AJ, Swanevelder S, Hanekom WA, Haslett PA, et al. Adjunctive thalidomide therapy for childhood tuberculous meningitis: results of a randomized study. Journal of Child Neurology. 2004;19(4):250-7. Not COPD patients. [pmid: 15163089].
Schonhofer B, Kerl J, Suchi S, Kohler D, Franklin KA. Effect of nasal valve dilation on effective CPAP level in obstructive sleep apnea. Respiratory Medicine. 2003;97(9):1001-5. Not COPD patients. [pmid: 14509553].
Schucher B, Zerbst J, Baumann HJ. Noninvasive mechanical ventilation in patients with stable severe COPD. Pneumologie. 2004;58(6):428-34. Not English language. [pmid: 15216436].
Schulze A. Respiratory mechanical unloading and proportional assist ventilation in infants. Acta Paediatrica Supplement. 2002;91(437):19-22. Review article. [pmid: 12200891].
Schumaker GL, Epstein SK. Managing acute respiratory failure during exacerbation of chronic obstructive pulmonary disease. Respiratory Care. 2004;49(7):766-82. Review article. [pmid: 15222909].
Sciurba FC. Medical management of chronic obstructive pulmonary disease. Chest Surgery Clinics of North America. 2003;13(4):615-29. Review article. [pmid: 14682598].
Sciurba FC. Physiologic similarities and differences between COPD and asthma. Chest. 2004;126(2 Suppl):117S-124S. Review article. [pmid: 15302772].
Scullion JE. Chronic obstructive pulmonary disease and community-based pharmacological care. British Journal of Community Nursing. 2004;9(3):97-101. Review article. [pmid: 15028994].
Seeger W, Schulz R. Inhalation combination therapy in chronic obstructive lung disease. TRISTAN-study. Internist. 2004;45(6):727-8. Not English language. [pmid: 15138641].
Sestini P, Renzoni E, Robinson S, Poole P, Ram FS. Short-acting beta 2 agonists for stable chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2002; (4)CD001495. Review article.
Sevransky JE, Haponik EF. Respiratory failure in elderly patients. Clinics in Geriatric Medicine. 2003;19(1):205-24. Review article. [pmid: 12735123].
Shaffer TH, Wolfson MR, Panitch HB. Airway structure, function and development in health and disease. Paediatric Anaesthesia. 2004;14(1):3-14. Review article. [pmid: 14717868].
Shioya T. Non-pharmacologic treatment in COPD. Nihon Kokyuki Gakkai Zasshi. 2004;42(8):717-23. Not English language. [pmid: 15455944].
Shmelev EI. Tiotropium bromide in the treatment of chronic obstructive lung disease. Terapevticheskii Arkhiv. 2003;75(12):69-72. Not English language. [pmid: 14959476].
Shochat T, Pillar G. Sleep apnoea in the older adult: pathophysiology, epidemiology, consequences and management. Drugs & Aging. 2003;20(8):551-60. Not COPD patients. [pmid: 12795623].
Shuster M, Nolan J, Barnes TA. Airway and ventilation management. Cardiology Clinics. 2002;20(1):23-35. Review article. [pmid: 11845543].
Siergiejko Z. Bronchoalveolar lavage and induced sputum in asthmatic and COPD patient. Polski Merkuriusz Lekarski. 2003;14(84):545-7. Not English language. [pmid: 14524267].
Silvanus MT, Groeben H, Peters J. Corticosteroids and inhaled salbutamol in patients with reversible airway obstruction markedly decrease the incidence of bronchospasm after tracheal intubation. Anesthesiology. 2004;100(5):1052-7. Less than 50 subjects per arm. [pmid: 15114199].
Similowski T, Cracco C, Duguet A, Derenne JP. Diagnosis and management of exacerbations and acute respiratory failure in patients with chronic obstructive pulmonary disease. Revue du Praticien. 2004;54(13):1438-44. Not English language. [pmid: 15497798].
Simmons P, Simmons M. Informed nursing practice: the administration of oxygen to patients with COPD. MEDSURG Nursing. 2004;13(2):82-5. Review article. [pmid: 15119419].
Simonds AK. Ethics and decision making in end stage lung disease. Thorax. 2003;58(3):272-7. Review article. [pmid: 12612311]. [pmcid: 1746620].
Simonds AK. Home ventilation. European Respiratory Journal - Supplement. 2003;47:38s-46s. Review article.
Simonds AK. Long-term ventilation in obstructive ventilatory disorders. Respiratory Care Clinics of North America. 2002;8(4):533-44. Review article. [pmid: 12602413].
Sin DD, Lacy P, York E, Man SF. Effects of fluticasone on systemic markers of inflammation in chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 2004;170(7):760-5. Less than 50 subjects per arm. [pmid: 15229100].
Sin DD, McAlister FA, Man SF, Anthonisen NR. Contemporary management of chronic obstructive pulmonary disease: scientific review. JAMA. 2003;290(17):2301-12. Review article. [pmid: 14600189].
Singh JM, Palda VA, Stanbrook MB, Chapman KR. Corticosteroid therapy for patients with acute exacerbations of chronic obstructive pulmonary disease: a systematic review. Archives of Internal Medicine. 2002;162(22):2527-36. Review article. [pmid: 12456224].
Singh SD, Whale C, Houghton N, Daley-Yates P, Kirby SM, Woodcock AA. Pharmacokinetics and systemic effects of inhaled fluticasone propionate in chronic obstructive pulmonary disease. British Journal of Clinical Pharmacology. 2003;55(4):375-81. Less than 50 subjects per arm. [pmid: 12680886]. [pmcid: 1884235].
Singh V, Khandelwal DC, Khandelwal R, Abusaria S. Pulmonary rehabilitation in patients with chronic obstructive pulmonary disease. Indian Journal of Chest Diseases & Allied Sciences. 2003;45(1):13-7. Less than 50 subjects per arm. [pmid: 12683707].
Sinuff T, Cook DJ. Health technology assessment in the ICU: noninvasive positive pressure ventilation for acute respiratory failure. Journal of Critical Care. 2003;18(1):59-67. Review article. [pmid: 12640616].
Sirak TE, Jelic S, Le Jemtel TH. Therapeutic update: non-selective beta- and alpha-adrenergic blockade in patients with coexistent chronic obstructive pulmonary disease and chronic heart failure. Journal of the American College of Cardiology. 2004;44(3):497-502. Review article. [pmid: 15358010].
Sitkauskiene B, Sakalauskas R, Malakauskas K, Lotvall J. Reversibility to a beta2-agonist in COPD: relationship to atopy and neutrophil activation. Respiratory Medicine. 2003;97(6):591-8. Not randomized controlled trial. [pmid: 12814141].
Smaldone GC. Aerosolized antibiotics in mechanically ventilated patients. Respiratory Care. 2004;49(6):635-9. Review article. [pmid: 15165298].
Smith PL, O'Donnell CP, Allan L, Schwartz AR. A physiologic comparison of nasal and oral positive airway pressure. Chest. 2003;123(3):689-94. Review article. [pmid: 12628864].
Smith T. Oxygen therapy for older people. Nursing Older People. 2004;16(5):22-8. Review article. [pmid: 15303515].
Smucny J, Flynn C, Becker L, Glazier R. Beta2-agonists for acute bronchitis. Cochrane Database of Systematic Reviews 2004; (1)CD001726. Review article.
Snider GL. Enhancement of exercise performance in COPD patients by hyperoxia: a call for research. Chest. 2002;122(5):1830-6. Review article. [pmid: 12426288].
Sonnad SS, Moyer CA, Patel S, Helman JI, Garetz SL, Chervin RD. A model to facilitate outcome assessment of obstructive sleep apnea. International Journal of Technology Assessment in Health Care. 2003;19(1):253-60. Review article. [pmid: 12701956].
Soroksky A, Stav D, Shpirer I. A pilot prospective, randomized, placebo-controlled trial of bilevel positive airway pressure in acute asthmatic attack. Chest. 2003;123(4):1018-25. Not COPD patients. [pmid: 12684289].
Soto FJ, Varkey B. Evidence-based approach to acute exacerbations of COPD. Current Opinion in Pulmonary Medicine. 2003;9(2):117-24. Review article. [pmid: 12574691].
Sovani MP, Whale CI, Tattersfield AE. A benefit-risk assessment of inhaled long-acting beta2-agonists in the management of obstructive pulmonary disease. Drug Safety. 2004;27(10):689-715. Review article. [pmid: 15350154].
Spencer S, Calverley PM, Burge PS, Jones PW. Impact of preventing exacerbations on deterioration of health status in COPD. European Respiratory Journal. 2004;23(5):698-702. Health status analysis of Burge (2000). [pmid: 15176682].
Spicuzza L, Bonfiglio C, Polosa R. Research applications and implications of adenosine in diseased airways. Trends in Pharmacological Sciences. 2003;24(8):409-13. Review article. [pmid: 12915050].
Spieker ED, Motzer SA. Sleep-disordered breathing in patients with heart failure: pathophysiology, assessment, and management. Journal of the American Academy of Nurse Practitioners. 2003;15(11):487-93. Review article. [pmid: 14685985].
Sposato B, Mazzei L, De Angelis G. Nocturnal desaturation in chronic obstructive pulmonary disease. Recenti Progressi in Medicina. 2002;93(12):686-94. Not English language. [pmid: 12557800].
Spruit MA, Gosselink R, Troosters T, De Paepe K, Decramer M. Resistance versus endurance training in patients with COPD and peripheral muscle weakness. European Respiratory Journal. 2002;19(6):1072-8. Less than 50 subjects per arm. [pmid: 12108859].
Spruit MA, Troosters T, Trappenburg JC, Decramer M, Gosselink R. Exercise training during rehabilitation of patients with COPD: a current perspective. Patient Education & Counseling. 2004;52(3):243-8. Review article. [pmid: 14998593].
Staevska MT, Mandajieva MA, Dimitrov VD. Rhinitis and sleep apnea. Current Allergy & Asthma Reports. 2004;4(3):193-9. Review article. [pmid: 15056401].
Stannard W, O'Callaghan C. Management of croup. Paediatric Drugs. 2002;4(4):231-40. Review article. [pmid: 11960512].
Steier J, Trammer T, Cloes RM, Petro W. Optical feedback training of inhalation with Autohaler and Turbuhaler in COPD patients. Lung. 2003;181(4):183-92. No clinical outcomes. [pmid: 14692558].
Stein TP, Wade CE, Investigator: Stein TP, Wade CE. Protein turnover in atrophying muscle: from nutritional intervention to microarray expression analysis. Current Opinion in Clinical Nutrition & Metabolic Care. 2003; 6(1):95-102. Review article.
Steiner MC, Barton RL, Singh SJ, Morgan MD. Nutritional enhancement of exercise performance in chronic obstructive pulmonary disease: a randomised controlled trial. Thorax. 2003;58(9):745-51. Less than 50 subjects per arm. [pmid: 12947128]. [pmcid: 1746806].
Stepnowsky CJ Jr, Moore PJ. Nasal CPAP treatment for obstructive sleep apnea: developing a new perspective on dosing strategies and compliance. Journal of Psychosomatic Research. 2003;54(6):599-605. Review article. [pmid: 12781315].
Steurer-Stey C. Inhalation of beta-2 agonists or corticosteroids as single drugs in comparison with combination therapy of patients with COPD. Schweizerische Rundschau fur Medizin Praxis. 2003;92(3132):1324-5. Not English language. [pmid: 12934343].
Stevens N. Inhaler devices for asthma and COPD: choice and technique. Professional Nurse. 2003;18(11):641-5. Review article.
Stevens TP, Blennow M, Soll RF. Early surfactant administration with brief ventilation vs selective surfactant and continued mechanical ventilation for preterm infants with or at risk for RDS. Cochrane Database of Systematic Reviews. 2002; (2)CD003063. Review article.
Strollo PJ Jr. Indications for treatment of obstructive sleep apnea in adults. Clinics in Chest Medicine. 2003;24(2):307-13. Review article. [pmid: 12800786].
Stulbarg MS, Carrieri-Kohlman V, Demir-Deviren S, Nguyen HQ, Adams L, Tsang AH, et al. Exercise training improves outcomes of a dyspnea self-management program. Journal of Cardiopulmonary Rehabilitation. 2002;22(2):109-21. Less than 50 subjects per arm. [pmid: 11984209].
Suman OE, Mlcak RP, Herndon DN. Effect of exercise training on pulmonary function in children with thermal injury. Journal of Burn Care & Rehabilitation. 2002;23(4):288-93. Not COPD patients. [pmid: 12142585].
Sutherland ER, Allmers H, Ayas NT, Venn AJ, Martin RJ. Inhaled corticosteroids reduce the progression of airflow limitation in chronic obstructive pulmonary disease: a meta-analysis. Thorax. 2003;58(11):937-41. Review article. [pmid: 14586043]. [pmcid: 1746510].
Sutherland ER, Cherniack RM. Management of chronic obstructive pulmonary disease. New England Journal of Medicine. 2004;350(26):2689-97. Review article. [pmid: 15215485].
Svatikova A, Wolk R, Shamsuzzaman AS, Kara T, Olson EJ, Somers VK. Serum amyloid a in obstructive sleep apnea. Circulation. 2003;108(12):1451-4. Not COPD patients. [pmid: 12952844].
Takahashi Y, Fukuda T. The indication and practice of home oxygen therapy. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2003;61(12):2193-9. Not English language. [pmid: 14674332].
Tan YK, L'Estrange PR, Luo YM, Smith C, Grant HR, Simonds AK, et al. Mandibular advancement splints and continuous positive airway pressure in patients with obstructive sleep apnoea: a randomized cross-over trial. European Journal of Orthodontics. 2002;24(3):239-49. Not COPD patients. [pmid: 12143088].
Tashkin DP, Cooper CB. The role of long-acting bronchodilators in the management of stable COPD. Chest. 2004;125(1):249-59. Review article. [pmid: 14718448].
Taube C, Kanniess F, Gronke L, Richter K, Mucke M, Paasch K, et al. Reproducibility of forced inspiratory and expiratory volumes after bronchodilation in patients with COPD or asthma. Respiratory Medicine. 2003;97(5):568-77. Less than 50 subjects per arm. [pmid: 12735677].
Teague WG. Noninvasive ventilation in the pediatric intensive care unit for children with acute respiratory failure. Pediatric Pulmonology. 2003;35(6):418-26. Review article. [pmid: 12746937].
Tennant RC, Erin EM, Barnes PJ, Hansel TT. Long-acting beta 2-adrenoceptor agonists or tiotropium bromide for patients with COPD: is combination therapy justified?. Current Opinion in Pharmacology. 2003;3(3):270-6. Review article. [pmid: 12810191].
Thill PJ, McGuire JK, Baden HP, Green TP, Checchia PA. Noninvasive positive-pressure ventilation in children with lower airway obstruction. Pediatric Critical Care Medicine. 2004;5(4):337-42. Not adult patients. [pmid: 15215002].
Thompson WH, Carvalho P, Souza JP, Charan NB. Controlled trial of inhaled fluticasone propionate in moderate to severe COPD. Lung. 2002;180(4):191-201. Less than 50 subjects per arm. [pmid: 12391509].
Thorsteinsson A, Werner O, Jonmarker C, Larsson A. Airway closure in anesthetized infants and children: influence of inspiratory pressures and volumes. Acta Anaesthesiologica Scandinavica. 2002;46(5):529-36. Not COPD patients. [pmid: 12027847].
Thys F, Roeseler J, Reynaert M, Liistro G, Rodenstein DO. Noninvasive ventilation for acute respiratory failure: a prospective randomised placebo-controlled trial. European Respiratory Journal. 2002;20(3):545-55. Less than 50 subjects per arm. [pmid: 12358327].
Tobias JD. Anaesthesia for neonatal thoracic surgery. Clinical Anaesthesiology. 2004;18(2):303-20. Review article. [pmid: 15171506].
Tobyn M, Staniforth JN, Morton D, Harmer Q, Newton ME. Active and intelligent inhaler device development. International Journal of Pharmaceutics. 2004;277(12):31-7. Review article. [pmid: 15158967].
Toma TP, Polkey MI, Goldstraw PG, Morgan C, Geddes DM. Methodological aspects of bronchoscopic lung volume reduction with a proprietary system. Respiration. 2003;70(6):658-64. Review article. [pmid: 14732802].
Toyoshima H, Yoshida M. Management of patients with stable COPD. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2003;61(12):2163-9. Not English language. [pmid: 14674327].
Troosters T, Gayan-Ramirez G, Pitta F, Gosselin N, Gosselink R, Decramer M. Exercise effort training for COPD: physiological basis and results. Revue des Maladies Respiratoires. 2004;21(2 Pt 1):319-27. Not English language. [pmid: 15211239].
Trotman-Dickenson B. Radiology in the intensive care unit (part 2). Journal of Intensive Care Medicine. 2003;18(5):239-52. Review article. [pmid: 15035758].
Trow TK. Lung-volume reduction surgery for severe emphysema: appraisal of its current status. Current Opinion in Pulmonary Medicine. 2004;10(2):128-32. Review article. [pmid: 15021182].
Umlauf MG, Chasens ER. Bedwetting--not always what it seems: a sign of sleep-disordered breathing in children. Journal for Specialists in Pediatric Nursing: JSPN. 2003;8(1):22-30. Review article. [pmid: 12715403].
van Beurden WJ, Harff GA, Dekhuijzen PN, van der Poel-Smet SM, Smeenk FW. Effects of inhaled corticosteroids with different lung deposition on exhaled hydrogen peroxide in stable COPD patients. Respiration. 2003;70(3):242-8. Less than 50 subjects per arm. [pmid: 12915742].
van der Valk P, Monninkhof E, van ver Palen J, Zielhuis G, van Herwaarden C. Management of stable COPD. Patient Education & Counseling. 2004;52(3):225-9. Review article. [pmid: 14998590].
van Grunsven P, Schermer T, Akkermans R, Albers M, van den Boom G, van Schayck O, et al. Short- and long-term efficacy of fluticasone propionate in subjects with early signs and symptoms of chronic obstructive pulmonary disease. Results of the DIMCA study. Respiratory Medicine. 2003;97(12):1303-12. Less than 50 subjects per arm. [pmid: 14682412].
van Noord JA, Smeets JJ, Custers FL, Korducki L, Cornelissen PJ. Pharmacodynamic steady state of tiotropium in patients with chronic obstructive pulmonary disease. European Respiratory Journal. 2002;19(4):639-44. Less than 50 subjects per arm. [pmid: 11998992].
van Schayck CP, Chavannes NH. Detection of asthma and chronic obstructive pulmonary disease in primary care. European Respiratory Journal - Supplement. 2003;39:16s-22s. Review article.
van Schayck CP, Dekhuijzen PN. Inhalation corticosteroids for COPD: possible less mortality. Nederlands Tijdschrift voor Geneeskunde. 2003;147(39):1896-9. Not English language. [pmid: 14560686].
van 't Hul A, Kwakkel G, Gosselink R. The acute effects of noninvasive ventilatory support during exercise on exercise endurance and dyspnea in patients with chronic obstructive pulmonary disease: a systematic review. Journal of Cardiopulmonary Rehabilitation. 2002;22(4):290-7. Review article. [pmid: 12202851].
van Weel C. Underdiagnosis of asthma and COPD: is the general practitioner to blame?. Monaldi Archives for Chest Disease. 2002;57(1):65-8. Review article. [pmid: 12174705].
Vaquerizo MJ, Casan P, Castillo J, Perpina M, Sanchis J, Sobradillo V, et al. Effect of montelukast added to inhaled budesonide on control of mild to moderate asthma. Thorax. 2003;58(3):204-10. Not COPD patients. [pmid: 12612294]. [pmcid: 1746619].
Varekojis SM, Douce FH, Flucke RL, Filbrun DA, Tice JS, McCoy KS, et al. A comparison of the therapeutic effectiveness of and preference for postural drainage and percussion, intrapulmonary percussive ventilation, and high-frequency chest wall compression in hospitalized cystic fibrosis patients. Respiratory Care. 2003;48(1):24-8. Not COPD patients. [pmid: 12556258].
Verhoeven GT, Hegmans JP, Mulder PG, Bogaard JM, Hoogsteden HC, Prins JB. Effects of fluticasone propionate in COPD patients with bronchial hyperresponsiveness. Thorax. 2002;57(8):694-700. Less than 50 subjects per arm. [pmid: 12149529]. [pmcid: 1746396].
Verstappen WH, van der Weijden T, Sijbrandij J, Smeele I, Hermsen J, Grimshaw J, et al. Effect of a practice-based strategy on test ordering performance of primary care physicians: a randomized trial. JAMA. 2003;289(18):2407-12. No clinical outcomes. [pmid: 12746365].
Vestbo J. Combined salmeterol and fluticasone in the treatment of chronic obstructive pulmonary disease. Ugeskrift for Laeger. 2004;166(4):271-4. Not English language. [pmid: 14964108].
Victor LD. Treatment of obstructive sleep apnea in primary care. American Family Physician. 2004;69(3):561-8. Review article. [pmid: 14971838].
Vieillard-Baron A, Jardin F. The issue of dynamic hyperinflation in acute respiratory distress syndrome patients. European Respiratory Journal - Supplement. 2003;42:43s-47s. Review article.
Vitacca M. Therapist driven protocols. Monaldi Archives for Chest Disease. 2003;59(4):342-4. Review article. [pmid: 15148851].
Vitacca M, Barbano L, D'Anna S, Porta R, Bianchi L, Ambrosino N. Comparison of five bilevel pressure ventilators in patients with chronic ventilatory failure: a physiologic study. Chest. 2002;122(6):2105-14. Less than 50 subjects per arm. [pmid: 12475854].
Vitacca M, Bianchi L, Zanotti E, Vianello A, Barbano L, Porta R, et al. Assessment of physiologic variables and subjective comfort under different levels of pressure support ventilation. Chest. 2004;126(3):851-9. Less than 50 subjects per arm. [pmid: 15364766].
Vogelmeier C. Chronic obstructive lung disease. Internist. 2003; 44 Suppl 1:S16–22, S24–7. Not English language.
Vogiatzis I, Nanas S, Roussos C. Interval training as an alternative modality to continuous exercise in patients with COPD. European Respiratory Journal. 2002;20(1):12-9. Less than 50 subjects per arm. [pmid: 12166558].
Vorona RD, Ware JC. Sleep disordered breathing and driving risk. Current Opinion in Pulmonary Medicine. 2002;8(6):506-10. Review article. [pmid: 12394158].
Voshaar T. Inhalation therapy: techniques and use of devices--main mistakes. Medizinische Klinik. 2002;97(Suppl 2):2-6. Not English language. [pmid: 12593174].
Vrijlandt EJ, Duiverman EJ, Bos AF. Chronic lung disease of the neonate; pathophysiology and treatment after the first weeks of life. Nederlands Tijdschrift voor Geneeskunde. 2003;147(49):2412-7. Not English language. [pmid: 14694549].
Wadell K, Sundelin G, Henriksson-Larsen K, Lundgren R. High intensity physical group training in water--an effective training modality for patients with COPD. Respiratory Medicine. 2004;98(5):428-38. Less than 50 subjects per arm. [pmid: 15139572].
Ward C, Pais M, Bish R, Reid D, Feltis B, Johns D, et al. Airway inflammation, basement membrane thickening and bronchial hyperresponsiveness in asthma. Thorax. 2002;57(4):309-16. Not COPD patients. [pmid: 11923548]. [pmcid: 1746305].
Waters KA, McBrien F, Stewart P, Hinder M, Wharton S. Effects of OSA, inhalational anesthesia, and fentanyl on the airway and ventilation of children. Journal of Applied Physiology. 2002;92(5):1987-94. Not COPD patients. [pmid: 11960949].
Wedzicha JA. Outcome of long-term noninvasive positive-pressure ventilation. Respiratory Care Clinics of North America. 2002;8(4):559-73. Review article. [pmid: 12602415].
Wedzicha JA, Donaldson GC. Exacerbations of chronic obstructive pulmonary disease. Respiratory Care. 2003;48(12):1204-13. Review article. [pmid: 14651761].
Wedzicha JA, Muir JF. Noninvasive ventilation in chronic obstructive pulmonary disease, bronchiectasis and cystic fibrosis. European Respiratory Journal. 2002;20(3):777-84. Review article. [pmid: 12358358].
Weiner P, Magadle R, Beckerman M, Weiner M, Berar-Yanay N. Maintenance of inspiratory muscle training in COPD patients: one year follow-up. European Respiratory Journal. 2004;23(1):61-5. Less than 50 subjects per arm. [pmid: 14738232].
Weiner P, Magadle R, Beckerman M, Weiner M, Berar-Yanay N. Specific expiratory muscle training in COPD. Chest. 2003;124(2):468-73. Less than 50 subjects per arm. [pmid: 12907530].
Weisman LE. Populations at risk for developing respiratory syncytial virus and risk factors for respiratory syncytial virus severity: infants with predisposing conditions. Pediatric Infectious Disease Journal. 2003;22(2 Suppl):S33-7. Review article. [pmid: 12671450].
Weitzenblum E, Chaouat A, Kessler R. Long-term oxygen therapy for chronic respiratory failure. Rationale, indications, modalities. Revue de Pneumologie Clinique. 2002;58(4 Pt 1):195-212. Not English language. [pmid: 12407284].
Wellingham J, Tracey J, Rea H, Gribben B. Chronic Care Management Programme. The development and implementation of the Chronic Care Management Programme in Counties Manukau. New Zealand Medical Journal. 2003;116(1169):U327. Not COPD patients. [pmid: 12601404].
Welte T. Fixed Combination of a Long-Acting beta(2)-Agonist and an Inhaled Steroid. A Therapeutic Option for COPD?. Medizinische Klinik. 2003;98(10):552-61. Not English language. [pmid: 14586509].
Welte T. Noninvasive ventilation in the intensive care unit -- is it still negligible?. Wiener Klinische Wochenschrift. 2003;115(34):89-98. Not English language. [pmid: 12674684].
Welte T, Gillissen A. Do we need inhalative steroids in chronic COPD patients?. Medizinische Klinik. 2002;97(Suppl 2):15-9. Not English language. [pmid: 12593177].
Wettengel R. Longterm treatment of COPD with theophylline--still a valuable option?. Pneumologie. 2003;57(10):598-605. Not English language. [pmid: 14569531].
White J, Cates C, Wright J. Continuous positive airways pressure for obstructive sleep apnoea. Cochrane Database of Systematic Reviews. 2002; (2)CD001106. Review article.
Whitford H, Walters EH, Levvey B, Kotsimbos T, Orsida B, Ward C, et al. Addition of inhaled corticosteroids to systemic immunosuppression after lung transplantation: a double-blind, placebo-controlled trial. Transplantation. 2002;73(11):1793-9. Not COPD patients. [pmid: 12085003].
Wiest GH, Harsch IA, Fuchs FS, Kitzbichler S, Bogner K, Brueckl WM, et al. Initiation of CPAP therapy for OSA: does prophylactic humidification during CPAP pressure titration improve initial patient acceptance and comfort?. Respiration. 2002;69(5):406-12. Not COPD patients. [pmid: 12232447].
Wijkstra PJ. Non-invasive positive pressure ventilation (NIPPV) in stable patients with chronic obstructive pulmonary disease (COPD). Respiratory Medicine. 2003;97(10):1086-93. Review article. [pmid: 14561015].
Wijkstra PJ, Lacasse Y, Guyatt GH, Casanova C, Gay PC, Meecham Jones J, et al. A meta-analysis of nocturnal noninvasive positive pressure ventilation in patients with stable COPD. Chest. 2003;124(1):337-43. Review article. [pmid: 12853542].
Wijkstra PJ, Lacasse Y, Guyatt GH, Goldstein RS. Nocturnal non-invasive positive pressure ventilation for stable chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2002; (3)CD002878. Review article.
Williams G. Recently published papers: a number of treatment controversies. Critical Care (London). 2003;7(1):16-8. Review article.
Winck JC, Vitacca M, Morais A, Barbano L, Porta R, Teixeira-Pinto A, et al. Tolerance and physiologic effects of nocturnal mask pressure support vs proportional assist ventilation in chronic ventilatory failure. Chest. 2004;126(2):382-8. Less than 50 subjects per arm. [pmid: 15302721].
Windisch W, Freidel K, Schucher B, Baumann H, Wiebel M, Matthys H, et al. The Severe Respiratory Insufficiency (SRI) Questionnaire: a specific measure of health-related quality of life in patients receiving home mechanical ventilation. Journal of Clinical Epidemiology. 2003;56(8):752-9. Not randomized controlled trial. [pmid: 12954467].
Wisniewski A. Chronic bronchitis and emphysema: clearing the air. Nursing. 2003;33(5):46-9. Review article. [pmid: 12792571].
Witek TJ Jr, Mahler DA. Meaningful effect size and patterns of response of the transition dyspnea index. Journal of Clinical Epidemiology. 2003;56(3):248-55. Retrospective analysis. [pmid: 12725879].
Wood-Baker R. Is there a role for systemic corticosteroids in the management of stable chronic obstructive pulmonary disease?. American Journal of Respiratory Medicine. 2003;2(6):451-8. Review article. [pmid: 14719984].
Woodson BT, Steward DL, Weaver EM, Javaheri S. A randomized trial of temperature-controlled radiofrequency, continuous positive airway pressure, and placebo for obstructive sleep apnea syndrome. Otolaryngology - Head & Neck Surgery. 2003;128(6):848-61. Not COPD patients. [pmid: 12825037].
Worth H, Dhein Y. Does patient education modify behaviour in the management of COPD?. Patient Education & Counseling. 2004;52(3):267-70. Review article. [pmid: 14998596].
Wouters EF. Management of severe COPD. Lancet. 2004;364(9437):883-95. Review article. [pmid: 15351196].
Wright J, Brocklebank D, Ram F. Inhaler devices for the treatment of asthma and chronic obstructive airways disease (COPD). Quality & Safety in Health Care. 2002;11(4):376-82. Review article. [pmid: 12468702]. [pmcid: 1758018].
Wysocki M, Richard JC, Meshaka P. Noninvasive proportional assist ventilation compared with noninvasive pressure support ventilation in hypercapnic acute respiratory failure. Critical Care Medicine. 2002;30(2):323-9. Not COPD patients. [pmid: 11889302].
Yamaguchi K. Pharmacologic treatment of stable COPD. Nihon Kokyuki Gakkai Zasshi. 2004;42(8):710-6. Not English language. [pmid: 15455943].
Yang SC, Yang SP. Effects of inspiratory flow waveforms on lung mechanics, gas exchange, and respiratory metabolism in COPD patients during mechanical ventilation. Chest. 2002;122(6):2096-104. No clinical outcomes. [pmid: 12475853].
Yantis MA. Obstructive sleep apnea syndrome. AJN, American Journal of Nursing. 2002;102(6):83-85. Review article.
Yernault JC, Sternon J. The choice and administration of corticoids in COPD. Revue Medicale de Bruxelles. 2002;23(2):96-101. Not English language. [pmid: 12056065].
Yohannes AM, Connolly MJ. Early mobilization with walking aids following hospital admission with acute exacerbation of chronic obstructive pulmonary disease. Clinical Rehabilitation. 2003;17(5):465-71. Less than 50 subjects per arm. [pmid: 12952150].
Yohannes AM, Hardy CC. Treatment of chronic obstructive pulmonary disease in older patients: a practical guide. Drugs & Aging. 2003;20(3):209-28. Review article. [pmid: 12578401].
Zaba R. Movement rehabilitation, psychotherapy and respiratory rehabilitation in patients with chronic obstructive pulmonary disease. Wiadomosci Lekarskie. 2002;55(Suppl 1):603-8. Not English language. [pmid: 15002310].
Zanotti E, Felicetti G, Maini M, Fracchia C. Peripheral muscle strength training in bed-bound patients with COPD receiving mechanical ventilation: effect of electrical stimulation. Chest. 2003;124(1):292-6. Less than 50 subjects per arm. [pmid: 12853536].
Zhong NS, Zeng GQ. Our strategies for fighting severe acute respiratory syndrome (SARS). American Journal of Respiratory & Critical Care Medicine. 2003;168(1):7-9. Review article. [pmid: 12773318].
Ziedalski TM, Sankaranarayanan V, Chitkara RK. Advances in the management of chronic obstructive pulmonary disease. Expert Opinion on Pharmacotherapy. 2003;4(7):1063-82. Review article. [pmid: 12831334].
Zielinski J. Pulmonary gas exchange during sleep in patients with airflow limitation undergoing long-term oxygen therapy. Respiratory Care. 2002;47(8):876-8. Review article. [pmid: 12162796].
Ziment I, Yick D. Treatment of chronic obstructive pulmonary disease. Journal of the American Medical Directors Association. 2003;4(5 Suppl):S121-6. Review article. [pmid: 14501809].