# References and Included Studies

1 Murray CJ, Lopez AD. Alternative projections of mortality and disability by cause 1990-2020: Global Burden of Disease Study. Lancet. May. 1997;349(9064):1498-504. [pmid: 9167458].
2 Sullivan SD, Ramsey SD, Lee TA. The economic burden of COPD. Chest. Feb. 2000;117(2 Suppl):5S-9S. [pmid: 10673466].
3 Coultas DB, Mapel D, Gagnon R, et al. The health impact of undiagnosed airflow obstruction in a national sample of United States adults. Am J Respir Crit Care Med. Aug. 2001;164(3):372-7. [pmid: 11500335].
4 Krahn M, Chapman KR. Economic issues in the use of office spirometry for lung health assessment. Can Respir J. Sep. 2003;10(6):320-6. [pmid: 14530824].
5 National Heart Lung and Blood Institute. Chronic Obstructive Pulmonary Disease (COPD) Data Fact Sheet. March. Available at: http://www.nhlbi.nih.gov/health/public/lung/other/copd_fact.pdf.
6 Global Initiative for Chronic Obstructive Lung Disease. Global strategy for the diagnosis, management, and prevention of chronic obstructive pulmonary disease. Available at: http://www.goldcopd.com/revised.pdf, 2004.
7 Calverley PM, Burge PS, Spencer S, et al. Bronchodilator reversibility testing in chronic obstructive pulmonary disease. Thorax. Aug. 2003;58(8):659-64. [pmid: 12885978]. [pmcid: 1746778].
8 Global Initiative for Chronic Obstructive Lung Disease. Global Initiative for Chronic Obstructive Lung Disease. Available at: http://www.goldcopd.com.
9 Sin DD, McAlister FA, Man SF, et al. Contemporary management of chronic obstructive pulmonary disease: scientific review. JAMA. Nov. 2003;290(17):2301-12. [pmid: 14600189].
10 Wilson CB, Jones PW, O'Leary CJ, et al. Validation of the St. George's Respiratory Questionnaire in bronchiectasis. Am J Respir Crit Care Med. Aug. 1997;156(2 Pt 1):536-41. [pmid: 9279236].
11 National Lung Health Education Program. Spirometry. 2002 Jan. Available at: http://www.nlhep.org/spirom1.html.
12 Redelmeier DA, Tan SH, Booth GL. The treatment of unrelated disorders in patients with chronic medical diseases. N Engl J Med. May. 1998;338(21):1516-20. [pmid: 9593791].
13 Hankinson JL, Odencrantz JR, Fedan KB. Spirometric reference values from a sample of the general U.S. population. Am J Respir Crit Care Med. Jan. 1999;159(1):179-87. [pmid: 9872837].
14 Schwartz LM, Woloshin S. Changing disease definitions: implications for disease prevalence. Analysis of the Third National Health and Nutrition Examination Survey, 1988-1994. Effective Clinical Practice. 1999;2(2):76-85. [pmid: 10538480].
15 Kanner RE, Connett JE, Williams DE, et al. Effects of randomized assignment to a smoking cessation intervention and changes in smoking habits on respiratory symptoms in smokers with early chronic obstructive pulmonary disease: the Lung Health Study. Am J Med. Apr. 1999;106(4):410-6. [pmid: 10225243].
16 Anthonisen NR, Connett JE, Murray RP. Smoking and lung function of Lung Health Study participants after 11 years. Am J Respir Crit Care Med. Sep 1. 2002;166(5):675-9. [pmid: 12204864].
17 Fiore MC, Bailey WC, Cohen SJ, et al. Treating Tobacco Use and Dependence. Clinical Practice Guideline. U.S. Department of Health and Human Services. Public Health Service. 2000 June. Available at: http://www.surgeongeneral.gov/tobacco/treating_tobacco_use.pdf, 2004 (http://www.surgeongeneral.gov/tobacco/treating_tobacco_use.pdf).
18 National Center for Chronic Disease Prevention and Health Promotion. Smoking Prevalence Among U.S. Adults. 2004 June. Available at: http://www.cdc.gov/tobacco/research_data/adults_prev/prevali.htm, 2004.
19 Anthonisen NR, Connett JE, Kiley JP, et al. Effects of smoking intervention and the use of an inhaled anticholinergic bronchodilator on the rate of decline of FEV1. The Lung Health Study. JAMA. Nov 16. 1994;272(19):1497-505. [pmid: 7966841].
20 Schulz KF. Assessing allocation concealment and blinding in randomised controlled trials: Why bother?. Evid Based Nurs. Jan. 2001;4(1):4-6. [pmid: 11707879].
21 Meecham Jones DJ, Paul EA, Jones PW, et al. Nasal pressure support ventilation plus oxygen compared with oxygen therapy alone in hypercapnic COPD. Am J Respir Crit Care Med. Aug. 1995;152(2):538-44. [pmid: 7633704].
22 Spencer S, Calverley PM, Sherwood Burge P, et al. Health status deterioration in patients with chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Jan. 2001;163(1):122-8. [pmid: 11208636].
23 Appleton S, Poole P, Smith B, et al. Long-acting beta2-agonists for chronic obstructive pulmonary disease patients with poorly reversible airflow limitation. Cochrane Database of Systematic Reviews. 2002(3):CD001104.
24 Sestini P, Renzoni E, Robinson S, et al. Short-acting beta 2 agonists for stable chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2002(4):CD001495.
25 McCrory DC, Brown CD. Anti-cholinergic bronchodilators versus beta2-sympathomimetic agents for acute exacerbations of chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2002(4):CD003900.
26 Wood-Baker R. Is there a role for systemic corticosteroids in the management of stable chronic obstructive pulmonary disease?. American Journal of Respiratory Medicine. 2003;2(6):451-8. [pmid: 14719984].
27 Nannini L, Cates CJ, Lasserson TJ, et al. Combined corticosteroid and longacting beta-agonist in one inhaler for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2004(3):CD003794.
28 Barr RG, Rowe BH, Camargo CA Jr. Methylxanthines for exacerbations of chronic obstructive pulmonary disease: meta-analysis of randomised trials. BMJ. Sep 20. 2003;327(7416):643. [pmid: 14500434]. [pmcid: 196388].
29 Lacasse Y, Brosseau L, Milne S, et al. Pulmonary rehabilitation for chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2002(3):CD003793.
30 Cambach W, Wagenaar RC, Koelman TW, et al. The long-term effects of pulmonary rehabilitation in patients with asthma and chronic obstructive pulmonary disease: a research synthesis. Arch Phys Med Rehabil. Jan. 1999;80(1):103-11. [pmid: 9915381].
31 Lacasse Y, Wong E, Guyatt GH, et al. Meta-analysis of respiratory rehabilitation in chronic obstructive pulmonary disease. Lancet. Oct. 1996;348(9035):1115-9. [pmid: 8888163].
32 Lotters F, van Tol B, Kwakkel G, et al. Effects of controlled inspiratory muscle training in patients with COPD: a meta-analysis. Eur Respir J. Sep. 2002;20(3):570-6. [pmid: 12358330].
33 Smith B, Appleton S, Adams R, et al. Home care by outreach nursing for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2001(3):CD000994.
34 Wijkstra PJ. Non-invasive positive pressure ventilation (NIPPV) in stable patients with chronic obstructive pulmonary disease (COPD). Respiratory Medicine. Oct. 2003;97(10):1086-93. [pmid: 14561015].
35 Ram FS, Lightowler JV, Wedzicha JA. Non-invasive positive pressure ventilation for treatment of respiratory failure due to exacerbations of chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2003(1):CD004104.
36 van 't Hul A, Kwakkel G, Gosselink R. The acute effects of noninvasive ventilatory support during exercise on exercise endurance and dyspnea in patients with chronic obstructive pulmonary disease: a systematic review. Journal of Cardiopulmonary Rehabilitation. Jul–Aug. 2002;22(4):290-7. [pmid: 12202851].
37 Keenan SP, Gregor J, Sibbald WJ, et al. Noninvasive positive pressure ventilation in the setting of severe, acute exacerbations of chronic obstructive pulmonary disease: more effective and less expensive. Crit Care Med. Jun. 2000;28(6):2094-102. [pmid: 10890671].
38 Burge PS, Calverley PM, Jones PW, et al. Prednisolone response in patients with chronic obstructive pulmonary disease: results from the ISOLDE study. Thorax. Aug. 2003;58(8):654-8. [pmid: 12885977]. [pmcid: 1746769].
39 Hermiz O, Comino E, Marks G, et al. Randomised controlled trial of home based care of patients with chronic obstructive pulmonary disease. BMJ. Oct. 2002;325(7370):938. [pmid: 12399344]. [pmcid: 130059].
40 O'Brien JA, Ward AJ, Jones MK, et al. Utilization of health care services by patients with chronic obstructive pulmonary disease. Respiratory Medicine. Jan. 2003;97(Suppl A):S53-8. [pmid: 12564611].
41 Jones PW, Wilson K, Sondhi S. Cost-effectiveness of salmeterol in patients with chronic obstructive pulmonary disease: an economic evaluation. Respiratory Medicine. Jan. 2003;97(1):20-6. [pmid: 12556006].
42 Plant PK, Owen JL, Parrott S, et al. Cost effectiveness of ward based non-invasive ventilation for acute exacerbations of chronic obstructive pulmonary disease: economic analysis of randomised controlled trial. BMJ. May. 2003;326(7396):956. [pmid: 12727767]. [pmcid: 153850].
43 Pauwels RA, Buist AS, Calverley PM, et al. Global strategy for the diagnosis, management, and prevention of chronic obstructive pulmonary disease. NHLBI/WHO Global Initiative for Chronic Obstructive Lung Disease (GOLD) Workshop summary. Am J Respir Crit Care Med. Apr. 2001;163(5):1256-76. [pmid: 11316667].
44 Weingarten SR, Henning JM, Badamgarav E, et al. Interventions used in disease management programmes for patients with chronic illness-which ones work? Meta-analysis of published reports. BMJ. Oct. 2002;325(7370):925. [pmid: 12399340]. [pmcid: 130055].
45 DerSimonian R, Laird N. Meta analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
46 Jones PW, Bosh TK. Quality of life changes in COPD patients treated with salmeterol. Am J Respir Crit Care Med. Apr. 1997;155(4):1283-9. [pmid: 9105068].
47 Jones PW. Health status measurement in chronic obstructive pulmonary disease. Thorax. Nov. 2001;56(11):880-7. [pmid: 11641515]. [pmcid: 1745959].
48 Holleman DR Jr, Simel DL. Does the clinical examination predict airflow limitation?. JAMA. Jan. 1995;273(4):313-9. [pmid: 7815660].
49 Marini JJ, Pierson DJ, Hudson LD, et al. The significance of wheezing in chronic airflow obstruction. Am Rev Respir Dis. Nov. 1979;120(5):1069-72. [pmid: 507523].
50 King DK, Thompson BT, Johnson DC. Wheezing on maximal forced exhalation in the diagnosis of atypical asthma. Lack of sensitivity and specificity. Ann Intern Med. Mar. 1989;110(6):451-5. [pmid: 2645821].
51 Workum P, Holford SK, Delbono EA, et al. The prevalence and character of crackles (rales) in young women without significant lung disease. Am Rev Respir Dis. Nov. 1982;126(5):921-3. [pmid: 7149458].
52 Holleman DR Jr, Simel DL, Goldberg JS. Diagnosis of obstructive airways disease from the clinical examination. J Gen Intern Med. Feb. 1993;8(2):63-8. [pmid: 8441077].
53 Foxman B, Lohr KN, Brook RH, et al. Conceptualization and Measurement of Physiologic Health for Adults. Vol. 8, Chronic Obstructive Airway Disease. Santa Monica, CA: RAND Health Communications; 1982.
54 Lancaster T, Stead L, Silagy C, et al. Effectiveness of interventions to help people stop smoking: findings from the Cochrane Library. BMJ. Aug. 2000;321(7257):355-8. [pmid: 10926597]. [pmcid: 1118332].
55 Silagy C, Stead LF. Physician advice for smoking cessation. Cochrane Database Syst Rev. 2004(2):CD000165.
56 Kottke TE, Battista RN, DeFriese GH, et al. Attributes of successful smoking cessation interventions in medical practice. A meta-analysis of 39 controlled trials. JAMA. May. 1988;259(19):2883-9. [pmid: 3367456].
57 Lerman C, Orleans CT, Engstrom PF. Biological markers in smoking cessation treatment. Semin Oncol. Aug. 1993;20(4):359-67. [pmid: 8342065].
58 O'Malley PG, Feuerstein IM, Taylor AJ. Impact of electron beam tomography, with or without case management, on motivation, behavioral change, and cardiovascular risk profile: a randomized controlled trial. JAMA. May. 2003;289(17):2215-23. [pmid: 12734132].
59 McClure JB. Are biomarkers a useful aid in smoking cessation? A review and analysis of the literature. Behav Med. Spring. 2001;27(1):37-47. [pmid: 11575171].
60 McBride CM, Halabi S, Bepler G, et al. Maximizing the motivational impact of feedback of lung cancer susceptibility on smokers' desire to quit. J Health Commun. Jul–Sep. 2000;5(3):229-41. [pmid: 11185023].
61 Scott RR, Mayer JA, Denier CA, et al. Long-term smoking status of cardiac patients following symptom-specific cessation advice. Addict Behav. 1990;15(6):549-52. [pmid: 2075852].
62 Kilburn KH, Warshaw RH. Effects of individually motivating smoking cessation in male blue collar workers. Am J Public Health. Nov. 1990;80(11):1334-7. [pmid: 2240300]. [pmcid: 1404897].
63 Cox LS, Clark MM, Jett JR, et al. Change in smoking status after spiral chest computed tomography scan screening. Cancer. Dec. 2003;98(11):2495-501. [pmid: 14635086].
64 Gorecka D, Bednarek M, Nowinski A, et al. Diagnosis of airflow limitation combined with smoking cessation advice increases stop-smoking rate. Chest. Jun. 2003;123(6):1916-23. [pmid: 12796168].
65 Wells S, de Lusignan S. Does screening for loss of lung function help smokers give up?. Br J Nurs. Jun–Jul. 2003;12(12):744-50. [pmid: 12829957].
66 Buist AS, Nagy JM, Sexton GJ. The effect of smoking cessation on pulmonary function: a 30-month follow-up of two smoking cessation clinics. Am Rev Respir Dis. Oct. 1979;120(4):953-7. [pmid: 507517].
67 Loss RW, Hall WJ, Speers DM. Evaluation of early airway disease in smokers: cost effectiveness of pulmonary function testing. Am J Med Sci. Jul–Aug. 1979;278(1):27-37. [pmid: 114050].
68 Petty TL, Pierson DJ, Dick NP, et al. Follow-up evaluation of a prevalence study for chronic bronchitis and chronic airway obstruction. Am Rev Respir Dis. Nov. 1976;114(5):881-90. [pmid: 1086621].
69 Hepper NG, Drage CW, Davies SF, et al. Chronic obstructive pulmonary disease: a community-oriented program including professional education and screening by a voluntary health agency. Am Rev Respir Dis. Jan. 1980;121(1):97-104. [pmid: 7352718].
70 Pride NB, et al. Smoking cessation: effects on symptoms, spirometry and future trends in COPD. Thorax. Sep. 2001;56(Suppl 2):ii7-10. [pmid: 11514700].
71 Scanlon PD, Connett JE, Waller LA, et al. Smoking cessation and lung function in mild-to-moderate chronic obstructive pulmonary disease. The Lung Health Study. American Journal of Respiratory & Critical Care Medicine. Feb. 2000;161(2 Pt 1):381-90. [pmid: 10673175].
72 Willemse BW, Postma DS, Timens W, et al. The impact of smoking cessation on respiratory symptoms, lung function, airway hyper-responsiveness and inflammation. Eur Respir J. Mar. 2004;23(3):464-76. [pmid: 15065840].
73 Enright PL, Crapo RO. Controversies in the use of spirometry for early recognition and diagnosis of chronic obstructive pulmonary disease in cigarette smokers. Clin Chest Med. Dec. 2000;21(4):645-52. [pmid: 11194776].
74 Badgett RG, Tanaka DJ. Is screening for chronic obstructive pulmonary disease justified?. Prev Med. Jul–Aug. 1997;26(4):466-72. [pmid: 9245668].
75 Freedman S, Raffin TA, Rothkopf MH, et al. The value of a stage prop: screening for chronic obstructive pulmonary disease. Chest. Mar. 1984;85(3):406-8. [pmid: 6697798].
76 Morris JF, Temple W. Spirometric “lung age” estimation for motivating smoking cessation. Prev Med. Sep. 1985;14(5):655-62. [pmid: 4070195].
77 Ferguson GT, Enright PL, Buist AS, et al. Office spirometry for lung health assessment in adults: A consensus statement from the National Lung Health Education Program. Chest. Apr. 2000;117(4):1146-61. [pmid: 10767253].
78 Wagena EJ, van der Meer RM, Ostelo RJ, et al. The efficacy of smoking cessation strategies in people with chronic obstructive pulmonary disease: results from a systematic review. Respir Med. Sep. 2004;98(9):805-15. [pmid: 15338790].
79 Segnan N, Ponti A, Battista RN, et al. A randomized trial of smoking cessation interventions in general practice in Italy. Cancer Causes & Control. Jul. 1991;2(4):239-46. [pmid: 1873454].
80 Risser NL, Belcher DW. Adding spirometry, carbon monoxide, and pulmonary symptom results to smoking cessation counseling: a randomized trial. Journal of General Internal Medicine. Jan–Feb. 1990;5(1):16-22. [pmid: 2405112].
81 Sippel JM, Osborne ML, Bjornson W, et al. Smoking cessation in primary care clinics.[see comment]. Journal of General Internal Medicine. Nov. 1999;14(11):670-6. [pmid: 10571715]. [pmcid: 1496767].
82 Richmond R, Webster I. Evaluation of general practitioners' use of a smoking intervention programme. International Journal of Epidemiology. Sep. 1985;14(3):396-401. [pmid: 4055206].
83 Humerfelt S, Eide GE, Kvale G, et al. Effectiveness of postal smoking cessation advice: a randomized controlled trial in young men with reduced FEV1 and asbestos exposure. European Respiratory Journal. Feb. 1998;11(2):284-90. [pmid: 9551726].
84 Rose G, Hamilton PJ. A randomised controlled trial of the effect on middle-aged men of advice to stop smoking. Journal of Epidemiology & Community Health. Dec. 1978;32(4):275-81. [pmid: 370171]. [pmcid: 1060968].
85 Li VC, Kim YJ, Ewart CK, et al. Effects of physician counseling on the smoking behavior of asbestos-exposed workers. Prev Med. Sep. 1984;13(5):462-76. [pmid: 6527988].
86 van der Valk P, Monninkhof E, van der Palen J, et al. Effect of discontinuation of inhaled corticosteroids in patients with chronic obstructive pulmonary disease: the COPE study. American Journal of Respiratory & Critical Care Medicine. Nov. 2002;166(10):1358-63. [pmid: 12406823].
87 Calverley P, Pauwels R, Vestbo J, et al. Combined salmeterol and fluticasone in the treatment of chronic obstructive pulmonary disease: a randomised controlled trial. Lancet. Feb 8. 2003;361(9356):449-56. [pmid: 12583942].
88 Calverley PM, Boonsawat W, Cseke Z, et al. Maintenance therapy with budesonide and formoterol in chronic obstructive pulmonary disease. Eur Respir J. Dec. 2003;22(6):912-9. [pmid: 14680078].
89 Brusasco V, Hodder R, Miravitlles M, et al. Health outcomes following treatment for six months with once daily tiotropium compared with twice daily salmeterol in patients with COPD. Thorax. May. 2003;58(5):399-404. [pmid: 12728159]. [pmcid: 1746668].
90 Celli B, Halpin D, Hepburn R, et al. Symptoms are an important outcome in chronic obstructive pulmonary disease clinical trials: results of a 3-month comparative study using the Breathlessness, Cough and Sputum Scale (BCSS). Respiratory Medicine. Jan. 2003;97(Suppl A):S35-43. [pmid: 12564609].
91 Hanania NA, Darken P, Horstman D, et al. The efficacy and safety of fluticasone propionate (250 microg)/salmeterol (50 microg) combined in the Diskus inhaler for the treatment of COPD. Chest. Sep. 2003;124(3):834-43. [pmid: 12970006].
92 Szafranski W, Cukier A, Ramirez A, et al. Efficacy and safety of budesonide/formoterol in the management of chronic obstructive pulmonary disease. European Respiratory Journal. Jan. 2003;21(1):74-81. [pmid: 12570112].
93 Aalbers R, Ayres J, Backer V, et al. Formoterol in patients with chronic obstructive pulmonary disease: a randomized, controlled, 3-month trial. European Respiratory Journal. May. 2002;19(5):936-43. [pmid: 12030736].
94 Chapman KR, Arvidsson P, Chuchalin AG, et al. The addition of salmeterol 50 microg bid to anticholinergic treatment in patients with COPD: a randomized, placebo controlled trial. Canadian Respiratory Journal. May–Jun. 2002;9(3):178-85. [pmid: 12068339].
95 Donohue JF, van Noord JA, Bateman ED, et al. A 6-month, placebo-controlled study comparing lung function and health status changes in COPD patients treated with tiotropium or salmeterol. Chest. Jul. 2002;122(1):47-55. [pmid: 12114338].
96 Mahler DA, Wire P, Horstman D, et al. Effectiveness of fluticasone propionate and salmeterol combination delivered via the Diskus device in the treatment of chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 2002 Oct 15 2002; 166(8):1084–91.
97 Rossi A, Kristufek P, Levine BE, et al. Comparison of the efficacy, tolerability, and safety of formoterol dry powder and oral, slow-release theophylline in the treatment of COPD. Chest. Apr. 2002;121(4):1058-69. [pmid: 11948033].
98 Wadbo M, Lofdahl CG, Larsson K, et al. Effects of formoterol and ipratropium bromide in COPD: a 3-month placebo-controlled study. European Respiratory Journal. Nov. 2002;20(5):1138-46. [pmid: 12449166].
99 Dahl R, Greefhorst LA, Nowak D, et al. Inhaled formoterol dry powder versus ipratropium bromide in chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Sep. 2001;164(5):778-84. [pmid: 11549532].
100 Rennard SI, Anderson W, ZuWallack R, et al. Use of a long-acting inhaled beta2-adrenergic agonist, salmeterol xinafoate, in patients with chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Apr. 2001;163(5):1087-92. [pmid: 11316640].
101 van Noord JA, de Munck DR, Bantje TA, et al. Long-term treatment of chronic obstructive pulmonary disease with salmeterol and the additive effect of ipratropium. Eur Respir J. May. 2000;15(5):878-85. [pmid: 10853852].
102 Mahler DA, Donohue JF, Barbee RA, et al. Efficacy of salmeterol xinafoate in the treatment of COPD. Chest. Apr. 1999;115(4):957-65. [pmid: 10208192].
103 Boyd G, Morice AH, Pounsford JC, et al. An evaluation of salmeterol in the treatment of chronic obstructive pulmonary disease (COPD). Eur Respir J. Apr. 1997;10(4):815-21. [pmid: 9150318].
104 Casaburi R, Mahler DA, Jones PW, et al. A long-term evaluation of once-daily inhaled tiotropium in chronic obstructive pulmonary disease.[see comment]. European Respiratory Journal. Feb. 2002;19(2):217-24. [pmid: 11866001].
105 Vincken W, van Noord JA, Greefhorst AP, et al. Improved health outcomes in patients with COPD during 1 yr's treatment with tiotropium. European Respiratory Journal. Feb. 2002;19(2):209-16. [pmid: 11871363].
106 van Noord JA, Bantje TA, Eland ME, et al. A randomised controlled comparison of tiotropium and ipratropium in the treatment of chronic obstructive pulmonary disease. The Dutch Tiotropium Study Group. Thorax. Apr. 2000;55(4):289-94. [pmid: 10722768]. [pmcid: 1745719].
107 Connett JE, Kusek JW, Bailey WC, et al. Design of the lung health study: A randomized clinical trial of early intervention for chronic obstructive pulmonary disease. Control Clin Trials. 1993;14(2 Suppl):3S-19S. [pmid: 8500311].
108 COMBIVENT Inhalation Aerosol Study Group. In chronic obstructive pulmonary disease, a combination of ipratropium and albuterol is more effective than either agent alone. An 85-day multicenter trial. Chest. May. 1994;105(5):1411-9. [pmid: 8181328].
109 COMBIVENT Inhalation Solution Study Group. Routine nebulized ipratropium and albuterol together are better than either alone in COPD. Chest. Dec. 1997;112(6):1514-21. [pmid: 9404747].
110 Tashkin DP, Ashutosh K, Bleecker ER, et al. Comparison of the anticholinergic bronchodilator ipratropium bromide with metaproterenol in chronic obstructive pulmonary disease. A 90-day multi-center study. Am J Med. Nov. 1986;81(5A):81-90. [pmid: 2947465].
111 Burge PS, Calverley PM, Jones PW, et al. Randomised, double blind, placebo controlled study of fluticasone propionate in patients with moderate to severe chronic obstructive pulmonary disease: the ISOLDE trial. BMJ. May 13. 2000;320(7245):1297-303. [pmid: 10807619]. [pmcid: 27372].
112 Vestbo J, Sorensen T, Lange P, et al. Long-term effect of inhaled budesonide in mild and moderate chronic obstructive pulmonary disease: a randomised controlled trial. Lancet. May. 1999;353(9167):1819-23. [pmid: 10359405].
113 Paggiaro PL, Dahle R, Bakran I, et al. Multicentre randomised placebo-controlled trial of inhaled fluticasone propionate in patients with chronic obstructive pulmonary disease. International COPD Study Group. Lancet. Mar. 1998;351(9105):773-80. [pmid: 9519948].
114 Lung Health Study Research Group. Effect of inhaled triamcinolone on the decline in pulmonary function in chronic obstructive pulmonary disease. N Engl J Med. Dec. 2000;343(26):1902-9. [pmid: 11136260].
115 Pauwels RA, Lofdahl CG, Laitinen LA, et al. Long-term treatment with inhaled budesonide in persons with mild chronic obstructive pulmonary disease who continue smoking. European Respiratory Society Study on Chronic Obstructive Pulmonary Disease. N Engl J Med. Jun. 1999;340(25):1948-53. [pmid: 10379018].
116 Bourbeau J, Rouleau MY, Boucher S. Randomised controlled trial of inhaled corticosteroids in patients with chronic obstructive pulmonary disease. Thorax. Jun. 1998;53(6):477-82. [pmid: 9713447]. [pmcid: 1745246].
117 Weir DC, Bale GA, Bright P, et al. A double-blind placebo-controlled study of the effect of inhaled beclomethasone dipropionate for 2 years in patients with nonasthmatic chronic obstructive pulmonary disease. Clin Exp Allergy. Jun. 1999;29(Suppl 2):125-8. [pmid: 10421835].
118 Hiller FC, Alderfer V, Goldman M. Long-term use of Viozan (sibenadet HCl) in patients with chronic obstructive pulmonary disease: results of a 1-year study. Respiratory Medicine. Jan. 2003;97(Suppl A):S45-52. [pmid: 12564610].
119 Laursen LC, Lindqvist A, Hepburn T, et al. The role of the novel D2/beta2-agonist, Viozan (sibenadet HCl), in the treatment of symptoms of chronic obstructive pulmonary disease: results of a large-scale clinical investigation. Respiratory Medicine. Jan. 2003;97(Suppl A):S23-33. [pmid: 12564608].
120 Steurer-Stey C, Bachmann LM, Steurer J, et al. Oral purified bacterial extracts in chronic bronchitis and COPD: systematic review. Chest. Nov. 2004;126(5):1645-55. [pmid: 15539739].
121 Ries AL, Kaplan RM, Myers R, et al. Maintenance after pulmonary rehabilitation in chronic lung disease: a randomized trial. American Journal of Respiratory & Critical Care Medicine. Mar. 2003;167(6):880-8. [pmid: 12505859].
122 Brooks D, Krip B, Mangovski-Alzamora S, et al. The effect of postrehabilitation programmes among individuals with chronic obstructive pulmonary disease. European Respiratory Journal. Jul. 2002;20(1):20-9. [pmid: 12166571].
123 Finnerty JP, Keeping I, Bullough I, et al. The effectiveness of outpatient pulmonary rehabilitation in chronic lung disease: a randomized controlled trial. Chest. Jun. 2001;119(6):1705-10. [pmid: 11399694].
124 Griffiths TL, Burr ML, Campbell IA, et al. Results at 1 year of outpatient multidisciplinary pulmonary rehabilitation: a randomised controlled trial. Lancet. Jan 29. 2000;355(9201):362-8. [pmid: 10665556].
125 Ringbaek TJ, Broendum E, Hemmingsen L, et al. Rehabilitation of patients with chronic obstructive pulmonary disease. Exercise twice a week is not sufficient!. Respir Med. Feb. 2000;94(2):150-4. [pmid: 10714421].
126 Engstrom CP, Persson LO, Larsson S, et al. Long-term effects of a pulmonary rehabilitation programme in outpatients with chronic obstructive pulmonary disease: a randomized controlled study. Scand J Rehabil Med. Dec. 1999;31(4):207-13. [pmid: 10599897].
127 Wedzicha JA, Bestall JC, Garrod R, et al. Randomized controlled trial of pulmonary rehabilitation in severe chronic obstructive pulmonary disease patients, stratified with the MRC dyspnoea scale. Eur Respir J. Aug. 1998;12(2):363-9. [pmid: 9727786].
128 Celli BR, Rassulo J, Corral R. Ventilatory muscle dysfunction in patients with bilateral idiopathic diaphragmatic paralysis: reversal by intermittent external negative pressure ventilation. Am Rev Respir Dis. Nov. 1987;136(5):1276-8. [pmid: 3674587].
129 Salpeter SR, Ormiston TM, Salpeter EE. Cardiovascular effects of beta-agonists in patients with asthma and COPD: a meta-analysis. Chest. Jun. 2004;125(6):2309-21. [pmid: 15189956].
130 Hunter DJ, Fairfield G. Disease management. BMJ. Jul. 1997;315(7099):50-3. [pmid: 9233330]. [pmcid: 2127038].
131 Ninane V, Rypens F, Yernault JC, et al. Abdominal muscle use during breathing in patients with chronic airflow obstruction. Am Rev Respir Dis. Jul. 1992;146(1):16-21. [pmid: 1385684].
132 Ninane V, Yernault JC, de Troyer A. Intrinsic PEEP in patients with chronic obstructive pulmonary disease. Role of expiratory muscles. Am Rev Respir Dis. Oct. 1993;148(4 Pt 1):1037-42. [pmid: 8214922].
133 Scano G, Gorini M, Duranti R, et al. Physiological changes during severe airflow obstruction in chronic obstructive pulmonary disease. Monaldi Arch Chest Dis. Oct. 1999;54(5):413-6. [pmid: 10741101].
134 Garrod R, Mikelsons C, Paul EA, et al. Randomized controlled trial of domiciliary noninvasive positive pressure ventilation and physical training in severe chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Oct. 2000;162(4 Pt 1):1335-41. [pmid: 11029341].
135 Casanova C, Celli BR, Tost L, et al. Long-term controlled trial of nocturnal nasal positive pressure ventilation in patients with severe COPD. Chest. Dec. 2000;118(6):1582-90. [pmid: 11115443].
136 Clini E, Sturani C, Rossi A, et al. The Italian multicentre study on noninvasive ventilation in chronic obstructive pulmonary disease patients. European Respiratory Journal. Sep. 2002;20(3):529-38. [pmid: 12358325].
137 Lui KJ, Kendal AP. Impact of influenza epidemics on mortality in the United States from October 1972 to May 1985. Am J Public Health. Jun. 1987;77(6):712-6. [pmid: 3578619]. [pmcid: 1647063].
138 Lui KJ, Kendal AP. Prevention and control of influenza: Recommendations of the Advisory Committee on Immunization Practices (ACEP). Morbidity and Mortality Weekly Report. 1998;47:797-802. [pmid: 9776166].
139 Ohmit SE, Monto AS. Influenza and pneumococcal vaccination levels among adults aged >=65 years--United States, 1997. Morbidity and Mortality Weekly Report. 1998;47:797-802. [pmid: 9776166].
140 Nichol KL, Baken L, Nelson A. Relation between influenza vaccination and outpatient visits, hospitalization, and mortality in elderly persons with chronic lung disease. Ann Intern Med. Mar. 1999;130(5):397-403. [pmid: 10068413].
141 Dear K, Holden J, Andrews R, et al. Vaccines for preventing pneumococcal infection in adults. Cochrane Database Syst Rev. 2003(4):CD000422.
142 Sutherland ER, Cherniack RM. Management of chronic obstructive pulmonary disease. N Engl J Med. Jun. 2004;350(26):2689-97. [pmid: 15215485].
143 Guyatt GH, Townsend M, Nogradi S, et al. Acute response to bronchodilator. An imperfect guide for bronchodilator therapy in chronic airflow limitation. Arch Intern Med. Sep. 1988;148(9):1949-52. [pmid: 3046537].
144 Antonelli-Incalzi R, Imperiale C, Bellia V, et al. Do GOLD stages of COPD severity really correspond to differences in health status?. Eur Respir J. Sep. 2003;22(3):444-9. [pmid: 14516133].
145 Celli BR, Cote CG, Marin JM, et al. The body-mass index, airflow obstruction, dyspnea, and exercise capacity index in chronic obstructive pulmonary disease. N Engl J Med. Mar. 2004;350(10):1005-12. [pmid: 14999112].
146 Fletcher C, Peto R. The natural history of chronic airflow obstruction. Br Med J. Jun 25. 1977;1(6077):1645-8. [pmid: 871704]. [pmcid: 1607732].
147 Enright RL, Connett JE, Bailey WC. The FEV1/FEV6 predicts lung function decline in adult smokers. Respir Med. Jun. 2002;96(6):444-9. [pmid: 12117045].
148 Burrows B, Knudson RJ, Camilli AE, et al. The “horse-racing effect” and predicting decline in forced expiratory volume in one second from screening spirometry. Am Rev Respir Dis. Apr. 1987;135(4):788-93. [pmid: 3565926].
149 Vestbo J, Lange P. Can GOLD Stage 0 provide information of prognostic value in chronic obstructive pulmonary disease?. Am J Respir Crit Care Med. Aug. 2002;166(3):329-32. [pmid: 12153965].
150 Mannino DM, Gagnon RC, Petty TL, et al. Obstructive lung disease and low lung function in adults in the United States: data from the National Health and Nutrition Examination Survey, 1988-1994. Arch Intern Med. Jun. 2000;160(11):1683-9. [pmid: 10847262].
151 von Hertzen L, Reunanen A, Impivaara O, et al. Airway obstruction in relation to symptoms in chronic respiratory disease--a nationally representative population study. Respir Med. Apr. 2000;94(4):356-63. [pmid: 10845434].
152 Isoaho R, Puolijoki H, Huhti E, et al. Prevalence of chronic obstructive pulmonary disease in elderly Finns. Respiratory Medicine. Sep. 1994;88(8):571-80. [pmid: 7991881].
153 Viegi G, Pedreschi M, Pistelli F, et al. Prevalence of airways obstruction in a general population: European Respiratory Society vs American Thoracic Society definition. Chest. May. 2000;117(5 Suppl 2):339S-45S. [pmid: 10843974].
154 Bakke PS, Baste V, Hanoa R, et al. Prevalence of obstructive lung disease in a general population: relation to occupational title and exposure to some airborne agents. Thorax. Dec. 1991;46(12):863-70. [pmid: 1792631]. [pmcid: 463489].
155 Pena VS, Miravitlles M, Gabriel R, et al. Geographic variations in prevalence and underdiagnosis of COPD: results of the IBERPOC multicentre epidemiological study. Chest. Oct. 2000;118(4):981-9. [pmid: 11035667].
156 Mannino DM, Ford ES, Redd SC. Obstructive and restrictive lung disease and markers of inflammation: data from the Third National Health and Nutrition Examination. American Journal of Medicine. Jun. 2003;114(9):758-62. [pmid: 12829203].
157 de Marco R, Accordini S, Cerveri I, et al. An international survey of chronic obstructive pulmonary disease in young adults according to GOLD stages. Thorax. Feb. 2004;59(2):120-5. [pmid: 14760151]. [pmcid: 1746950].
158 Buffels J, Degryse J, Heyrman J, et al. Office spirometry significantly improves early detection of COPD in general practice: the DIDASCO Study. Chest. Apr. 2004;125(4):1394-9. [pmid: 15078751].
159 Bourbeau J, Julien M, Maltais F, et al. Reduction of hospital utilization in patients with chronic obstructive pulmonary disease: a disease-specific self-management intervention.[see comment]. Archives of Internal Medicine. Mar. 2003;163(5):585-91. [pmid: 12622605].
160 Monninkhof E, van der Valk P, van der Palen J, et al. Effects of a comprehensive self-management programme in patients with chronic obstructive pulmonary disease. European Respiratory Journal. Nov. 2003;22(5):815-20. [pmid: 14621090].
161 Weinberger M, Murray MD, Marrero DG, et al. Effectiveness of pharmacist care for patients with reactive airways disease: a randomized controlled trial. JAMA. Oct. 2002;288(13):1594-602. [pmid: 12350190].
162 Gallefoss F, Bakke PS. Impact of patient education and self-management on morbidity in asthmatics and patients with chronic obstructive pulmonary disease. Respir Med. Mar. 2000;94(3):279-87. [pmid: 10783940].
163 Watson PB, Town GI, Holbrook N, et al. Evaluation of a self-management plan for chronic obstructive pulmonary disease. Eur Respir J. Jun. 1997;10(6):1267-71. [pmid: 9192927].
164 Weinberger M, Oddone EZ, Henderson WG. Does increased access to primary care reduce hospital readmissions? Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. N Engl J Med. May. 1996;334(22):1441-7. [pmid: 8618584].
165 Littlejohns P, Baveystock CM, Parnell H, et al. Randomised controlled trial of the effectiveness of a respiratory health worker in reducing impairment, disability, and handicap due to chronic airflow limitation. Thorax. Aug. 1991;46(8):559-64. [pmid: 1926024]. [pmcid: 463273].
166 Cockcroft A, Bagnall P, Heslop A, et al. Controlled trial of respiratory health worker visiting patients with chronic respiratory disability. Br Med J (Clin Res Ed). Jan 24. 1987;294(6566):225-8.
167 Jolliet P, Tassaux D, Roeseler J, et al. Helium-oxygen versus air-oxygen noninvasive pressure support in decompensated chronic obstructive disease: A prospective, multicenter study.[see comment]. Critical Care Medicine. Mar. 2003;31(3):878-84. [pmid: 12627000].
168 Ambrosino N, Bruletti G, Scala V, et al. Cognitive and perceived health status in patient with chronic obstructive pulmonary disease surviving acute on chronic respiratory failure: a controlled study. Intensive Care Medicine. Feb. 2002;28(2):170-7. [pmid: 11907660].