# Summary

Authors: Wilt TJ, Niewoehner D, Kim C, Kane RL, Linabery A, Tacklind J, MacDonald R, Rutks I

## Introduction

Chronic Obstructive Pulmonary Disease (COPD) is manifested by chronic cough, sputum production, wheezing and, in later stages, dyspnea, poor exercise tolerance, and signs/symptoms of right-sided heart failure. Symptomatic COPD affects more than 5 percent of the adult population, is the fourth leading cause of death, and the twelfth leading cause of morbidity in the United States. ^1^ , ^2^ In more than 80 percent of cases, cigarette smoking is causally linked to the development of COPD. Smoking status should be assessed in all adults, and smokers should be advised to abstain from tobacco.

COPD is diagnosed in symptomatic individuals through spirometric testing that demonstrates irreversible airflow obstruction. ^3^ Spirometry for case-finding diagnosis and management of all adults with persistent respiratory symptoms or having a history of exposure to pulmonary risk factors has been recommended in primary care settings for all current and former smokers as well as never smokers who have persistent respiratory symptomsor have history of exposure to other COPD risk factors. This report was prepared to provide objective evidence and recommendations to inform the work of the American Thoracic Society (ATS), in collaboration with the American Academy of Family Physicians, the American College of Physicians, and the American Academy of Pediatrics Spirometry Task Force in clarifying usage of spirometry as part of the management of COPD. A systematic literature review was undertaken to address four questions:

1. What is the prevalence of COPD and airflow obstructions in various adult populations as defined by: (1) spirometry and (2) clinical examination?
2. Can use of spirometry lead to increased smoking cessation rates?
3. Does the effectiveness of COPD-specific therapies to improve clinically relevant outcomes vary based on baseline severity or change in spirometry?
4. Is prediction of future COPD status based on spirometry, with or without clinical indicators, more accurate than prediction based on clinical indicators alone?

## Methods

Articles published in the English language from 1966 to May 2005 were identified by searching MEDLINE^®^ and the Cochrane Database. Because the individual questions addressed different areas, the search strategies, types of eligible studies, populations, interventions, and outcomes varied. Emphasis was placed on studies that assessed outcomes from adults in primary care or population-based settings who had or were at risk for COPD according to race, gender, age, smoking, symptom, and spirometric status. Children or individuals with asthma, or alpha-1 antitrypsin disease were excluded. Ten cohort studies ^4^ – ^13^ were included to estimate COPD/airflow obstruction prevalence and diagnostic accuracy. Seven randomized controlled trials (RCT) ^14^ – ^20^ met inclusion criteria for smoking cessation studies, 52 RCT ^21^ – ^ 70^ and six meta-analyses of RCT ^73^ – ^78^ were included for assessment of COPD-specific therapies, and five cohort studies were included for prognosis. ^10^ , ^79^ – ^82^ The main outcomes according to question were:

1. Prevalence of airflow obstruction as determined by spirometry and clinical examination according to race, gender, age, smoking, and symptom status and previous diagnosis of COPD.
2. Long-term sustained smoking abstinence rates among smokers randomized to receive results of spirometry alone or in combination with other interventions compared to controls.
3. Exacerbations, hospitalizations, mortality, and respiratory health status according to type of treatment; baseline symptom status and FEV1; acute change in FEV1 or slope in FEV1 over time.
4. Independent prognostic value of airflow obstruction as determined by spirometric stage to predict future COPD status (stage and symptoms).

Data were used to estimate the number of adults according to smoking status that would require symptom and spirometric assessment and subsequent treatment to prevent COPD exacerbations, reduce mortality or hospitalizations, and improve smoking cessation or respiratory health status.

## Results

More than one-third of the adult U.S. population reported respiratory symptoms compatible with symptomatic COPD. Compared to clinical examination, spirometry plus clinical examination improves diagnostic accuracy of clinically significant disease in adults who report respiratory symptoms (especially dyspnea). Based on the National Health and Nutrition Examination Survey (NHANES) III results, 12.8 percent of adults report a current or past diagnosis of obstructive lung disease (emphysema, chronic bronchitis, or asthma). However, only 17.4 percent of adults reporting a diagnosis of chronic bronchitis or emphysema (COPD) had 1987-ATS defined low lung function suggesting that many of these individuals have normal lung function. Fewer than half of individuals reporting a diagnosis of chronic bronchitis or emphysema stated that they were bothered by shortness of breath. Based on gender, age, and smoking status, between 40 and 80 percent of NHANES III participants with low lung function as determined by spirometry in the absence of bronchodilator testing reported no prior clinical diagnosis of COPD. However, there were no data regarding prevalence or type of respiratory symptoms in this group.

Spirometry, when used in primary care settings for case finding of all adults with persistent respiratory symptoms or having a history of exposure to pulmonary risk factors, is likely to label a relatively large proportion of individuals as diseased with airflow obstruction but who do not have respiratory symptoms or whose symptoms are unlikely to affect their health status. Conversely, spirometry is normal in a relatively large percentage of adults who report respiratory symptoms including dyspnea, the respiratory symptom having the greatest impact on quality of life. Prevalence and severity of airflow obstruction and symptomatic COPD vary widely according to definitions utilized and country and populations studied. The percentage of adults having normal spirometry and no respiratory symptoms (normal/asymptomatic) ranged from 56 to 91 percent. Compared with previous definitions of airflow obstruction, use of recent criteria tripled the number of adults being labeled as “at-risk” or having “low lung function” (from 6.8 to 20 percent). Normal spirometry with chronic sputum production (“at-risk”) was present in 7.2 percent of subjects. An additional 13.9 percent of adults had prebronchodilator spirometrically detected airflow obstruction (mild, moderate, or severe to very severe airflow obstruction = 7.2 percent, 5.4 percent, and 1.5 percent respectively). Prevalence was higher in current smokers and older individuals. The percentage of individuals reporting respiratory symptoms increased with airflow obstruction severity. However, one-third of individuals with normal spirometry reported respiratory symptoms (21 percent reported shortness of breath). Some of these individuals may have had asthma and thus might have normal spirometry at the time of testing. Approximately, 21 percent of individuals with severe to very-severe airflow obstruction (similar to Global Initiative for Obstructive Lung Disease Stage 3,4) were asymptomatic and 35 percent did not report shortness of breath.

Smoking cessation is the most important factor in reducing the development and/or progression of airflow obstruction and symptomatic COPD. All adults should be asked about smoking and current smokers encourge to quit. However, evidence indicates that baseline symptom and spirometric status are of limited clinical use in reliably predicting a patient's future likelihood of quitting smoking. Spirometric testing as a motivational tool to improve smoking cessation rates is unlikely to provide more than a small benefit. Results from observational studies of spirometry are mixed. RCT of other biomarkers used as motivational tools for smoking cessation are generally negative. The only randomized controlled trial that assessed the independent contribution of spirometry and counseling on smoking cessation rates reported a nonsignificant 1 percent greater quit rate at 12 months in the group assigned to receive spirometry plus repeat counseling compared to repeat counseling alone (6.5 percent vs. 5.5 percent). Quit rates were lower in the spirometry group than in participants who received repeat counseling plus nicotine replacement therapy (7.5 percent). Two other studies approximated an independent effect and their results were mixed. The self-reported 6-month point prevalent abstinence rates for the intervention group assigned to receive spirometry in combination with advice plus carbon monoxide values were lower than the group that received advice alone (9 percent vs. 14 percent). The one study that showed an improvement in smoking cessation rates compared a 50-minute educational intervention with a group that received the educational intervention plus a questionnaire and discussion of symptom status, spirometric results, and carbon monoxide levels. At 12 months, the biologically verified point prevalent quit rates were 20 percent in the intervention group and 6.7 percent in the control group. Four other trials that evaluated spirometry demonstrated an improvement in smoking cessation but all included concomitant interventions proven to increase abstinence.

Spirometry is useful for determining at what threshold of airflow obstruction initiation of therapy is likely to improve clinical outcomes in adults with bothersome respiratory symptoms. However, monitoring with spirometry to guide additional therapy or to initiate interventions in individuals who do not report bothersome respiratory symptoms does not appear to be beneficial. COPD trials typically were of short duration, they involved subjects with an established clinical diagnosis of COPD who had moderate to severe respiratory symptoms, frequent COPD exacerbations, and severe to very severe baseline airflow obstruction, and they used varying outcome definitions for exacerbations. On average, interventions reduced the relative risk of exacerbations by 20 to 25 percent and the absolute risk by 5 to 6 percent. Treatments improved measures of dyspnea and respiratory functional status, although the average improvement from inhaled bronchodilators and corticosteroids on validated health status measures failed to achieve a predetermined level of clinical significance. However, some individuals will notice greater and clinically significant improvement in respiratory symptoms. Few studies reported information on hospitalizations, but in those that did reduction was 4 to 7 percent. Mortality was similar between treatment and control groups, though there were relatively few events and the available information cannot rule out an improvement with long term inhaled treatment. Information related to the effectiveness of short-acting inhaled medications used for acute symptomatic rescue therapy was not available.

Benefits from interventions are mostly limited to reduction in exacerbations in patients having activity limiting respiratory symptoms and severe to very severe airflow obstruction (FEV1 <50 percent predicted). Five large studies of greater than 1-year duration (one assessing a short-acting anticholinergic and four evaluating inhaled corticosteroids) found little to no improvement in respiratory outcomes among subjects with mild to moderate airflow obstruction or those with normal airflow but having chronic sputum production (“at risk” individuals). Analysis of one of these studies that enrolled a subgroup of individuals that had mild to moderate airflow obstruction but denied respiratory symptoms demonstrated that ipratropium did not prevent development of symptoms at 3 years of followup. Subgroup analysis of other studies indicated that treatment benefit was almost exclusively confined to adults with bothersome respiratory symptoms and severe to very-severe airflow obstruction. Five additional comparative studies of long-acting inhaled b-agonists and corticosteroids indicated that combination therapy was similar to monotherapy regarding exacerbations (ARR 1–2 percent) and mortality (ARR 0–1 percent). Combination therapy with short-or long-acting beta-agonists plus anticholinergics was not superior to anticholinergics alone but did reduce exacerbations versus short-acting beta-agonists (ARR = 6 percent). Adverse effects of inhaled interventions during the study followup periods were generally mild but included bone loss, thrush, dry mouth, and serious cardiovascular events. About 50 percent of subjects remained compliant with therapy. Withdrawals from therapy were greater in subjects assigned to placebo than to active treatments.

Studies have not examined the value of spirometry to monitor need for additional therapy or to identify candidates for treatment among patients who do not report symptoms. It is unlikely to be beneficial because data indicated that: (1) clinical improvement was not associated with an individual's spirometric response to therapy; (2) treatments other than smoking cessation did not alter the rate of spirometric decline over time; (3) there was wide intra-individual variation in spirometric decline; (4) higher doses of inhaled interventions or combination therapy were not superior to lower doses or to monotherapy; and, (5) interventions were not effective in asymptomatic individuals or those with mild to moderate airflow obstruction.

Based on NHANES III results if all “at risk” adults (i.e., smokers and ex-smokers regardless of symptom status as well as never smokers with persistent respiratory symptom) undergo an office-based spirometric test then nearly two-thirds of the adult population, approximately 110 million adults, would receive spirometric testing.

- If a primary care clinic was comprised of 10,000 adults with similar demographic, smoking, symptom, and spirometric status as NHANES III respondents then 6,588 would undergo spirometric testing, 129 (1.3 percent) would be potential candidates for COPD therapy and 7 (0.08 percent) would have reductions in exacerbations (i.e., an estimated 1,010 current smokers, 960 former smokers, and 2,043 never smokers would undergo spirometric and respiratory assessment to identify candidates for treatment consisting of an inhaled bronchodilator or corticosteroid to prevent an individual from having one or more exacerbations).
- If subjects with moderate airflow obstruction (FEV1 50–80 percent predicted; approximately Global Initiative for Obstructive Lung Disease Stage 2) benefit to a similar magnitude as severe to very severe airflow obstruction, then 529 adults (5.3 percent) would be candidates for treatment and 32 adults (0.3 percent) would benefit from having at least one exacerbation prevented compared with placebo. Approximately 76 (0.8%) would report a clinically noticeable improvement in respiratory health status. Reserving testing and treatment for individuals with respiratory symptoms (especially dyspnea, exercise intolerance, or exacerbations) would maintain benefits.
- If spirometry was targeted to individuals with dyspnea, regardless of smoking status, the number needed to screen and treat for severe to very severe airflow obstruction would be 475.

These estimates assume individuals with airflow obstruction and respiratory symptoms have COPD as the cause of their symptoms and that effective detection by clinical examination and treatment would not have occurred without spirometry. Based on 2004 Red Book prices the annual long-acting inhaled drug costs would be over $4.5 billion to treat the estimated 4 percent of adults with dyspnea and severe to very-severe airflow obstruction (n = 4,630,000). If combination therapy was routinely used instead of monotherapy, effectiveness would be similar but drug costs would be considerably higher. Compared to diagnosis and treatment based on clinical examination alone, spirometry may reduce the number of symptomatic individuals who are diagnosed with, and treated for, COPD but do not have airflow obstruction of severity that is likely to benefit from treatment.

Spirometry provides independent prognostic value regarding respiratory symptoms, morbidity, and mortality, though level of dyspnea is a better predictor of symptom progression and mortality. Baseline spirometry predicts rate of spirometric decline over time in male smokers. Spirometric levels may be useful as a guide for initiation of inhaled medications and pulmonary rehabilitation among individuals having disabling respiratory symptoms, especially frequent exacerbations. Subjects with chronic sputum production and normal spirometry (Stage GOLD 0 condition) are not at increased risk for developing airflow obstruction compared to individuals without chronic sputum production, and more than half of these subjects do not have chronic sputum production after 10 years of followup.

## Discussion

Spirometry in addition to clinical examination improves COPD diagnostic accuracy compared to clinical examination alone and it is a useful diagnostic tool in individuals with symptoms suggestive of possible COPD. The primary benefit of spirometry is to identify individuals who might benefit from pharmacologic treatment in order to improve exacerbations. These include adults with symptomatic, severe to very severe airflow obstruction. In individuals where a diagnosis of asthma is suspected bronchodilator responsiveness, testing may be indicated. The evidence does not support widespread use of spirometry in primary care settings for all adults with persistent respiratory symptoms or having a history of exposure to pulmonary risk factors for case-finding, improving smoking cessation rates, monitoring the clinical course of COPD, or adjusting COPD interventions.

Routine spirometric testing in primary care settings is likely to result in considerable testing and treatment costs, resource utilization, and health care personnel time. It might reduce the number of individuals being labeled as having COPD or receiving disease-specific treatment in the absence of severe to very-severe airflow obstruction. However, it is likely to label a large number of individuals (many not reporting bothersome respiratory symptoms or having nondisabling symptoms) as diseased who would not benefit from testing or treatment. Treatment effectiveness (beyond short acting medications used for “acute rescue therapy”) is largely limited to reducing exacerbations among subjects who have bothersome dyspnea, frequent exacerbations, and severe to very-severe airflow obstruction. Nearly all the benefit from treatment could be obtained by reserving spirometry for those having activity limiting respiratory symptoms and targeting therapy to those who have reached a spirometric threshold of airflow obstruction of approximately a FEV1 less than 50 percent predicted. Spirometric response to therapy or change over time has not been shown to be associated with clinical outcomes, nor does it appear to be beneficial in modifying therapy. Future studies should be conducted to determine if spirometry improves smoking cessation rates; if treatment effectiveness in established COPD varies according to an individual's baseline or followup spirometric value; if treatment benefits individuals with airflow obstruction and moderate to no reported respiratory symptoms; or if therapy improves the rate of decline of FEV1. Spirometry provides independent prognostic value for predicting respiratory and overall morbidity and mortality.

## Availability of the Full Report

The full evidence report from which this summary was taken was prepared for the Agency for Healthcare Research and quality (AHRQ) by the Minnesota Evidence-based Practice Center, under Contract No. 290-02-0009. It is expected to be available in September 2005. At that time, printed copies may be obtained free of charge from the AHRQ Publications Clearinghouse by calling 800-358-9295. Requesters should ask for Evidence Report/Technology Assessment No. 121, Use of Spirometry for Case Finding, Diagnosis, and Management of Chronic Obstructive Pulmonary Disease (COPD).In addition, Internet users will be able to access the report and this summary online through AHRQ's Web site at www.ahrq.gov.

## Suggested Citation

Wilt TJ, Niewoehner D, Kim C, Kane RL, Linabery A, Tacklind J, MacDonald R, Rutks I. Use of Spirometry for Case Finding, Diagnosis, and Management of Chronic Obstructive Pulmonary Disease (COPD). Summary, Evidence Report/Technology Assessment No. 121. (Prepared by the Minnesota Evidence-based Practice Center, under Contract No. 290-02-0009.) AHRQ Publication No. 05-E017-1. Rockville, MD: Agency for Healthcare Research and Quality. August 2005.

## References

1 Murray CJ, Lopez AD. Alternative projections of mortality and disability by cause 1990-2020: Global Burden of Disease Study. Lancet. May. 1997;349(9064):1498-504. [pmid: 9167458].
2 Sullivan SD, Ramsey SD, Lee TA. The economic burden of COPD. Chest. Feb. 2000;117(2 Suppl):5S-9S. [pmid: 10673466].
3 Global Initiative for Chronic Obstructive Lung Disease. Global strategy for the diagnosis, management, and prevention of chronic obstructive pulmonary disease. Available at: http://www.goldcopd.com/revised.pdf, 2004.
4 Bakke PS, Baste V, Hanoa R, et al. Prevalence of obstructive lung disease in a general population: relation to occupational title and exposure to some airborne agents. Thorax. Dec. 1991;46(12):863-70. [pmid: 1792631]. [pmcid: 463489].
5 de Marco R, Accordini S, Cerveri I, et al. An international survey of chronic obstructive pulmonary disease in young adults according to GOLD stages. Thorax. Feb. 2004;59(2):120-5. [pmid: 14760151]. [pmcid: 1746950].
6 Isoaho R, Puolijoki H, Huhti E, et al. Prevalence of chronic obstructive pulmonary disease in elderly Finns. Respir Med. Sep. 1994;88(8):571-80. [pmid: 7991881].
7 Mannino DM, Ford ES, Redd SC. Obstructive and restrictive lung disease and markers of inflammation: data from the Third National Health and Nutrition Examination. Am J Med. Jun. 2003;114(9):758-62. [pmid: 12829203].
8 Mannino DM, Gagnon RC, Petty TL, et al. Obstructive lung disease and low lung function in adults in the United States: data from the National Health and Nutrition Examination Survey, 1988-1994. Arch Intern Med. Jun. 2000;160(11):1683-9. [pmid: 10847262].
9 Pena VS, Miravitlles M, Gabriel R, et al. Geographic variations in prevalence and underdiagnosis of COPD: results of the IBERPOC multicentre epidemiological study. Chest. Oct. 2000;118(4):981-9. [pmid: 11035667].
10 Vestbo J, Lange P. Can GOLD Stage 0 provide information of prognostic value in chronic obstructive pulmonary disease?. Am J Respir Crit Care Med. Aug. 2002;166(3):329-32. [pmid: 12153965].
11 Viegi G, Pedreschi M, Pistelli F, et al. Prevalence of airways obstruction in a general population: European Respiratory Society vs American Thoracic Society definition. Chest. May. 2000;117(5 Suppl 2):339S-45S. [pmid: 10843974].
12 von Hertzen L, Reunanen A, Impivaara O, et al. Airway obstruction in relation to symptoms in chronic respiratory disease—a nationally representative population study. Respir Med. Apr. 2000;94(4):356-63. [pmid: 10845434].
13 Buffels J, Degryse J, Heyrman J, et al. Office spirometry significantly improves early detection of COPD in general practice: the DIDASCO Study. Chest. Apr. 2004;125(4):1394-9. [pmid: 15078751].
14 Humerfelt S, Eide GE, Kvale G, et al. Effectiveness of postal smoking cessation advice: a randomized controlled trial in young men with reduced FEV1 and asbestos exposure. Eur Respir J. Feb. 1998;11(2):284-90. [pmid: 9551726].
15 Li VC, Kim YJ, Ewart CK, et al. Effects of physician counseling on the smoking behavior of asbestos-exposed workers. Prev Med. Sep. 1984;13(5):462-76. [pmid: 6527988].
16 Richmond R, Webster I. Evaluation of general practitioners' use of a smoking intervention programme. Int J of Epidemiol. Sep. 1985;14(3):396-401. [pmid: 4055206].
17 Risser NL, Belcher DW. Adding spirometry, carbon monoxide, and pulmonary symptom results to smoking cessation counseling: a randomized trial. J Gen Intern Med. Jan-Feb. 1990;5(1):16-22. [pmid: 2405112].
18 Rose G, Hamilton PJ. A randomised controlled trial of the effect on middle-aged men of advice to stop smoking. J Epidemiol Community Health. Dec. 1978;32(4):275-81. [pmid: 370171]. [pmcid: 1060968].
19 Segnan N, Ponti A, Battista RN, et al. A randomized trial of smoking cessation interventions in general practice in Italy. Cancer Causes Control. Jul. 1991;2(4):239-46. [pmid: 1873454].
20 Sippel JM, Osborne ML, Bjornson W, et al. Smoking cessation in primary care clinics.[see comment]. J Gen Intern Med. Nov. 1999;14(11):670-6. [pmid: 10571715]. [pmcid: 1496767].
21 Aalbers R, Ayres J, Backer V, et al. Formoterol in patients with chronic obstructive pulmonary disease: a randomized, controlled, 3-month trial. Eur Respir J. May. 2002;19(5):936-43. [pmid: 12030736].
22 Ambrosino N, Bruletti G, Scala V, et al. Cognitive and perceived health status in patient with chronic obstructive pulmonary disease surviving acute on chronic respiratory failure: a controlled study. Intensive Care Med. Feb. 2002;28(2):170-7. [pmid: 11907660].
23 Anthonisen NR, Connett JE, Kiley JP, et al. Effects of smoking intervention and the use of an inhaled anticholinergic bronchodilator on the rate of decline of FEV1. The Lung Health Study. JAMA. Nov 16. 1994;272(19):1497-505. [pmid: 7966841].
24 Bourbeau J, Rouleau MY, Boucher S. Randomised controlled trial of inhaled corticosteroids in patients with chronic obstructive pulmonary disease. Thorax. Jun. 1998;53(6):477-82. [pmid: 9713447]. [pmcid: 1745246].
25 Bourbeau J, Julien M, Maltais F, et al. Reduction of hospital utilization in patients with chronic obstructive pulmonary disease: a disease-specific self-management intervention.[see comment]. Arch Intern Med. Mar. 2003;163(5):585-91. [pmid: 12622605].
26 Brooks D, Krip B, Mangovski-Alzamora S, et al. The effect of postrehabilitation programmes among individuals with chronic obstructive pulmonary disease. Eur Respir J. Jul. 2002;20(1):20-9. [pmid: 12166571].
27 Brusasco V, Hodder R, Miravitlles M, et al. Health outcomes following treatment for six months with once daily tiotropium compared with twice daily salmeterol in patients with COPD. Thorax. May. 2003;58(5):399-404. [pmid: 12728159]. [pmcid: 1746668].
28 Burge PS, Calverley PM, Jones PW, et al. Randomised, double blind, placebo controlled study of fluticasone propionate in patients with moderate to severe chronic obstructive pulmonary disease: the ISOLDE trial. BMJ. May 13. 2000;320(7245):1297-303. [pmid: 10807619]. [pmcid: 27372].
29 Calverley P, Pauwels R, Vestbo J, et al. Combined salmeterol and fluticasone in the treatment of chronic obstructive pulmonary disease: a randomised controlled trial.[see comment][erratum appears in Lancet. 2003 May 10;361(9369):1660]. Lancet. Feb 8 2003;361(9356):449–56.
30 Casaburi R, Mahler DA, Jones PW, et al. A long-term evaluation of once-daily inhaled tiotropium in chronic obstructive pulmonary disease.[see comment]. Eur Respir J. Feb. 2002;19(2):217-24. [pmid: 11866001].
31 Celli B, Halpin D, Hepburn R, et al. Symptoms are an important outcome in chronic obstructive pulmonary disease clinical trials: results of a 3-month comparative study using the Breathlessness, Cough and Sputum Scale (BCSS). Respir Med. Jan. 2003;97(Suppl A):S35-43. [pmid: 12564609].
32 Chapman KR, Arvidsson P, Chuchalin AG, et al. The addition of salmeterol 50 microg bid to anticholinergic treatment in patients with COPD: a randomized, placebo controlled trial. Can Respir J. May-Jun. 2002;9(3):178-85. [pmid: 12068339].
33 Cockcroft A, Bagnall P, Heslop A, et al. Controlled trial of respiratory health worker visiting patients with chronic respiratory disability. Br Med J (Clin Res Ed). Jan 24. 1987;294(6566):225-8.
34 COMBIVENT Inhalation Solution Study Group. Routine nebulized ipratropium and albuterol together are better than either alone in COPD. Chest. Dec. 1997;112(6):1514-21. [pmid: 9404747].
35 COMBIVENT Inhalation Aerosol Study Group. In chronic obstructive pulmonary disease, a combination of ipratropium and albuterol is more effective than either agent alone. An 85-day multicenter trial. Chest. May. 1994;105(5):1411-9. [pmid: 8181328].
36 Dahl R, Greefhorst LA, Nowak D, et al. Inhaled formoterol dry powder versus ipratropium bromide in chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Sep. 2001;164(5):778-84. [pmid: 11549532].
37 Donohue JF, van Noord JA, Bateman ED, et al. A 6-month, placebo-controlled study comparing lung function and health status changes in COPD patients treated with tiotropium or salmeterol. Chest. Jul. 2002;122(1):47-55. [pmid: 12114338].
38 Engstrom CP, Persson LO, Larsson S, et al. Long-term effects of a pulmonary rehabilitation programme in outpatients with chronic obstructive pulmonary disease: a randomized controlled study. Scand J Rehabil Med. Dec. 1999;31(4):207-13. [pmid: 10599897].
39 Finnerty JP, Keeping I, Bullough I, et al. The effectiveness of outpatient pulmonary rehabilitation in chronic lung disease: a randomized controlled trial. Chest. Jun. 2001;119(6):1705-10. [pmid: 11399694].
40 Gallefoss F, Bakke PS. Impact of patient education and self-management on morbidity in asthmatics and patients with chronic obstructive pulmonary disease. Respir Med. Mar. 2000;94(3):279-87. [pmid: 10783940].
41 Griffiths TL, Burr ML, Campbell IA, et al. Results at 1 year of outpatient multidisciplinary pulmonary rehabilitation: a randomised controlled trial. Lancet. Jan 29. 2000;355(9201):362-8. [pmid: 10665556].
42 Hanania NA, Darken P, Horstman D, et al. The efficacy and safety of fluticasone propionate (250 microg)/salmeterol (50 microg) combined in the Diskus inhaler for the treatment of COPD. Chest. Sep. 2003;124(3):834-43. [pmid: 12970006].
43 Hermiz O, Comino E, Marks G, et al. Randomised controlled trial of home based care of patients with chronic obstructive pulmonary disease. BMJ. Oct. 2002;325(7370):938. [pmid: 12399344]. [pmcid: 130059].
44 Hiller FC, Alderfer V, Goldman M. Long-term use of Viozan (sibenadet HCl) in patients with chronic obstructive pulmonary disease: results of a 1-year study. Respir Med. Jan. 2003;97(Suppl A):S45-52. [pmid: 12564610].
45 Jolliet P, Tassaux D, Roeseler J, et al. Helium-oxygen versus air-oxygen noninvasive pressure support in decompensated chronic obstructive disease: A prospective, multicenter study.[see comment]. Crit Care Med. Mar. 2003;31(3):878-84. [pmid: 12627000].
46 Jones PW, Bosh TK. Quality of life changes in COPD patients treated with salmeterol. Am J Respir Crit Care Med. Apr. 1997;155(4):1283-9. [pmid: 9105068].
47 Laursen LC, Lindqvist A, Hepburn T, et al. The role of the novel D2/beta2-agonist, Viozan (sibenadet HCl), in the treatment of symptoms of chronic obstructive pulmonary disease: results of a large-scale clinical investigation. Respir Med. Jan. 2003;97(Suppl A):S23-33. [pmid: 12564608].
48 Littlejohns P, Baveystock CM, Parnell H, et al. Randomised controlled trial of the effectiveness of a respiratory health worker in reducing impairment, disability, and handicap due to chronic airflow limitation. Thorax. Aug. 1991;46(8):559-64. [pmid: 1926024]. [pmcid: 463273].
49 Lung Health Study Research Group. Effect of inhaled triamcinolone on the decline in pulmonary function in chronic obstructive pulmonary disease. N Engl J Med. Dec. 2000;343(26):1902-9. [pmid: 11136260].
50 Mahler DA, Donohue JF, Barbee RA, et al. Efficacy of salmeterol xinafoate in the treatment of COPD. Chest. Apr. 1999;115(4):957-65. [pmid: 10208192].
51 Mahler DA, Wire P, Horstman D, et al. Effectiveness of fluticasone propionate and salmeterol combination delivered via the Diskus device in the treatment of chronic obstructive pulmonary disease. Am J Respir Crit Care Med 2002. Oct 15. 2002;166(8):1084-91.
52 Monninkhof E, van der Valk P, van der Palen J, et al. Effects of a comprehensive self-management programme in patients with chronic obstructive pulmonary disease. Eur Respir J. Nov. 2003;22(5):815-20. [pmid: 14621090].
53 Paggiaro PL, Dahle R, Bakran I, et al. Multicentre randomised placebo-controlled trial of inhaled fluticasone propionate in patients with chronic obstructive pulmonary disease. International COPD Study Group. Lancet. Mar. 1998;351(9105):773-80. [pmid: 9519948].
54 Pauwels RA, Lofdahl CG, Laitinen LA, et al. Long-term treatment with inhaled budesonide in persons with mild chronic obstructive pulmonary disease who continue smoking. European Respiratory Society Study on Chronic Obstructive Pulmonary Disease. N Engl J Med. Jun. 1999;340(25):1948-53. [pmid: 10379018].
55 Rennard SI, Anderson W, ZuWallack R, et al. Use of a long-acting inhaled beta2-adrenergic agonist, salmeterol xinafoate, in patients with chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Apr. 2001;163(5):1087-92. [pmid: 11316640].
56 Ries AL, Kaplan RM, Myers R, et al. Maintenance after pulmonary rehabilitation in chronic lung disease: a randomized trial. Am J Respir Crit Care Med. Mar. 2003;167(6):880-8. [pmid: 12505859].
57 Ringbaek TJ, Broendum E, Hemmingsen L, et al. Rehabilitation of patients with chronic obstructive pulmonary disease. Exercise twice a week is not sufficient!. Respir Med. Feb. 2000;94(2):150-4. [pmid: 10714421].
58 Rossi A, Kristufek P, Levine BE, et al. Comparison of the efficacy, tolerability, and safety of formoterol dry powder and oral, slow-release theophylline in the treatment of COPD. Chest. Apr. 2002;121(4):1058-69. [pmid: 11948033].
59 Szafranski W, Cukier A, Ramirez A, et al. Efficacy and safety of budesonide/formoterol in the management of chronic obstructive pulmonary disease. Eur Respir J. Jan. 2003;21(1):74-81. [pmid: 12570112].
60 Tashkin DP, Ashutosh K, Bleecker ER, et al. Comparison of the anticholinergic bronchodilator ipratropium bromide with metaproterenol in chronic obstructive pulmonary disease. A 90-day multi-center study. Am J Med. Nov. 1986;81(5A):81-90. [pmid: 2947465].
61 van der Valk P, Monninkhof E, van der Palen J, et al. Effect of discontinuation of inhaled corticosteroids in patients with chronic obstructive pulmonary disease: the COPE study. Am J Respir Crit Care Med. Nov. 2002;166(10):1358-63. [pmid: 12406823].
62 van Noord JA, de Munck DR, Bantje TA, et al. Long-term treatment of chronic obstructive pulmonary disease with salmeterol and the additive effect of ipratropium. Eur Respir J. May. 2000;15(5):878-85. [pmid: 10853852].
63 van Noord JA, Bantje TA, Eland ME, et al. A randomised controlled comparison of tiotropium and ipratropium in the treatment of chronic obstructive pulmonary disease. The Dutch Tiotropium Study Group. Thorax. Apr. 2000;55(4):289-94. [pmid: 10722768]. [pmcid: 1745719].
64 Vestbo J, Sorensen T, Lange P, et al. Long-term effect of inhaled budesonide in mild and moderate chronic obstructive pulmonary disease: a randomised controlled trial. Lancet. May. 1999;353(9167):1819-23. [pmid: 10359405].
65 Vincken W, van Noord JA, Greefhorst AP, et al. Improved health outcomes in patients with COPD during 1 yr's treatment with tiotropium. Eur Respir J. Feb. 2002;19(2):209-16. [pmid: 11871363].
66 Wadbo M, Lofdahl CG, Larsson K, et al. Effects of formoterol and ipratropium bromide in COPD: a 3-month placebo-controlled study. Eur Respir J. Nov. 2002;20(5):1138-46. [pmid: 12449166].
67 Watson PB, Town GI, Holbrook N, et al. Evaluation of a self-management plan for chronic obstructive pulmonary disease. Eur Respir J. Jun. 1997;10(6):1267-71. [pmid: 9192927].
68 Wedzicha JA, Bestall JC, Garrod R, et al. Randomized controlled trial of pulmonary rehabilitation in severe chronic obstructive pulmonary disease patients, stratified with the MRC dyspnoea scale. Eur Respir J. Aug. 1998;12(2):363-9. [pmid: 9727786].
69 Weinberger M, Murray MD, Marrero DG, et al. Effectiveness of pharmacist care for patients with reactive airways disease: a randomized controlled trial. JAMA. Oct. 2002;288(13):1594-602. [pmid: 12350190].
70 Weinberger M, Oddone EZ, Henderson WG. Does increased access to primary care reduce hospital readmissions? Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. N Engl J Med. May. 1996;334(22):1441-7. [pmid: 8618584].
71 Weir DC, Bale GA, Bright P, et al. A double-blind placebo-controlled study of the effect of inhaled beclomethasone dipropionate for 2 years in patients with nonasthmatic chronic obstructive pulmonary disease. Clin Exp Allergy. Jun. 1999;29(Suppl 2):125-8. [pmid: 10421835].
72 Calverley PM, Boonsawat W, Cseke Z, et al. Maintenance therapy with budesonide and formoterol in chronic obstructive pulmonary disease. Eur Respir J. Dec. 2003;22(6):912-9. [pmid: 14680078].
73 Sin DD, McAlister FA, Man SF, et al. Contemporary management of chronic obstructive pulmonary disease: scientific review. JAMA. Nov. 2003;290(17):2301-12. [pmid: 14600189].
74 Dear K, Holden J, Andrews R, et al. Vaccines for preventing pneumoccal infection in adults. Chochrane Database System Review. 2003;4:CDD000422.
75 Salpeter SR, Ormiston TM, Salpeter EE. Cardiovascular effects of beta-agonists in patients with asthma and COPD: a meta-analysis. Chest. Jun. 2004;125(6):2309-21. [pmid: 15189956].
76 Steurer-Stey C, Bachmann LM, Steurer J, et al. Oral purified bacterial extracts in chronic bronchitis and COPD: systematic review. Chest. Nov. 2004;126(5):1645-55. [pmid: 15539739].
77 Barr RG, Bourbeau J, Camargo CA, Ram FSF. Inhaled tiotropium for stable chronic obstructive pulmonary disease. The Cochrane Database of Systematic Reviews 2005, Issue 2. Art. No.: CD002876.pub2.
78 Nannini L, Cates CJ, Lasserson TJ, Poole P. Combined corticosteroid and longacting beta-agonist in one inhaler for chronic obstructive pulmonary disease. The Cochrane Database of Systematic Reviews 2004, Issue 3. Art. No.: CD003794.pub2.
79 Celli BR, Cote CG, Marin JM, et al. The body-mass index, airflow obstruction, dyspnea, and exercise capacity index in chronic obstructive pulmonary disease. N Engl J Med. Mar. 2004;350(10):1005-12. [pmid: 14999112].
80 Enright RL, Connett JE, Bailey WC. The FEV1/FEV6 predicts lung function decline in adult smokers. Respir Med. Jun. 2002;96(6):444-9. [pmid: 12117045].
81 Burrows B, Knudson RJ, Camilli AE, et al. The “horse-racing effect” and predicting decline in forced expiratory volume in one second from screening spirometry. Am Rev Respir Dis. Apr. 1987;135(4):788-93. [pmid: 3565926].
82 Fletcher C, Peto R. The natural history of chronic airflow obstruction. Br Med J. Jun 25. 1977;1(6077):1645-8. [pmid: 871704]. [pmcid: 1607732].