# Acknowledgments

We would like to thank Marilyn Eells for editing and formatting this report and Debra McKeehen for her assistance in preparation of tables and figures.