# Results

## Question 1 What is the prevalence of chronic obstructive pulmonary disease (COPD) and airflow obstructions in various adult populations as defined by: 1) spirometry and 2) clinical examination?

### Does Clinical Examination Predict Airflow Limitation?

There are no data that directly describe the sensitivity and specificity of spirometry (i.e., the probability of developing clinical obstructive airways disease given a particular FEV_1_ or FEV_1_/FVC). Instead, patients with an abnormally low FEV_1_ and FEV_1_/FVC are said to have “airflow limitation.” An FEV_1_/FVC lower than the fifth percentile for age, height, and gender has been described as abnormal. ^48^

Despite the lack of a “gold standard” for defining the clinical presence of COPD, a systematic review by Holleman and Simel evaluated 19 articles that assessed the clinical examination for detecting airflow limitation according to spirometry. ^48^ Spirometric reference standards used in studies yielding operating characteristics for individual clinical examination items varied across the studies. None used the GOLD 2003 classification. Only two studies incorporated both FEV_1_ and the FEV_1_/FVC as the reference standard. Factors considered in the clinical examination included history (background information such as cigarette smoking and occupational or environmental pollutants and symptoms of wheezing, dyspnea, coughing, and sputum production) and physical examination (inspection, vital signs, palpation, percussion, auscultation, and clinical measures of airflow [match test, forced expiratory time test]).

Smoking status (ever vs. never) is only a moderately good predictor of airflow limitation. Compared to “never smokers” patients who have “ever smoked” are only slightly more likely to have airflow limitation (+LR [likelihood ratio] = 1.8). Never having smoked is moderately associated with decreased likelihood of disease. The most powerful predictor was at least a 70 pack-year history of smoking (+LR = 8.0) though the sensitivity was only 40 percent. Symptoms of sputum production or wheezing are associated with a moderate increase in the likelihood of airflow limitation. However, symptoms of cough or exertional dyspnea are associated with only a slight increase in the likelihood. Additionally, the absence of dyspnea or exertional dyspnea is only moderately useful in ruling out disease (any dyspnea: +LR = 1.2; -LR = 0.55; sensitivity = 82 percent; specificity = 0.33 percent).

Physical examination findings to predict airflow limitation all had a specificity of >90 percent but were limited by poor sensitivity. Patients who have wheezing on unforced expiration almost certainly have airflow obstruction, and this increases with the severity of airflow limitation and the prior probability of disease (Positive Likelihood Ratio = 36). The presence or absence of wheezing on forced expiration is of no value in diagnosis or ruling out airflow limitation. ^49^ , ^50^ Absent wheezing, normal breath sound intensity, or absent rhonchi are associated with only a moderate decrease in the likelihood of disease. (Negative Likelihood Ratio 0.85, 0.70 and 0.95 respectively). Neither the presence nor absence of rales was useful in diagnosing airflow limitation. ^51^ – ^53^

Can the clinical examination predict severity of airflow limitation? Two studies reported on whether the presence of positive clinical findings could predict the severity of airflow limitation. The number of positive findings predicted the severity of airflow limitation in patients with known disease. The findings were present only if the FEV_1_ was less than 50 percent predicted. Similarly, the number of positive findings predicted the severity of airflow limitation (r = 0.6).

Accuracy of the overall clinical impression for predicting airflow limitation. Three studies evaluated the accuracy of the overall clinical impression, or a clinician's ability to integrate all aspects of the clinical examination in forming an impression about the likelihood of airflow limitation. Clinicians' overall impressions predicted any airflow limitation only moderately well. The ability to diagnose airflow limitation clinically is variable but seems to improve as the severity of the disorder increases.

Combinations of individual findings. Six studies assessed the utility of combining clinical examination items to predict airflow limitation. Combinations of findings do not effectively rule out airflow limitation. The best combination is never having smoked, no reported wheezing, and no wheezing on examination (LR = 0.18). A patient with any combination of two findings (≥70 pack-year history of smoking, history of COPD, or decreased breath sounds) can be considered to have airflow limitation.

### Prevalence and Severity of Airflow Obstruction

Population-based studies from seven different countries were identified that assessed the prevalence and severity of airflow obstruction and respiratory symptoms (Table 2 on page 19, Figures 5 and 6 on page 19, Summary Tables 1–4 on pages 55–60, and Evidence Tables 1–4 in Appendix D *). The prevalence and severity of airflow obstruction and COPD in general populations varied widely according to definitions utilized and country studied. Postbronchodilator testing or response to bronchodilators was rarely performed in these large population surveys. Respiratory symptoms were usually assessed according to responses to single item questions rather than detailed clinical probing. Additionally, subjects were generally categorized as having COPD based on a patient reported diagnosis of emphysema or chronic bronchitis. Some reports provided outcomes according to age, race, gender, smoking, respiratory symptom, and spirometric status (Summary Tables 1 and 2 on pages 55–58 and Evidence Table 1 in Appendix D *). However, none provided additional subgroup data required for assessment of a specific respiratory symptom (presence or absence or type) according to postbronchodilator spirometric value (e.g., GOLD stage) in a particular demographic category (e.g., age, race, gender, smoking). Thus, estimates of these are extrapolated from prebronchodilator results provided for larger aggregate groups. Data from one study of Spanish adults ages 40–65 indicated that the 26 percent of adults with airflow obstruction had a positive bronchodilator response of at least 200 mL and a relative increase of at least 12 percent. However, only 5 percent had normal airflow after bronchodilator inhalation (i.e., asthma). The methodology reported in these surveys is likely to introduce only a small misclassification. Findings may more accurately reflect the results obtained using primary-care spirometry and brief respiratory symptom assessment than those obtained in pulmonary specialty practice. Determining normal airflow “at-risk” populations (approximately GOLD 0) across studies was difficult because some provided the prevalence of “any respiratory symptom” (wheeze, cough, sputum, or dyspnea) but not specifically chronic cough and sputum in subjects with GOLD stage normal airflow. Data from the NHANES I and III (Summary Tables 1–3 on pages 55–59 and Evidence Tables 1–3 in Appendix D *) survey provide the most comprehensive and relevant assessment of obstructive lung disease, low lung function, and respiratory symptoms in adults in the United States. NHANES III assessed adults ages 17 years and older from 1988-1994 who classified themselves as whites or blacks and had pulmonary function testing performed without bronchodilators based on 1987 American Thoracic Society recommendations and had complete information on race, smoking status, height, and presence of respiratory symptoms. Subjects were asked if they had ever been told by a doctor that they had Obstructive Lung Disease (OLD) of asthma, chronic bronchitis, or emphysema (and if yes whether they still had that condition). Individuals who reported ever being told they had a diagnosis of emphysema or currently reported a diagnosis of chronic bronchitis were categorized by the authors as having current COPD. There was no information regarding whether any of these individuals had previously undergone spirometry or whether spirometry led to the clinical diagnosis of these conditions. However, we considered that individuals with a “current” or “previous” diagnosis of emphysema or chronic bronchitis were not detected by “primary care case finding” and that they had “clinically detected COPD.”

* Note: Appendixes and evidence tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/spirotp.htm

Table 2 Prebronchodilator spirometric stage according to patient's presenting symptom status*

| Patient's Presenting Symptom (%)
GOLD Stage** | Cough*** | Phlegm*** | Wheeze*** | Dyspnea***
Normal or 0 | 72.0 | 74.0 | 71.3 | 78.9
1 (mild) | 13.3 | 10.5 | 11.3 | 7.9
2 (moderate) | 8.3 | 9.9 | 12.4 | 9.1
≥ 3 (severe-very severe) | 6.3 | 5.7 | 5.0 | 4.1

* From Mannino et al. Arch Intern Med. 2000; 160:1683–1689.. NHANES results are provided as spirometric values done without bronchodilator testing.

** GOLD stages are categorized according to post bronchodilator spirometric value: The percent overall distribution by GOLD spirometric stage for “all adults” was: normal or stage 0=86%, stage 1=7.2%, stage 2=5.3%, and ≥ stage 3=1.4%.

*** The percent overall distribution of symptoms for “all adults” regardless of GOLD stage was: cough=9.4%, phlegm=8.4%, wheeze=18.3%, and dyspnea=23.4%.

Figure 5. Prebronchodilator spirometric categories according to smoking status (NHANES I)

Figure 6. Proportion of spirometry categories and % with dyspnea in adults based on GOLD criteria in the United States (NHANES III)

Data derived from Mannino et al. Arch Intern Med. 2000; 160:1683-1689.

Subjects in NHANES were classified as reporting respiratory symptoms if they gave a positive response to respiratory specific questions related to cough, phlegm, wheeze, and dyspnea. The question for dyspnea read: “Are you troubled by shortness of breath when hurrying on level ground or walking up a slight hill?” For cough and sputum a positive response was considered if subjects affirmatively answered the question: “Do you usually cough (bring up phlegm) on most days for 3 consecutive months or more during the year?” Data were stratified according to national population estimates by race, sex, and smoking status. Overall estimates were then age-adjusted to all study participants. Subjects were defined as having “low lung function” based on the 1987 ATS recommendations (i.e., subjects with an FEV_1_/FVC <0.70 and an FEV_1_ <80 percent predicted. This group was further divided according to ATS-1995 criteria (Stage 1 vs. Stage 2 or 3) into subjects with an FEV_1_ of ≥50 percent predicted and those with <50 percent predicted). Because activity-limiting or “troubling” shortness of breath (as reported in the NHANES questionnaire) is the most clinically bothersome and relevant outcome, we judged this to be the most “clinically significant” symptom of COPD if accompanied by spirometric evidence of airflow obstruction performed in the absence of bronchodilators.

Spirometry performed in the absence of inhaled bronchodilators identified a relatively large proportion of individuals with airflow obstruction who did not report respiratory symptoms and conversely was also normal in a large percentage of adults who report respiratory symptoms. An estimated 8.5 percent of the population reported current OLD (asthma, emphysema, or chronic bronchitis) and another 4.3 percent reported OLD in the past but not currently. Approximately 28 percent of adults reporting a current diagnosis of OLD had asthma as their only type of OLD. The proportion of the population with past or current OLD and COPD varied by sex, race, and smoking status, with women reporting more disease than men, whites reporting more disease than blacks, and current or former smokers reporting more disease than never smokers. OLD was reported among 12.5 percent of current smokers, 9.4 percent of former smokers, and 5.8 percent of never smokers. Former smokers were on average older than current smokers and never smokers. Mean level of lung function was lower among smokers than never smokers and increased with age. Results from the NHANES III survey indicated that the prevalence of 1987-ATS defined “low-lung function” increased from 6.0 percent in adults ages 25–44 to 40.7 percent in those ages ≥75 years (Summary Table 3 on page 59). NHANES I results indicate that ATS 2 or 3 (approximately GOLD postbronchodilator Stage 3,4) airflow obstruction was present in 2.6 percent of adults 50–59 years old and 4.2 percent of adults ages 70–74. The prevalence of mild versus moderate to severe airflow obstruction in the Po Delta Survey in adults ages >45 years increased from 8 percent versus <3 percent to 35 percent versus 5 percent respectively when using ATS rather than European Respiratory Society (ERS) criteria (Summary Table 3 on page 59). The prevalence of low lung function was similar in whites and blacks (13.8 percent vs. 11.6 percent in NHANES III) (Evidence Table 2 in Appendix D *). Results from the NHANES I survey indicated that the percentage of whites and non-whites having normal spirometry and no respiratory symptoms was 67.6 percent and 65.3 percent respectively.

The prevalence of adults having normal spirometry and not reporting respiratory symptoms (normal/individuals not reporting respiratory symptoms) varied by country. However, the criteria used to define symptoms and airflow obstruction was the greatest factor contributing to varying prevalence estimates. It ranged from 52 percent (U.S.: NHANES III) to 89 percent (Italy: ERS Criteria) (Summary Table 2 on pages 56–58). The prevalence of normal spirometry and no respiratory symptoms in the Italian Po Delta Survey decreased from 89 percent to 60 percent when subjects were classified by ATS criteria instead of ERS criteria.

An estimated 6.8 percent of the U.S. population had ATS-1987 criteria for low lung function and 7.2 percent had an FEV_1_/FVC <0.7 but an FEV_1_ >80 percent predicted. When recategorizing NHANES subjects according to a 2003 GOLD staging system that uses postbronchodilator spirometric values to define airflow obstruction, the percentage of individuals labeled as having “airflow obstruction” or “at-risk” increased by more than three-fold. Only 56.4 percent of the population had both normal spirometry and reported no chronic respiratory symptoms. Greater than 20 percent had airflow obstruction or were considered “at risk.” Specifically, 7.2 percent of subjects had GOLD Stage 0 (chronic sputum and phlegm but normal spirometry), and an additional 13.9 percent of adults had airflow obstruction (approximate GOLD Stage 1, 2, 3,4 = 7.2 percent, 5.4 percent, and 1.5 percent respectively). Prevalence was higher in current smokers and with increasing age (Evidence Table 4 in Appendix D * and Figure 5 on page 19). The percentage of individuals reporting respiratory symptoms increased with worsening airflow obstruction (Summary Table 4 on page 60). However, 23 percent of individuals with normal spirometry reported respiratory symptoms and 21 percent of individuals with severe to very severe airflow obstruction (ATS 2–3; FEV_1_ less than 50 percent predicted, approximate GOLD Stage 3,4) had no symptoms. Furthermore, 35 percent of individuals with an FEV_1_ less than 50 percent predicted did not report being troubled by shortness of breath, the symptom felt to be most clinically bothersome and warranting intervention. (Figure 6 on page 19) Therefore, the overall prevalence of adults having both low lung function and “any respiratory symptom” is GOLD 1 = 3.6 percent, GOLD 2 = 3.2 percent, GOLD 3,4 = 1.2 percent. Findings from other population-based studies are consistent with these when attempting to account for differences in definitions of airflow obstruction and symptom status as well as use of prebronchodilator spirometric values. Between 40 and 80 percent of individuals with spirometrically determined “low lung function” had no prior diagnosis of OLD.

To assess diagnostic accuracy of spirometry the additional number of adults with clinically significant disease that would be detected by case-finding is required. These would be defined as an adult with spirometrically determined airflow obstruction who reports bothersome respiratory symptoms but not a diagnosis of COPD. However, there were no data according to previous reported diagnosis of COPD, stage severity of airflow obstruction, and symptom status (particularly dyspnea). In adults who reported a clinical diagnosis of COPD (emphysema or chronic bronchitis), (approximately 3 percent of the total NHANES respondents) only 17.4 percent had 1987-ATS defined low lung function suggesting that the vast majority of these individuals do not have COPD. Among individuals reporting a clinical diagnosis of COPD 25.6 percent reported chronic phlegm, and 48 percent reported shortness of breath.

## Question 2 Can use of spirometry lead to increased smoking cessation rates?

### Summary of Interventions Used to Enhance Smoking Cessation

Two major categories of effective and potentially effective strategies, pharmacologic therapy and counseling/behavioral treatments, are shown in Figure 7 on page 23. Interventions can be used either alone or in combination. A summary of effectiveness is provided below.

Figure 7. Components of smoking cessation interventions

Pharmacologic therapy. Nicotine replacement therapies (NRTs) and Buproprion SR are considered “first line” medications. The overall odds of smoking cessation in those who used NRTs (except lozenges) were 1.7 fold greater than those who did not use NRT (95 percent CI: 1.6, 1.8). ^54^ Separate meta-analyses of each of the first four NRTs shown in Figure 7 on page 23 were conducted and the results were statistically significant ranging from an odds ratio of 1.5 for gum to 2.7 for nasal spray. The absolute differences ranged from 6.6 percent for gum to 16.6 percent for nasal spray. ^17^ The results of a meta-analysis of two studies indicate that Buproprion SR improved smoking cessation rates twofold with an absolute rate difference of 13.2 percent. ^17^

Counseling/behavioral therapy. Several counseling and behavioral therapy strategies have been shown to be effective with absolute differences in smoking cessation rates between control and intervention ranging from 2.3 percent to 8.0 percent. These include advice to quit by a physician, ^17^ nurse, or other health professional; intensive counseling, either at the group or individual level; ^17^ general problem-solving, ^17^ such as providing general information about smoking cessation and relapse, identifying potential stumbling blocks, and creating solutions to overcome them; self-help materials, including written and computer-based materials and audio-and videotapes; ^54^ and the technique of rapid smoking. ^17^ A systematic review found inconclusive evidence of effectiveness from motivational counseling, ^55^ including a discussion of the benefits of quitting, the risks of continued smoking, or a discussion of personal risk based on biological markers (including spirometry). The results of a meta-analysis of smoking cessation trials by Kottke et al., suggest that a smoking cessation message reinforced consistently and repeatedly over time is the best predictor of success. ^56^

### Use of Biological Markers in Smoking Cessation

Biological markers may have a unique role as motivational aids in smoking cessation programs. ^57^ , ^58^ Three categories of biomarkers include markers of: 1) tobacco exposure (e.g., carbon monoxide, cotinine, thiocyanate); 2) physiologic effects (e.g., pulmonary function tests—including spirometry, histopathological changes, x-rays, plethysmography, electron beam tomography, and other diagnostic tests); and 3) genetic susceptibility (e.g., CYP2D6). ^59^ Several observational studies have assessed biomarkers as motivational tools for smoking cessation. However, the lack of controls makes assessment problematic. (Studies without controls: CO, ^60^ – ^62^ CT scans, ^63^ airflow limitation/spirometry, ^64^ – ^66^ plus others. ^67^ – ^69^

### Rationale for the Use of Spirometry in Smoking Cessation

Determination of smoking and respiratory symptom status as well as advice and interventions to aid cessation or maintenance of abstinence should be provided to all smokers, regardless of pulmonary function or the presence or absence of symptoms. Results from the Lung Health Study (LH-1), a 5-year multicenter randomized control trial in the United States and Canada, indicated that smoking cessation is beneficial in slowing both the clinical and spirometric progression of patients with mild/moderate airflow obstruction. If smokers quit prior to the development of symptoms, the rate of lung function decline approaches that of nonsmokers. ^70^ , ^71^ In LH-1, smokers who quit experienced an initial increase in lung function in the first year after quitting (mean increase of 47mL/year), followed by an annual decline comparable to declines observed in nonsmokers attributed to age (mean annual decline of 31mL/year). Subjects who continued to smoke had an annual decrease in lung function that was twice the rate seen in those who quit (mean annual decline of 62mL/year). Similar findings have been observed in other studies. ^72^ The standard deviation of the annual rates of decline in FEV_1_ in the LH-1 (48mL/year in quitters and 55mL/year in continuing smokers) indicates that, even over 5 years of followup, confidence in a value for the annual decline in an individual is low.

Despite the evidence that smoking cessation improves clinical outcomes and measures of airflow obstruction, the concept of performing spirometry and using these test results to provide personalized encouragement for smoking cessation is controversial. ^73^ – ^75^ Spirometry might be useful in motivating individuals to quit smoking or maintain abstinence. It may identify individuals likely to benefit from more intensive smoking cessation counseling as well as those unlikely to quit smoking. It may motivate physicians to more carefully assess symptom and clinical status and/or provide smoking cessation counseling. Spirometric results can be provided to those at-risk in several formats, including percent FEV_1_, FEV_1_/FVC, FEV_1_/FEV_6_, or “lung age” estimations, wherein a patient's chronological age is contrasted with the physiologic age of his/her lung tissue. ^76^ , ^77^ However, spirometry entails time and costs, and may result in false labeling or reassurance and it is not yet known whether it improves smoking cessation rates. The available evidence suggests that cessation rates are relatively low and require fairly intensive counseling and pharmacologic intervention. Therefore, spirometry may not offer additional motivational benefit nor serve as a reliable predictor for an individual's likelihood of quitting. A conceptual model for the role of spirometry in smoking cessation is provided in Figure 2 on page 15.

### Smoking Cessation Strategies in People with COPD

Most smoking cessation studies did not specifically recruit subjects with airflow obstruction or clinically diagnosed COPD, nor do they report outcomes according to spirometry or symptom status. A systematic review published in 2004 evaluated the effects of interventions for smoking cessation in people with established COPD. ^78^ The authors identified five randomized trials comprising 6,491 patients with COPD conducted in the U.S., Canada, and Denmark between 1991 and 2001. None of these studies used spirometry as a motivational tool for smoking cessation. However, three studies, including the largest study, used spirometry as the method to identify subjects eligible for participation. Lung Health Study One (LH-1) enrolled 5,887 current smokers who had spirometric evidence of mild to moderate airflow obstruction. Nearly 30 percent had a previous clinical diagnosis of bronchitis but only 3.2 percent had a diagnosis of emphysema. Because studies were clinically heterogeneous regarding study population (severity of obstruction and symptoms) and types of interventions, abstinence rates were not pooled.

Three trials involved 179 subjects and evaluated four different behavioral intervention strategies. Two studies involved smokers who were admitted to the hospital and may not be representative of large population-based strategies. Behavioral interventions included: 1) use of the term “smokers' lung” rather than “chronic bronchitis” when talking to patients plus an informational brochure; 2) individual counseling responsive to patients needs and questions combined with a self-help manual; and 3) behavioral reinforcement schedules that provided lottery tickets for reduced breath carbon monoxide, self-reported smoking cessation, or attendance at clinic visits. Absolute differences in self-reported and biochemically validated point prevalence or continuous abstinence at 6–12 months ranged from 10–16 percent. However, the confidence intervals were wide and there were no statistically significant differences in any of the studies.

The Lung Health Study evaluated the effect of an intensive smoking cessation intervention (combined with either the inhaled bronchodilator ipratropium bromide or placebo) on the rate of decline in FEV_1_. The comparison (usual care) group received no study prescribed smoking intervention. The smoking intervention group received intensive cessation counseling (advice to quit by physician at one session plus group counseling—12 sessions in 10 weeks), nicotine gum provided at no cost, and a maintenance program for those who quit smoking. After 12 months, the smoking intervention program was significantly more effective in helping smokers to quit (RD at 5 years = 0.26, 95 percent CI: 0.23, 0.28). The differences declined but persisted throughout the 5 years of study followup (RD = 0.16, 96 percent CI: 0.14, 0.18).

Can symptom status and/or baseline spirometric values be used as risk stratification tools to assess the likelihood of smoking cessation? Observational studies reported in the 1970s provide conflicting information regarding the motivational effects of spirometric test results on smoking rates or the ability of spirometric values or symptom status to predict smoking cessation rates. Loss et al. examined the prevalence of pulmonary abnormalities at baseline and the subsequent 6-month abstinence rates in a group of 73 smokers. ^67^ Subjects completed pulmonary function testing and received these results along with brief counseling 1 week later via telephone. Twenty-nine percent of subjects had abnormal spirometric results and 89 percent had cough, excess sputum production, shortness of breath, or wheezing. At 6 months followup, 7 percent of those with abnormal Pulmonary Function Test (PFT) results were abstinent as compared with 11 percent of those with normal results. The authors concluded that pulmonary testing did not provide sufficient motivation to induce smoking cessation and that the costs of the testing outweighed the benefits.

Petty et al. examined smoking cessation rates among 101 smokers that were followed for up to 7 years. ^68^ All subjects were notified of their spirometric results via mail. The abstinence rate at the end of followup was 18 percent in those with abnormal lung function at baseline (FEV_1_/FVC <60 percent) versus 11 percent in those with values above this threshold. Cessation rates were similar in subjects with chronic bronchitis (18 percent) and those without bronchitis (19 percent).

Hepper et al. conducted a series of community screening programs for COPD. ^69^ Participants with abnormal lung function received their test results within 2 weeks after screening. They were encouraged to follow up with their primary care physician, who was also provided with the results of the tests, and could give them further information. Subjects from randomly selected communities (n = 553) were contacted 2 to 3 years after baseline testing to assess smoking status. The quit rate among smokers with abnormal results and no prior COPD diagnosis was 21.4 percent, compared with 11.7 percent among those with normal results and 11.9 percent among those with abnormal results and prior COPD diagnosis. These authors concluded that providing the spirometric results was enough motivation to compel smokers to quit if they had no prior clinical diagnosis of COPD and were not already aware that they had reduced pulmonary function.

Gorecka et al. reported results of a case-series of adult smokers who received smoking cessation advice along with baseline spirometric screening and 1 year followup. ^64^ The authors attempted to assess factors associated with smoking cessation in adult smokers (n = 558) categorized as either having “airflow limitation” (defined as FEV_1_/FVC ratio <85 percent or normal lung function. Subjects with airflow limitation were further categorized as having mild (FEV_1_ <70 percent of normal), moderate (FEV_1_, 50–69 percent of normal) and severe (FEV_1_ <50 percent of normal) airflow limitation. There was no difference in 1 year sustained smoking cessation among individuals with normal lung function compared to those with spirometrically determined airflow limitation. However, in post hoc multivariate analyses (and in contrast to findings from the LH-1 study) FEV_1_ was independently inversely associated with likelihood of abstinence at 1 year. Individuals with poorer lung function as defined as an FEV_1_ <88 percent had greater odds of having sustained smoking cessation than individuals with an FEV_1_ >88 percent. However, the confidence intervals were wide and included one (OR = 1.61; 95 percent CI: 0.91, 2.87). The authors provide no explanation for the selection of the FEV_1_ comparison values used in post hoc analyses.

Results from the LH-1 study suggest that the use of symptom status and baseline spirometric values including percent FEV_1_, percent FEV_1_/FVC and bronchodilator response reported as a percent of baseline are of limited clinical value in determining the likelihood of future smoking cessation. Spirometric values are strongly inversely associated with intensity of smoking, degree of addictiveness, and thus smoking cessation rates. In LH-1, differences in spirometric values between symptomatic individuals and individuals not reporting respiratory symptoms and across the type of symptoms were typically small (5–10 percent). At 5 years of followup, smoking cessation rates among enrollees with baseline respiratory symptoms (i.e., cough for ≥3 months/year, phlegm for ≥3 months/year, wheezing, dyspnea), were less than those without symptoms (14.7–15.8 percent vs.16.9–17.4 percent). ^15^ However, the absolute differences in quit rates according to presence or absence of baseline symptoms or type of symptoms were small (1.2–2.8 percent). Thus the presence or type of symptoms is not a reliable clinical indicator for assessing future quit rates. Conversely, regardless of the presence or type of symptoms at baseline, there were significant differences in the point prevalence of symptoms according to the three smoking categories. All four respiratory symptoms were most common in those who continued to smoke, least common in sustained quitters, and intermediate in subjects who abstained intermittently. Symptoms were more prevalent at followup in all smoking groups among those who reported the symptom at baseline.

Additional analyses assessed the association between symptoms and changes in FEV_1_ (percent predicted) during the 5-year study period. Regardless of treatment assignment or symptom status individuals with a greater loss in FEV_1_ had a greater occurrence of symptoms at 5 years. The quintiles of change in spirometry ranged from a loss of ≥11 percent to a gain of ≥2 percent. The 5-year occurrence of symptoms in the intervention group from highest to lowest quintile of change ranged from 33 percent to 10 percent among individuals without baseline symptoms and 68 percent to 29 percent if a baseline symptom was present. Similar findings were observed in the usual care group. Thus there appears to be an association between change in spirometry and occurrence of symptoms. Because of the known intra-individual variability in spirometric values, it is not clear how useful these findings would be for individual patient counseling and therapeutic decisions. Both smoking cessation and the reduction in the number of cigarettes smoked per day were associated with less severe airflow obstruction at baseline. However, the magnitude of these differences was small and unlikely to be useful in clinical decisionmaking.

One study compared bupropion sustained release to placebo in 404 patients with a FEV_1_/FVC ≤70 percent and clinically defined COPD. ^78^ At 12 months there was no statistically significant difference between subjects randomized to buproprion or placebo (10 percent vs. 7 percent abstinence; RD = 0.02; 95 percent CI = -0.04, 0.07). Prolonged abstinence rates after 26 weeks were lower in patients with more severe COPD (FEV_1_ between 35 percent and 50 percent predicted) than those with more mild airflow obstruction. However, the difference was not statistically significant.

### Summary of Included Study Interventions

A summary of the study characteristics, including duration, sample sizes, descriptions of control and intervention, and a brief description of participants and inclusion criteria, is provided in Summary Table 5 on pages 61–62. Only one study ^79^ evaluated the independent effect of obtaining and providing results of spirometry combined with targeted counseling on smoking cessation rates. In six studies ^80^ – ^85^ individual smoking cessation counseling was provided to intervention and control participants, although the duration, format, and intensity of this counseling varied widely across the studies. In the remaining study ^83^ no intervention was provided to the control group. Six study designs ^80^ – ^85^ involved more than one intervention being evaluated in the experimental group as compared to the control group. CO levels were incorporated into the intervention arms of two studies; ^80^ , ^81^ written smoking cessation materials were provided to participants assigned to the experimental group in three studies; ^82^ – ^84^ and to both treatment arms in three studies. ^80^ , ^81^ , ^85^ Blood tests, ^82^ chest x-rays, ^85^ and symptom questionnaires with feedback ^80^ were each included in one study. ^80^ Spirometric results were provided in-person to participants in six studies ^79^ – ^82^ , ^84^ , ^85^ and via mail in one study. ^83^

### Methodological Quality and Characteristics of Included Studies

Study strengths and limitations are shown in Summary Table 6 on pages 63–64. Randomization to a treatment arm was clearly adequate in one study, ^79^ unclear in four, ^80^ , ^83^ – ^85^ and inadequate in two of the studies. ^81^ , ^82^ Six studies ^79^ – ^84^ provided data such that intention to treat results could be calculated. In the study by Li et al. the analysis completed was not intended-to-treat, as the randomization was not maintained in the analysis due to poor physician compliance in delivering the appropriate intervention. ^85^

Length of followup, sample size, and loss to followup. Each of the seven studies provides followup data at 9 months or longer, and two studies provide followup data at 36 months. ^82^ , ^84^ Approximately one-fifth of the 6,052 participants randomized to a treatment group (six trials reporting) were lost to followup (n = 1,137, 19 percent). The number lost to followup in each study is shown in Evidence Table 5 in Appendix D *. The range of attrition rates in the seven studies was between 7 percent and 36 percent of participants per treatment arm. The rates were greater in the intervention than in the control group in three of the five studies that reported attrition rates by treatment arm. The study by Risser et al. is small with large, uneven attrition; at 12 months followup 13 of 45 participants were lost to followup in the intervention group versus 6 of 45 in the control group, although their reasons for not participating were similar across the two groups. Additionally, the results of this study may not be generalizable to other populations since the participants in this study had an average of five active medical conditions, one-quarter were enrolled in psychiatric programs, and 21 percent consumed four or more alcoholic beverages daily, all characteristics that make smoking cessation more difficult. ^80^

Compliance. In the Segnan study, physician compliance to the randomized treatment groups was low and study subject compliance to complete the followup visits and spirometry, if applicable, was also low. ^79^ Among participants, there was less than 40 percent attendance at the return visits and among those randomized to receive spirometric testing, only 50.2 percent of subjects attended this appointment. One factor contributing to the low compliance to spirometry was that subjects were asked to make a separate appointment for spirometry at another facility. In the study by Li et al., two of the four participating physicians carried out the study protocol as expected and the remaining two did not. ^85^ In the study by Risser et al., 7 percent of controls and 5 percent of those in the treatment group did not complete the initial 1-hour intervention. ^80^ Only 37 percent completed all six visits in the Richmond study. ^82^

### Baseline Characteristics

Summary baseline characteristics are shown in Table 3 on page 29. Six of the seven studies provided subject age at baseline; the mean age of subjects was 42.1 years (range 16–75, n = 5,962). Gender was reported in all seven studies and the vast majority of subjects were male (90.1 percent, n = 5,453). A large proportion of the participants in the two studies that supplied race data were white (84.5 percent, n = 662); no further information regarding race or ethnicity was provided.

Table 3 Compiled baseline characteristics from randomized control trials

Variable | # Studies Reporting | N | Mean
Personal Characteristics
Age (years) | 6 | 5,962 | 42.1
Gender (% Male) | 7 | 6,052 | 90.1%
Race (% White) | 2 | 784 | 84.5%
Smoking History
Intensity (cigarettes/day) | 7* | 5,129 | 18.3
Pack-years | 2 | 295 | 38.5
At least one previous quit attempt (%) | 4 | 1,797 | 71.0%
Motivational state (% prepared) | 1 | 205 | 36%
Symptoms
Any (%) | 1 | 923 | 51.6%
Phlegm (%) | 3 | 4,515 | 35.6%
Cough (%) | 2 | 3,112 | 29.2%
Dyspnea (%) | 1 | 579 | 2.8%
Spirometry Results
Mean FEV_1_ | 1 | 1,445 | 2.64
FEV_1_ (% predicted) | 1 | 103 | 87.0%
FEV/FVC (%) | 1 | 103 | 76.0%

* One study provided smoking intensity as categorical data and was therefore not included in the calculation of the mean.

The average intensity of smoking among participants in six of the seven studies was 18.3 cigarettes per day (n = 5,129). The average amount of smoking was 38.5 pack-years (two studies, n = 295). Just over 70 percent of subjects had previously made at least one quit attempt (71 percent; four studies n = 1,275) and one study indicated that 36 percent of participants were in the “prepared” motivational state at baseline (n = 74).

Few studies reported respiratory symptom status or spirometry at baseline (51.6 percent of participants had any symptoms, n = 476). Of those evaluated, most subjects had relatively minimal symptoms and/or mild airflow obstruction. Three studies provided specific respiratory symptom data. In three studies, 35.6 percent of participants indicated that they had excess phlegm (n = 1,608), while 29.2 percent of subjects in two studies had cough (n = 908) and 2.8 percent of those in one study reported dyspnea (n = 16). Baseline spirometry results were presented in two of the studies. The mean FEV_1_ of the 1,445 participants in one study was 2.64. The other study presented FEV_1_ as a percentage (87 percent) as well as the ratio of FEV_1_/FVC (76 percent) among those assigned to the intervention group (n = 103). None of the studies provided outcome data according to symptom status.

None of the participants were selected based on their motivation to quit smoking. Subjects were selected as part of a cohort of outpatients in three studies, ^79^ , ^81^ , ^82^ as part of a cohort of workers in two studies, ^84^ , ^85^ and as volunteers in two studies, including volunteers of a health promotion clinic ^80^ and a community health survey. ^83^ Participants were selected for the study by Rose et al. ^84^ because they were at high cardiorespiratory risk. Likewise, smokers included in the study by Humerfelt et al. ^83^ were at high risk due to previous occupational asbestos exposure and/or adjusted FEV_1_ in the lowest quartile and subjects of the study by Li et al. may have additional motivation to quit due to long-term occupational exposure to asbestos. ^85^

### Results

Smoking cessation outcomes data for each of the seven included trials are summarized in Summary Table 7 on pages 65–66. Smoking cessation outcomes in clinical trials are measured in a variety of ways including short- and long-term point-prevalence or sustained abstinence. In general, short-term abstinence refers to outcomes less than 3 months following treatment, and may include in-treatment results depending on the duration of treatment. Long-term abstinence refers to outcomes generally measured at 6 to 12 months. In addition, at the measurement point, abstinence can be described as point prevalent (usually 7–30 days) or sustained (ranges generally from 6 months to continually from point of intervention). Finally, abstinence can be self-reported or validated by biomarkers of exposure such as carbon monoxide or cotinine. Quit attempts are regarded as a less robust, secondary process outcome.

Due to the heterogeneity of the interventions and the diverse manner in which results were reported, the calculation of a pooled estimate of cessation rates was considered inappropriate. A summary of the individual study results is provided and displayed in Figure 8 on page 30, Figure 9 on page 31, and Summary Table 7 on pages 65–66. The study by Rose et al. ^84^ also provided data on change in participant pulmonary function over the course of followup.

Figure 8. Abstinence rate at 6–12 months

Figure 9. One or more quit attempts

Abstinence rates. Six studies reported greater smoking cessation rates among those in the experimental groups compared to those in the control groups after 6 to 12 months of followup. The results were statistically significant in two studies. ^82^ , ^84^ The largest study involving 2,610 subjects compared multiple interventions using a letter + informational pamphlet + questionnaire + spirometry to a group that received no intervention. The absolute difference in sustained abstinence at 12 months between groups was 1.5 percent and of borderline statistical significance. ^83^ One study showed a lower rate of abstinence among the intervention group as compared to the control group; this difference was not statistically significant. ^81^ The range of abstinence rates for the control groups was 2.8 percent to 14 percent and among intervention groups was 6.5 percent to 39.3 percent. The range of absolute rate differences (abstinence rate _intervention_ - abstinence rate _control_) was 1.0 percent to 33.0 percent (Figure 8 on page 30). Results for two studies are biologically verified. ^79^ , ^85^ Results for the remaining five studies are based on participant self-report. ^80^ – ^84^

Caution must be taken in attributing differences in cessation rates to the independent contribution of spirometry (Summary Tables 6 and 7 on pages 63–66) because most studies used interventions in addition to spirometric testing that have been proven to independently improve smoking cessation. Only one study ^79^ assessed the independent contribution from the process of obtaining and providing the results of spirometry to smokers in combination with focused smoking cessation counseling. Two others approximated this process. ^80^ , ^81^ The results of these three studies ^79^ – ^81^ are mixed and none were statistically significant. The study most closely adhering to this principal demonstrated a nonsignificant 1 percent greater point prevalent quit rate at 12 months in the group assigned to receive spirometry plus repeat counseling compared to repeat counseling alone (6.5 percent vs. 5.5 percent). ^79^ Quit rates were lower in this group than in the group that received repeat counseling plus nicotine replacement therapy (7.5 percent). The self-reported 6 month point prevalent abstinence rates for the intervention group assigned to receive spirometry in combination with advice plus carbon monoxide values was lower than the group that received advice alone (9 percent vs. 14 percent). ^81^ The one study that showed a beneficial effect compared a 50-minute educational intervention in the control group with a similar intervention plus spirometry, carbon monoxide values, and a questionnaire and discussion of symptom status. At 12 months the biologically verified point prevalent quit rates were 20 percent in the intervention group and 6.7 percent in the control group. ^80^ The effect on cessation rates that occurred in the intervention group due to carbon monoxide testing and symptom assessment/discussion is not known. A summary of the study strengths and limitations are included in Summary Table 6 on pages 63–64.

Self-reported abstinence rates. Results were similar across studies when various measures of abstinence, including self-reported point prevalence abstinence at 6 to 12 months followup and sustained abstinence over the course of the study, were examined. In the study by Richmond et al., the 6-month point prevalent self-reported abstinence rate among controls was 3.0 percent compared with 35.0 percent among those in the intervention group (p <0.0001). ^82^ Sippel et al. reported a higher self-reported abstinence rate among controls than among those in the intervention group at 9 months followup (14 percent vs. 9 percent); however, this result was not statistically significant (p = 0.10). ^81^ The 12-month self-reported abstinence rates were 11.1 percent among controls versus 24.4 percent among the intervention group in the study by Risser et al. (p = 0.08), ^80^ 9.1 percent in controls and 11.4 percent in the intervention group in the study by Humerfelt et al. (p = 0.05), ^83^ and 8.9 percent and 39.3 percent, respectively, in the study by Rose et al. (p < 0.0001). ^84^ Rose et al. also provided self-reported abstinence rates at 36 months of followup of 14.5 percent among controls and 35.5 percent among those in the experimental group (p <0.0001). ^84^

Biologically verified abstinence rates. Biological validation of cessation, using varying definitions of abstinence, was performed in four studies. ^79^ , ^80^ , ^82^ , ^85^ Studies with self-reported abstinence rates showed higher rates of abstinence than studies with biologic confirmation of abstinence. In each of the biologically validated studies, the abstinence rate among those in the intervention group was greater than the rate among the controls; these results were statistically significant in two of the four studies. ^82^ , ^85^

Li et al. reported biologically verified abstinence rates at 11 months of followup of 2.8 percent among controls and 6.5 percent among those in the intervention group (p <0.0001). ^85^ In the study by Richmond et al., ^82^ the biologically validated abstinence rates at 36 months of followup were 8.0 percent among controls and 35.7 percent among those in the experimental group (p <0.001).

Sustained abstinence over the course of the study. Among the three studies that reported sustained abstinence, ^82^ , ^83^ , ^85^ higher abstinence rates were reported in the intervention groups compared to the control groups in all three studies. The results were statistically significant in two of the three. ^82^ , ^85^ In the study by Li et al., ^85^ the self-reported sustained abstinence rates over the course of the study at 11 months of followup were 3.6 percent among controls and 8.4 percent among those in the experimental group (p = 0.01) and the self-reported 12-month rates were 3.2 percent among controls receiving no intervention versus 4.7 percent among the intervention group that receives a letter providing spirometry test results, advice to quit, and a pamphlet emphasizing behavior modification (p = 0.05). ^83^ Richmond et al. reported biologically validated sustained abstinence rates at 36 months of 2.0 percent among controls and 23.5 percent among those in the intervention group (p <0.001). ^82^ As previously noted the intervention group had six visits to a primary care provider for counseling and smoking cessation support versus only two visits in the control group.

Quit attempts. Risser et al. reported that 15.6 percent of participants in the control group versus 35.6 percent of participants in the intervention group had made one or more quit attempts over the 12 months of followup (p = 0.03) ^80^ and Sippel et al. reported that 36 percent and 48 percent, respectively, had attempted to quit over 9 months of followup (p = 0.09). ^81^

Change in pulmonary function. Participant changes in pulmonary function were reported at 1 and 3 years post-intervention by Rose et al. At 1 year, those in the intervention group had a mean decline in FEV_1_ of -0.075 compared with -0.115 in the control group. Likewise, the intervention group experienced a mean reduction in FVC of -0.132 versus -0.153 in the control group. At 3 years, the mean change in FEV_1_ was -0.056 in the intervention group and -0.037 in the control group, while the mean change in FVC was -0.001 versus -0.002, respectively. This corresponded to an overall rate of change in lung function (FEV_1_ and FVC) that was 14 percent less in the intervention group compared with the control group over 3 years, a difference that was highly significant statistically. ^84^

## Question 3 Does the effectiveness of specific therapies to improve clinically relevant outcomes in COPD vary based on baseline or followup spirometry, short term spirometric response due to initial therapy, or spirometric progression over time?

### Demographic and Baseline Characteristic of Studies

1) Pharmacological therapies. Among the 53 studies, there is some overlap across each intervention. Most intervention trials 1) were of short duration (i.e., 6 months or less), 2) enrolled subjects with a previous clinical diagnosis of COPD, 3) had subjects with severe to very severe airflow obstruction, and 4) enrolled subjects who had symptomatic, stable COPD but relatively frequent episodes of exacerbations. Almost all studies used spirometric criteria for inclusion criteria. However few studies used spirometry for casefinding or population-based recruiting and many did not assess postbronchodilator spirometric values or categorize enrollees according to spirometric response to bronchodilators.

All studies compared a fixed dose of medications though some studies evaluated different doses of a given pharmacologic agent. Five studies were multiarm trials that compared combination therapy with inhaled long-acting beta agonists (LABA) plus corticosteroids to placebo or monotherapy with either LABA or inhaled corticosteroids. Three studies compared ipratropium monotherapy with combination therapy consisting of ipratropium with either a short or long-acting beta agonist. None titrated interventions according to short-term spirometric response to therapy, change in spirometry over time, or based on an enrollee crossing a threshold value of spirometry. None of the studies used spirometry to begin, discontinue, adjust, or monitor treatment effectiveness.

The range of mean study baseline spirometry of enrolled subjects was typically quite narrow. Only four studies evaluating inhaled corticosteroids and one study of short-acting inhaled anticholingerics had mean baseline FEV_1_ percent predicted values that were greater than GOLD stage 3,4 airflow obstruction (i.e., mild-moderate severe airflow obstruction). None of the studies published subgroup outcomes according to smoking status, previous clinical diagnosis of COPD, age, race, or gender. Only two studies reported outcomes according to spirometric stage of disease ^86^ , ^87^ and these involved inhaled corticosteroids. Additional outcome data according to baseline symptom and spirometric status were obtained from one study of short acting anticholinergics through personal communication with the Data Coordinating Center for LH-1 (John Connett, personal communication, 2004). The few studies that followed groups of patients for longer than 1 year did not report outcomes separately according to baseline symptom status (i.e., wheezing, dyspnea, sputum production, cough, or respiratory symptoms).

The definition of our primary outcome (COPD exacerbation) varied across studies. Most studies defined exacerbations as a subjective worsening of cough, sputum, or dyspnea that required treatment with antibiotics and/or oral/intravenous corticosteroids. Other studies defined exacerbations based only on acute changes in respiratory symptoms and did not specifically require the use of additional medications. For our analyses, an exacerbation event was defined as a subject having at least one exacerbation during the treatment period. If this outcome was not available, an exacerbation was denoted by the alternative events: 1) subject having a COPD adverse event; 2) subject requiring additional treatment for COPD; 3) exacerbation/deterioration of COPD leading to study withdrawal.

Long-acting β agonists. The baseline demographic and pulmonary characteristics of the 18 studies ^46^ , ^87^ – ^103^ evaluating long-acting β2 agonists are summarized in Evidence Table 6 in Appendix D *. One published report was a pooled analyses of a published RCT ^95^ and an unpublished RCT. ^89^ The quality of the randomization allocation concealment method was adequate in only three trials ^87^ , ^93^ , ^94^ and unclear in the remaining studies. Intention-to-treat analysis was reportedly used in 14 trials. ^46^ , ^88^ , ^90^ – ^94^ , ^96^ – ^101^ , ^103^ All studies were double-blinded. Enrolled subjects had symptomatic COPD and severe to very severe airflow obstruction. A total of 12,390 patients, with a mean FEV_1_ of 1.24L (range 0.96–1.51L) and pretreatment FEV_1_ range of 33–55 percent predicted at baseline spirometry, were evaluated during 3 months to 1 year in studies assessing long-acting β agonist alone or in combination with other therapies. Long-acting β2 agonists (salmeterol or formeterol) alone were compared to placebo in 14 trials that provided exacerbation outcomes (n=6,544). Subjects randomized to active controls received tiotropium (2 trials), ipratropium (4 trials) sibenadet (1 trial), inhaled long acting corticorticosteroids fluticasone or budesonide (5 trials), or combination therapies (five with inhaled corticosteroids and one with ipratropium). Three studies compared different doses of formoterol ^93^ , ^97^ , ^99^ and two studies assessed different doses of salmeterol. ^46^ , ^103^ The mean age was 63.5 years (n=8,029) and males were 74 percent of the subjects. Five trials provided ethnicity information. ^90^ , ^91^ , ^96^ , ^100^ , ^102^ Nearly 95 percent of subjects were white. Smoking history was recorded in ten trials ^87^ – ^92^ , ^95^ , ^96^ , ^99^ , ^102^ (mean of 46 pack-years) and the duration of COPD diagnosis was about 8 years (nine trials reporting). ^89^ , ^91^ , ^93^ , ^95^ – ^99^ , ^102^

Long-acting anticholinergics. In Evidence Table 7 in Appendix D * the general characteristics of the five clinical trials, ^89^ , ^95^ , ^104^ – ^106^ with tiotropium (18 ug/day) are summarized. Two of the published reports ^89^ , ^105^ were pooled analyses of two published RCTs ^95^ , ^106^ and two unpublished RCTs. The quality of the randomization allocation concealment method was unclear in all studies. Intention-to-treat analysis was reportedly used in three trials. ^104^ – ^106^ All studies were double-blinded. A total of 2,663 patients were enrolled. All had severe to very-severe airflow obstruction, (a mean FEV_1_ of 1.11L with range 1.04L to 1.25L, and pretreatment FEV_1_ of 38–42 percent predicted), respiratory symptoms and a previous diagnosis of COPD. Treatment duration ranged from 3.3 months to 1 year. Of the 2,663 patients, 1,308 (49.1 percent) received monotherapy with tiotropium. Twenty-nine percent received placebo (two reports, n=771 subjects) or ipratropium bromide (one report, n=179 subjects). The others (15 percent) were only treated by long-acting β2 agonists (salmeterol; one study). The mean age was 64.5 years and 70 percent of subjects were male. No further information regarding race or ethnicity was provided. Subjects had a mean of 48 pack-years smoking and had COPD for approximately 9 years.

Short-acting anticholinergics. There were eight published reports, five multi-armed, involving the short-acting anticholinergic ipratroprium (typically 40 ug three to four times/day). ^19^ , ^98^ , ^99^ , ^100^ – ^102^ , ^105^ , ^106^ Seven involved ipratropium monotherapy, (including five versus placebo, four versus long-acting β agonists and one versus tiotropium) and one combined ipratropium with salmeterol in comparison to salmeterol alone and placebo. One published report was a pooled analyses of a published RCT and an unpublished RCT ^105^ , ^106^ . The quality of the randomization allocation concealment method was unclear in all studies, except the LH1. ^107^ Intention-to-treat analysis was reportedly used in five trials. ^98^ – ^100^ , ^105^ , ^106^ All studies were double-blinded. Two studies compared outcomes to the long-acting anticholinergic tiotroprium. Studies providing data on exacerbations were 3 months in duration. General characteristics are summarized in Evidence Table 8 in Appendix D *. A total of 8,489 patients with moderate to severe COPD (a mean FEV_1_ of 2.21L with range 1.18L to 2.64L and pretreatment FEV_1_ of 33–46 percent predicted) were evaluated during 3 months to 1 year. Of the 8,345 patients, 2,667 (31 percent) were randomized to ipratropium monotherapy and 5,466 patients (66.7 percent) to placebo, tiotropium, or usual care. Combination therapy with salmeterol was evaluated in 47 subjects. In comparison to other interventions, studies evaluating ipratroprium enrolled a higher percentage of relatively young individuals, women, subjects with mild to moderate airflow obstruction, and those without symptoms or previous clinical diagnosis of COPD. Therefore, subjects enrolled in these studies more closely represent a spectrum of the population likely to be detected by case finding in primary care settings. The mean age was 52.9 years (n=5,523). Sixty-five percent were men. Nearly 95 percent were white (n=two studies). ^100^ , ^102^ The mean smoking history was 41 pack-years (n=five studies) ^19^ , ^99^ , ^102^ , ^105^ , ^106^ and the mean duration of COPD was 9.8 years. ^98^ , ^99^ , ^102^ , ^105^ , ^106^

Combination therapy with inhaled short-acting anticholinergics and β2 agonists. Combination therapy (inhaled short acting anticholinergics bronchodilators [ipratropium bromide] + short (or long)-acting β2 agonists (albuterol or salmeterol) studies are summarized in Evidence Table 8 in Appendix D *. ^108^ – ^110^ A total of 1,186 patients with severe to very severe airflow obstruction and symptomatic COPD (a mean FEV_1_ of 0.95L with range 0.91L to 1.00L and pretreatment FEV_1_ of 34 percent to 37 percent predicted) were evaluated during 85 days. Of all patients, 404 (34.1 percent) had been treated by combination therapy. Ipratropium and albuterol, were given to 393 (33.1 percent) and 389 (32.8 percent), respectively. The mean age was 64.4 years (n=1,186) and approximately 65 percent were men. Over 93 percent of enrollees were white and the mean duration of COPD was 8.9 years.

Inhaled corticosteroids. Thirteen studies evaluated inhaled corticosteroids and are summarized in Evidence Table 9 in Appendix D *. The quality of the randomization allocation concealment method was adequate in five studies, ^86^ , ^87^ , ^111^ – ^113^ and unclear in the other studies. Intention-to-treat analysis was reportedly used in 11 trials. ^86^ , ^88^ , ^91^ , ^92^ , ^96^ , ^111^ – ^116^ All studies were double-blinded. A total of 8,849 patients were enrolled. Studies evaluating inhaled corticosteroids enrolled subjects with a relatively wide spectrum of clinical and airflow severity. Studies also assessed treatment over several years. Enrolled subjects (a mean FEV_1_ of 2.0L with range 0.91L to 2.53L and pretreatment FEV_1_ of 36–77 percent predicted) were evaluated from 6 months to 4.5 years. Of all patients, 3,247 (36.7 percent) had been treated by inhaled corticosteroids (fluticasone or triamcinolone; or budesonide or beclomethasone) and 3,257 patients had only taken a placebo (36.8 percent). The mean age overall was 60 years (n=6,504). The percent of males overall was about 71 percent. According to three trials ^91^ , ^96^ , ^114^ with ethnicity information, the proportion of white subjects was 94 percent. All subjects in ten trials ^86^ – ^88^ , ^91^ , ^92^ , ^96^ , ^111^ , ^115^ – ^117^ had a smoking history with a mean of 44 pack-years.

Combination corticosteroids and long-acting β agonists. Five studies evaluated inhaled corticosteroid and long-acting β agonist combination therapy (Evidence Table 9 in Appendix D *). ^87^ , ^88^ , ^91^ , ^92^ , ^96^ All studies were parallel-grouped, placebo-controlled, and double-blinded. The quality of the randomization allocation concealment method was adequate in one trial ^87^ and intention-to-treat analysis was reportedly used in four studies. ^88^ , ^91^ , ^92^ , ^96^ Study duration ranged from 6 to 12 months. A total of 4,713 subjects were enrolled, approximately 25 percent randomized to combination, placebo, and monotherapy arms each. The subjects were, on average, 64 years old, had a baseline FEV_1_ of 1.2L (range 0.96 to 1.3, FEV_1_ of 36–45 percent predicted), had a smoking history with a mean of 46 pack-years, and a median duration of COPD of 6 years (two studies reporting. ^91^ , ^96^ Two trials reported ethnicity and nearly all subjects were white (94 percent). ^91^ , ^96^

D2 antagonist. Sibenadet was evaluated in three studies involving four study protocols ^90^ , ^118^ , ^119^ and summarized in Evidence Table 10 in Appendix D *. One study included two trials according to study duration (3 or 6.5 months). ^119^ A total of 4,077 patients with a mean FEV_1_ of 1.29L (range 1.2–1.4L) and pretreatment FEV_1_ of 39–42 percent predicted at baseline were evaluated during 3 to 13 months. Of all patients, 1,977 (48.5 percent) had only been treated by sibenadet. A placebo was given as treatment to 1,547 (37.9 percent). The others (13.6 percent) were treated with salmeterol. The mean age was 63.9 years (n=3,523). The percent of males was 71 percent. According to one trial ^90^ with ethnicity information, the proportion of whites was 97.2 percent. In four trials subjects had a mean of 47 pack-years.

Oral Purified Bacterial Extracts. A systematic review and meta-analysis identified 13 trials (1,971 patients) of oral purified bacterial (active) extracts in patients with chronic bronchitis and COPD. ^120^ Ten studies tested OM-85BV, two trials tested LW-50020, and one study tested SL-04. ^120^ Study duration ranged from 3–12 months. In trials that reported demographic information, 60 percent were male. Inclusion criteria were COPD in six trials, chronic bronchitis in ten trials, and more than three episodes of exacerbation within the previous year in eight trials. In the seven studies that reported smoking habits, almost half of analyzed patients were smokers or ex-smokers. Lung function was reported in five trials (mild to moderate COPD, four trials; severe COPD, one trial). ^120^

2) Nonpharmacological therapies. The general characteristics of the seven studies ^121^ – ^127^ of pulmonary rehabilitation intervention are summarized in Evidence Table 11 in Appendix D *. One study included two trials according to disease severity (moderate or severe). ^127^ Subjects enrolled in nonpharmacological therapy trials typically had severe to very severe airflow obstruction and respiratory symptoms, already received a clinical diagnosis of COPD, and were already receiving a wide assortment of pharmacologic agents. Thus they are unlikely to be representative of the vast majority of subjects detected by casefinding with spirometry in primary care settings, whom this report is targeted to address. We provide this information for the sake of completeness.

A total of 693 patients with a FEV_1_ range (0.71–1.07L) and pretreatment FEV_1_ of 31–50 percent predicted at baseline were evaluated from 8 weeks to 2 years. The general characteristics of the nine studies using interventions of disease management, education, and followup are summarized in Evidence Table 12 in Appendix D *. A total of 1,997 patients with a FEV_1_ range (0.78-post 1.71L) and pretreatment FEV_1_ of 37–59 percent predicted at baseline were evaluated from 3 months to 1 year. Also, the general characteristics of the two studies intervened by NIMV are summarized in Evidence Table 13 in Appendix D *. A total of 220 patients with a FEV_1_ range of 0.73L and pretreatment FEV_1_ of 30 percent predicted at baseline were evaluated from 6 months to 2 years.

### Outcomes by Intervention

1) Pharmacological therapies.

Long-acting β2 agonists as monotherapy (LABA). (Figure 10 on page 67, Evidence Figures 1 and 2 in Appendix D *, and Evidence Tables 14 and 15 in Appendix D *.) Thirteen placebo-controlled trials (6,544 patients, baseline) followed patients from 3 to 12 months. Compared to placebo, both formoterol and salmeterol reduced exacerbations as well as improved St George's Respiratory Questionnaire scores. There was a pooled 18 percent relative risk reduction (95 percent CI, 10–24 percent) and 4 percent pooled absolute risk reduction [95 percent CI, -6 to -2] in the percentage of individuals having one or more COPD exacerbation events during study followup. Reductions were consistently seen across studies with each agent and were similar in studies utilizing formeterol and those using salmeterol. Only three studies reported rates of hospitalization. They were reduced by about 5 percent compared to placebo in one study and not different in two others. The few dose comparison studies of the long acting β2 antagonists salmeterol or fometerol found similar improvements in all clinical outcomes at differing doses of medication. This suggests that increasing the dose of β2 antagonist beyond salmeterol 50 ug/bid or fometerol 12 ug/bid is not beneficial.

Figure 10. Inhaled therapies for the management of COPD, Long-acting B2-agonists vs. placebo

There was no significant difference in all-cause mortality between placebo and LABA (12 studies, 5,700 patients) (RR=1.07; 95 percent CI: 0.65–1.78). Absolute risk reduction was 0 percent [95 percent CI, -1 to 1]. Improvement was demonstrated in health-related quality of life scores as measured by the SGRQ in seven studies of subjects with GOLD Stage 3,4 disease (1.98-unit improvement; 95 percent CI: 0.81–3.15 vs. placebo). However, the pooled weighted mean difference in SGRQ compared to placebo failed to achieve a previously specified level of clinical significance (i.e., ≥4). Additionally, the only two studies that individually reported a clinically important difference in SGRQ enrolled subjects with severe to very severe airflow obstruction (mean FEV_1_ predicted <50 percent).

The narrow range of mean baseline spirometric values (FEV_1_ range=1.1–1.5; percent predicted=33–54 percent; GOLD 3,4) precludes assessment of whether treatment effectiveness varied according to baseline spirometry. The high percentage of subjects in the placebo arm that had at least one COPD exacerbation suggests that in all but one study ^93^ subjects had severe symptoms and frequent exacerbations. In two trials lasting 6 months (n=1,212) salmeterol provided similar reductions in exacerbations compared to tiotropium (RR=1.07; 95 percent CI 0.92 to 1.25). ^89^ , ^95^

Long-acting anticholinergics: tiotropium. (Figure 11 on page 68, Evidence Figure 3 in Appendix D *, and Summary Tables 8 and 9 on pages 69–71.) Five clinical trials of the long-acting, anti-cholinergic tiotropium (n=2,956) in patients with severe to very severe airflow obstruction (mean FEV_1_ percent predicted = 39–41 percent) and respiratory symptoms demonstrated a reduction in exacerbations compared with either placebo (RR = 0.84; 95 percent CI, 0.74–0.95) or with the short-acting anti-cholingeric ipratropium bromide (RR = 0.77; 95 percent CI, 0.62–0.95). Pooled absolute risk reductions were 6 percent (95 percent CI, -11 to -2) compared to placebo and 11 percent (95 percent CI, -20 to -2) versus ipratropium. Subjects enrolled in these studies had frequent episodes of exacerbations. The weighted mean percentage of subjects with at least one exacerbation during the 3–12 month study period in the control group was approximately 40 percent. Hospitalization rates were reported in three studies and found to be lower by about 7 percent compared to placebo and 4 percent versus ipratropium. All-cause mortality was decreased versus placebo (RR = 0.50; 95 percent CI 0.17 to 1.24) in two trials (n=1,723), ^89^ , ^104^ and the absolute risk reduction was one percent (95 percent CI, -2 to 0). The risk of all-cause mortality was increased compared with ipratropium in one trial, although not significantly (RR = 1.51; 95 percent CI 0.41 to 5.50). ^105^ Tiotropium also improved scores on the SGRQ health-related quality of life scale relative to placebo (2.7–3.7 unit improvement) and ipratropium (3.3 unit improvement) though the reduction failed to achieve a previously determined level of clinical significance. Exacerbations were similar compared to long-acting β2 agonists (RR for exacerbations vs. long-acting β2 agonists, 0.92; 95 percent CI, 0.75–1.11) in pooled results from two studies. ^89^

Figure 11. Inhaled therapies for the management of COPD, Tiotropium vs. placebo or Ipratropium

Short-acting anticholinergics alone or in combination with β2 agonists. (Figure 12 on page 72, Evidence Figure 4 in Appendix D *, and Summary Tables 10 and 11 on pages 73–75.) Ipratropium was no more effective than placebo and less effective than tiotroprium in reducing exacerbations and hospitalizations. In four trials of patients with GOLD Stage 3,4 COPD, (range of FEV_1_ percent predicted = 33–45 percent) with followup of 3 months, ipratropium monotherapy did not significantly reduce the percentage of subjects having one or more COPD exacerbations compared with a placebo (ARR = 1.3 percent; RR = 0.95 [0.78 to 1.16]. Between 18 percent and 38 percent of subjects experienced a study-defined exacerbation suggesting that, on average, individuals had symptomatically severe COPD with frequent exacerbations. Three studies reported results from validated respiratory functional status questionnaires. ^98^ , ^99^ , ^105^ The change from baseline between control and ipratroprium was small and less than considered clinically significant (four point difference) in two studies ^98^ , ^99^ and favored tiotropium by three points in the other trial. ^105^ Exacerbation rates for LH-1 (n=3,923; mean FEV_1_ = 2.6; FEV_1_ percent predicted = 75 percent) have not been published. Additional outcomes from LH-1, which is the only trial that enrolled subjects with mild to moderate airflow obstruction regardless of symptoms, are described below. Combination therapy with either short or long acting β agonist (four trials) in addition to ipratropium did not reduce exacerbations compared to ipratropium alone (RR=1.03 95 percent CI=0.64 to 1.67) but did versus β agonists (RR=0.68 95 percent CI=0-.51 to 0.91). ^106^ , ^108^ – ^110^

Figure 12. Inhaled therapies for the management of COPD, Ipratropium vs. placebo or Tiotropium

In the one study comparing ipratropium to tiotropium (n=535) ^105^ the percentage of subjects having at least one exacerbation was higher in the ipratroprium group (46 percent) than subjects randomized to receive tiotropium (35 percent). There was no significant difference in mortality rates between ipratropium and control groups. However, only one study (LH-1) followed patients for more than 1 year. The overall mortality rate in the placebo arm of 2.2 percent was less than the ipratropium group (2.8 percent).

Inhaled corticosteroids. (Figure 13 on page 76, Evidence Figure 5 in Appendix D *, and Summary Tables 12 and 13 on pages 77–80.) In ten placebo-controlled trials (3,734 patients) ^86^ – ^88^ , ^92^ , ^96^ , ^111^ – ^113^ , ^116^ , ^117^ with at least a 6-month followup period, inhaled corticosteroids led to a 22 percent relative reduction in the percentage of subjects having a COPD exacerbation event (RR 0.78; 95 percent CI, 0.70–0.88). The pooled absolute risk reduction was 5 percent (95 percent CI, -8 to -3). Six of the studies were 1 year in duration or longer and the percentage of subjects in the placebo arm that experienced at least one exacerbation was 22.4 percent. ^87^ , ^88^ , ^92^ , ^111^ , ^112^ , ^117^ An additional study ^113^ enrolled 1,116 smokers with moderate airflow obstruction (FEV_1_ percent predicted = 64 percent) and is the only trial of inhaled corticosteroids to report on rates of hospitalizations. Members of the triamcinolone group had fewer overall respiratory symptoms during the course of the study (21.1 per 100 person-years vs. 28.2 per 100 person years, p = 0.005), had fewer visits to a physician because of a respiratory illness (1.2 per 100 person-years vs. 2.1 per 100 person-years), and fewer hospitalizations for respiratory conditions (0.99 per 100 person years vs. 2.1 per 100 person years). There was no significant association between triamcinolone use and specific respiratory symptoms including chronic cough, production of phlegm, or wheezing.

Figure 13. Interventions for COPD using Spirometry, inhaled Corticosteroids vs. placebo

As shown in the meta-analysis by Sin et al. ^9^ and subgroup data from the study by van der Valk ^86^ the beneficial effect of inhaled corticosteroids was associated with the severity of airflow obstruction as measured by FEV_1_. Whereas the study that had the highest mean FEV_1_ value failed to demonstrate a beneficial effect of inhaled corticosteroids, trials that had a mean FEV_1_ of less than 1.7L or lower (mean baseline FEV_1_ percent predicted 36–57 percent) demonstrated a positive effect of inhaled corticosteroids on exacerbations, regardless of the duration of the study or the specific formulation used. Analysis of the subgroup of patients with a FEV_1_ value less than 50 percent predicted (low FEV_1_ group) suggests that the improvement time to first exacerbation due to fluticasone observed in the COPE trial is driven by this group. The hazard ratio was 2.1 (95 percent CI 1.1–36) and 1.2 (95 percent 0.8–2.0) in the low and high-FEV_1_ groups respectively. Inhaled corticosteroids resulted in a 19 percent reduction in all-cause mortality though the confidence intervals were wide and not statistically significant (RR 0.81 95 percent CI = 0.60 to 1.10) and the absolute reduction was only 0.6 percent. Changes in the SGRQ reported in two trials involving 995 subjects followed from 6 months to 3 years were less than considered clinically significant. ^86^ , ^111^

Combination corticosteroids and long-acting inhaled β agonists. (Figure 14 on page 81, Evidence Figures 6–12 in Appendix D *, and Summary Tables 14 and 15 on pages 82–84.) Five multi-arm trials (n=1,982 patients) ^87^ , ^88^ , ^91^ , ^92^ , ^96^ evaluated monotherapy with either LABA or inhaled corticosteroids compared to combination therapy with these agents and to placebo. Thus they provide direct comparative evidence regarding the relative effectiveness of either agent or combination therapy to placebo as well as to their respective monotherapies. The ARR in exacerbations compared to placebo seen with both monotherapies and combination therapy were all statistically significant and of similar magnitude (ARR compared to placebo for LABA = 3.7 percent; corticosteroids = 5.2 percent and combination therapy = 5.9 percent). The addition of inhaled corticosteroids to LABA resulted in a borderline significant reduction in exacerbations compared to LABA alone (RR = 0.82 [0.65, 1.04]; ARR = 1.3 percent). When compared to monotherapy with corticosteroids, there was approximately one-half the reduction reported for comparison to LABA monotherapy (RR = 0.92) and the absolute risk reduction was less than 1 percent. The mean baseline FEV_1_ ranged from 36–45 percent predicted indicating subjects had very severe airflow obstruction (GOLD Stage ≥3). A subgroup analysis reported by Calverley indicated that therapeutic effectiveness varied by severity of baseline spirometry. While the relative risk reduction for combination therapy compared to placebo was 39 percent for all enrollees, individuals with FEV_1_ >50 percent predicted had only a 10 percent relative risk reduction. Improvements in respiratory symptoms compared to placebo as measured at 1 year by the SGRQ were less than considered clinically significant in one trial) (WMD = -2.2; 95 percent CI = -3.3 to -1.1) ^87^ and one study demonstrated a large and clinically relevant improvement of 7.5 units. ^88^ Compared to placebo, combination therapy reduced all-cause mortality by 44 percent, but the confidence intervals were wide and not statistically significant and the absolute reduction was 0.7 percent (RR vs. placebo, 0.66; 95 percent CI, 0.32–1.38). (Summary Table 14 on pages 82–83 and Evidence Figure 6 in Appendix D *.) The addition of LABA to inhaled corticosteroids did not reduce mortality compared to corticosteroids alone (RR = 0.98). However, when compared to LABA, combination therapy with corticosteroids resulted in nearly a 54 percent reduction in mortality though there were relatively few deaths. Thus, monotherapy with corticosteroids may be slightly more effective in reducing exacerbations than LABA. The addition of LABA to corticosteroids does not reduce exacerbations or improve mortality or respiratory status compared to monotherapy.

Figure 14. Combination long-acting B2-agonists and Corticosteriod analyses

Sibanet (D2 receptor/β agonist). (Evidence Figures 13 and 14 and Evidence Tables 16 and 17 in Appendix D *.) Four trials evaluated the D2 receptor/β agonist, sibanet (n=3,524 patients) ^118^ , ^119^ , ^128^ in patients with GOLD Stage 3,4 airflow obstruction. Compared to placebo there was no significant difference in exacerbations (RR, 0.91; 95 percent CI, 0.81 to 1.03; ARR = -0.7). Changes in the SGRQ were small and less than considered clinically important. Only one study was at least 1 year in duration and all-cause mortality was not different between sibanet and placebo (RR vs. placebo, 1.14; 95 percent CI, 0.60–12.15).

Oral purified bacterial extracts. There was a large variety in the reported end points. No more than five trials reported on the same efficacy end point. Three trials reported on the prevalence of exacerbation with OM-85BV or SL-04 over a 6-month period. Two trials (731 patients) were judged to be of high methodologic quality. The combined RR for prevention of exacerbations was 0.83 (95 percent CI, 0.55 to 1.25). Itching or cutaneous eruptions were reported in 3.3 percent of subjects who received active extracts compared with 1.0 percent of control subjects. Data on hospital admission for respiratory problems was reported in 31 of 191 patients (16.2 percent) receiving OM-85BV and in 44 of 190 patients (23.2 percent). Urologic problems (primarily urinary tract infections) were reported in 8 percent of patients who received active extracts compared with 3.0 percent of control subjects. ^120^

Overall withdrawals from treatment, noncompliance, and adverse events were examined for trials 1 year or longer in duration. Subjects treated with a β agonist, tiotropium, or a corticosteroid were less likely to withdraw from treatment for any reason compared to placebo or control. The percent of β agonist subjects withdrawing was 30.8 percent compared with 37.9 percent of the placebo subjects in four trials >1 year (ARR = 7.1; RR = 0.86: 95 percent CI 0.77 to 0.96). ^87^ , ^88^ , ^92^ , ^97^ The overall withdrawal rate for subjects treated with tiotropium was 17.3 percent compared with 27.8 percent and 21.2 percent of placebo and ipratropium subjects, respectively (ARR = 8.3; RR = 0.69: 95 percent CI 0.56 to 0.84). ^104^ , ^105^ Subjects on corticosteroids had a withdrawal rate of 26.5 percent versus 31.9 percent of placebo subjects in seven trials reported withdrawal data (ARR = 5.45; RR = 0.83: 95 percent CI = 0.76 to 0.90). ^87^ , ^88^ , ^92^ , ^111^ , ^112^ , ^114^ The one trial of ipratropium reporting withdrawal data favored the control, tiotropium, 15.2 percent to 21.2 percent (RR = 1.40: 95 percent CI 0.96 to 2.03). ^105^ In trials of combination corticosteroids and long-acting β agonist, withdrawals were lower for combination therapy compared with placebo but were similar compared with either monotherapy.

Four trials reported withdrawal from treatment due to noncompliance. ^87^ , ^97^ , ^105^ , ^111^ The rates of withdrawal ranged from <1 to 16 percent for treatment and <1 to 16 percent for placebo or control. The LHS2 trial reported adherence to treatment based both on patient report and canister weight. Approximately 70 percent of triamcinolone and placebo subjects had satisfactory adherence to the treatment protocol based on self-report. However, these rates decreased to 53.7 percent and 58.5 percent respectively based on canister weights for triamcinolone and placebo. ^114^

Treatments were generally well tolerated. Adverse events during the study followup period were usually minor and seldom more than placebo. Compared to placebo, an increased frequency of oropharyngeal candidiasis (5.1 percent vs. 2.1 percent), throat irritation (7.6 percent vs. 4.5 percent), and bruising (8.4 percent vs. 3.7 percent) was seen with corticosteroid use. Dry mouth was reported in 12 percent of subjects using anticholinergics. ^104^ , ^105^ A separate meta-analysis of 20 RCTs involving 6,623 subjects by Salpeter and colleagues assessed the cardiovascular effects of β agonists (primarily the long-acting β agonists salmeterol and fometerol) in patients with asthma or COPD. Treatment with β agonists was associated with a significantly increased risk for adverse cardiovascular events (RR 2.54; 95 percent CI 1.59 to 4.05; 2.7 percent vs. 0.7 percent). The vast majority of the adverse events in the β agonist group were due to sinus tachycardia (87 percent) and thus of uncertain clinical significance. However, major cardiovascular events were also higher in this group compared to placebo though not statistically different (RR = 1.66; 95 percent CI 0.76 to 3.60). ^129^

2) Nonpharmacological therapies

a. Pulmonary rehabilitation program. (Evidence Table 18 in Appendix D *.) Patients with advanced COPD experience marked dyspnea and exercise intolerance related in part to generalized muscle weakness, cardiac impairments, and nutritional deficiencies. Pulmonary rehabilitation programs were developed to address some of these adverse physiological changes. The contents of pulmonary rehabilitation vary from center to center. However, most contain four major components: exercise training, education, behavioral modification, and outcome assessment. The intensity of the exercise training is heterogeneous. Most aerobic training is targeted at 60–90 percent of the predicted maximal heart rate for about 30 minutes. Most programs emphasize endurance training. The eight clinical trials (693 patients) indicate that pulmonary rehabilitation may improve the health status of patients with severe to very severe COPD (mean FEV_1_, 0.71 to 1.07L; FEV_1_ percent predicted = 31–50 percent) as assessed by SGRQ and increases exercise tolerance beyond that achieved by standard care alone (including inhaled bronchodilators), at least during the time patients are in the rehabilitation program. Three of the eight trials reported an improvement in the SGRQ between control and intervention greater than the four point minimally important difference. ^123^ , ^124^ , ^127^ As noted by Sin, pulmonary rehabilitation did not have any significant effect on mortality. ^9^
b. Disease management, education, and followup studies. (Evidence Table 19 in Appendix D *.) Disease management is an approach to coordinate resources across the health care system with the aim of fostering continuity of care and increasing patients' knowledge and control over their chronic diseases. ^130^ Because the care of patients with COPD frequently requires multiple caregivers, including physicians, nurses, physiotherapists, pharmacists, and nutritionists, a process to promote integration and seamless care may improve clinical outcomes in COPD. Sin et al. noted that because of marked heterogeneity in the content of the programs and their effects, these data need to be interpreted cautiously and further study is required. ^9^ Patients enrolled in these programs had moderate to very severe airflow obstruction (FEV_1_ percent predicted = 37–59 percent), had been previously diagnosed clinically with COPD, and were taking inhaled bronchodilators. It is likely that individuals involved in these programs represent an extremely small fraction of adults likely to be detected by case finding with spirometry. Only one trial reported exacerbation rates and rates of hospitalization were not consistently different between intervention and controls. ^116^ On average, these programs did not achieve a clinically meaningful improvement in health status of patients or a statistically significant impact in hospitalization rates.
c. Non-invasive mechanical ventilation (NIMV). Respiratory muscle fatigue and dynamic hyperinflation commonly are observed in patients with severe COPD. ^131^ – ^133^ Patients with severe COPD work harder than patients without COPD because they have to overcome dynamic lung hyperinflation and airflow obstruction. ^132^ , ^133^ Long-term NIMV therapy theoretically unloads the inspiratory muscles of respiration and helps restore depleted energy stores, as well as partially reversing respiratory muscle fatigue. ^128^ Sin and colleagues concluded that the long-term use of NIMV cannot be recommended at this time because there is insufficient clinical trial evidence for its efficacy. ^21^ , ^134^ – ^136^
d. Influenza and pneumococcal vaccinations. Elderly persons and persons with certain underlying medical conditions experience more than 80 percent of the serious complications of influenza, such as hospitalization and death. ^137^ , ^138^ Among elderly persons, those with a clinical diagnosis of chronic lung disease are an especially high-risk group. Their hospitalization rates for pneumonia are two to seven times those of individuals without underlying pulmonary conditions. Influenza vaccination is recommended for all adults, especially those with chronic medical conditions. High-risk elderly persons, such as those with chronic lung disease, have inadequate vaccination rates. ^139^ Methods to improve influenza vaccinations in these individuals would be beneficial.

A retrospective, multiseason cohort study in a large managed care organization assessed the effects of influenza and the benefits of influenza vaccination in elderly persons with a diagnosis of chronic lung disease during the previous 12 months. Influenza vaccination was associated with fewer hospitalizations for pneumonia and influenza (adjusted risk ratio, 0.48 [95 percent CI, 0.28 to 0.82]) and with lower risk for death (adjusted odds ratio, 0.30 [CI, 0.21 to 0.43]) during the influenza seasons. It was also associated with fewer outpatient visits for pneumonia and for all respiratory conditions. ^140^ However, there is no information assessing whether vaccination rates are improved by case finding with spirometry. Additionally, there is no information to determine whether spirometry should be used to identify asymptomatic individuals with airflow obstruction who should be considered at increased priority for influenza vaccination, especially if vaccination supplies are limited.

Streptococcus pneumoniae is a major cause of morbidity and mortality. Pneumococcal vaccination is often recommended for preventing invasive disease for the elderly and others who are at increased risk for serious pneumococcal infections and their complications. This includes individuals with chronic lung disease. A recent meta-analysis of randomized or quasi-randomized controlled trials assessed the effectiveness of pneumococcal vaccination ^141^ in preventing pneumonia, bronchitis, and mortality. Patient populations and type of vaccine varied in these trials. Two trials limited enrollment to subjects with COPD (n=292). The authors of the meta-analysis concluded that despite encouraging data from some very early trials, pooling trial results published from 1977 on suggest there is no significant effect on pneumonia (14 trials, n=75,008 subjects; OR = 0.77, 95 percent CI = 0.58, 1.02) or death (OR = 0.90, 95 percent CI = 0.90, 1.07). In the two small trials involving subjects with COPD, the odds of definitive pneumococcal pneumonia were actually higher in the groups receiving vaccine than control, though “all-cause pneumonia” was less common in vaccine recipients in one of these studies. The pooled results from case-control studies did demonstrate a significant efficacy in preventing invasive pneumoccocal disease (OR = 0.47 [CI = 0.37, 0.59]) as have other cohort studies among elderly persons with chronic lung disease. However, these pooled data from RCTs suggest that pneumococcal vaccination may not reduce morbidity and/or mortality, especially in individuals with COPD. Furthermore, even if a decision is made, despite the findings from this meta-analysis of RCT, to routinely vaccinate elderly individuals or those with chronic lung disease, there is no evidence that spirometry leads to improved vaccination rates or that outcomes are improved in individuals not reporting respiratory symptoms who have airflow obstruction.

### Does Treatment Effectiveness Vary According to Baseline Spirometry, Spirometric Response to Treatment, and/or Change in Spirometry Over Time?

Periodic monitoring with spirometry has been recommended as a guide to treatment response and/or patient health status. ^142^ However, correlation between spirometric changes and long-term clinical outcomes in COPD has been shown to be weak. ^22^ As noted above, most treatment trials enrolled subjects who had both moderate to severe respiratory symptoms and severe to very severe airflow obstruction. All studies used spirometry to confirm and quantify the presence and severity of airflow obstruction and used spirometric values as entry criteria and most ruled out a clinically significant bronchodilator response. None of the trial protocols involved modification of treatment according to spirometry. Results from large long-term RCTs of inhaled corticosteroids and anti-cholinergics demonstrate that these interventions do not alter the course of spirometric decline. Two studies assessed clinical response according to short-term change in spirometry.

A conceptual model and flow diagram Figure 15 on page 85 illustrates how periodic monitoring with spirometry (e.g., annually or every 3–5 years) may be used to identify symptomatic individuals with normal airflow to mild to moderate airflow obstruction who may subsequently develop severe to very severe airflow obstruction and thus be candidates for treatment. The starting point is based on the pooled summary of treatment effectiveness indicating that interventions with the exception of smoking cessation and influenza vaccinations were only effective in symptomatic individuals (regardless of smoking status) who had severe to very severe (approximately GOLD Stage 3,4) airflow obstruction. Periodic monitoring with spirometry in patients reporting respiratory symptoms would assist the health care provider in initiating or modifying therapy if data demonstrated that outcomes are improved if treatment initiation or modification is based on 1) acute spirometric response to therapy, 2) change in spirometry over time (slope of FEV_1_ decline), or 3) crossing a given followup spirometric threshold (e.g., transition from mild-moderate to severe or very severe; approximately GOLD 1 or 2 to GOLD 3 or 4).

Figure 15. Potential role of spirometry for monitoring patients with symptomatic COPD

### Effectiveness of Treatment According to Baseline Spirometry

All studies of long- and short-acting inhaled anti-cholinergics and long-acting β agonist, except for LH-1 evaluating ipratropium, assessed individuals with severe to very severe airflow obstruction and respiratory symptoms (mean FEV_1_ ranged from 0.96–1.51 and FEV_1_ percent predicted from 33–55 percent; approximately equivalent to GOLD Stage 3). Therefore it is not possible to determine the effectiveness of long-acting anti-cholinergics or β agonist in subjects with spirometry demonstrating mild to moderate airflow obstruction. However, information is available from other inhaled agents suggesting that a spirometric threshold for treatment effectiveness exists and that treatments do not prevent the development of symptoms among individuals not reporting respiratory symptoms.

As shown by Sin and colleagues and confirmed in our results, the effectiveness of inhaled corticosteroids is associated with baseline spirometry as measured by FEV_1_. Three trials enrolling approximately 2,500 subjects with a mean FEV_1_ >2L (GOLD Stage 0–2) and followed for 3 or more years failed to demonstrate a benefit in clinical outcomes, although there was a trend towards a reduction of mortality. Analysis of the subgroup of patients with a FEV_1_ value less than 50 percent predicted (low FEV_1_ group) suggests that the improvement in time to first exacerbation due to fluticasone observed in the COPE trial is driven by this group. The hazard ratio was 2.1 (95 percent CI 1.1–36) and 1.2 (95 percent 0.8–2.0) in the low- and high-FEV_1_ groups respectively. The study by Calverley and colleagues evaluated inhaled corticosteroids alone or in combination with long acting β agonists in subjects with a mean baseline FEV_1_ percent predicted of 45 percent (GOLD Stage 3). ^87^ They observed that treatment effectiveness was associated with disease severity as measured by baseline spirometry. Compared to placebo, combination therapy resulted in a relative risk reduction in exacerbations of 39 percent. However, in the subgroup with baseline FEV_1_ >50 percent (moderate airflow obstruction; GOLD Stage 2) the relative risk reduction was only 10 percent (P value and confidence intervals not provided).

The largest and longest study assessing inhaled bronchodilators (LH-1) compared outcomes of 3,923 adult smokers who were at risk for or had mild to moderate airflow obstruction and treated them with ipratropium vs. placebo over an average of 5 years. Prevalence of baseline symptoms (LH-1) according to spirometric category are shown in Table 4 on page 45. Only a small percentage of subjects had a previous diagnosis of COPD, less than one-half reported dyspnea, about 5 percent had normal spirometry and sputum production (GOLD 0), and almost 20 percent reported no respiratory symptoms. Therefore subjects enrolled in LH-1 are representative of adults likely to be detected by spirometric case finding. In unpublished data obtained from the Data Coordinating Center Director (John Connett, personal communication, 2004) there was no reduction at 3 years in respiratory hospitalizations for subjects with baseline post-bronchodilator assessed GOLD spirometric stages “Normal,” 0, 1, or 2 (Evidence Table 20 in Appendix D *) in subjects randomized to ipratropium compared with placebo. Ipratroprium did not improve outcomes of dyspnea (31.0 percent vs. 31.2 percent), cough and sputum (14.9 vs. 15.0 percent), or respiratory hospitalizations in the overall cohort. Results were not different when assessed according to baseline spirometric stage or symptom status (Table 5 on page 46). The presence of symptoms at baseline, rather than spirometry or treatment, was the best predictor of symptoms at the 3-year followup. Additional analysis demonstrated that ipratropium did not improve the percentage of subjects having dyspnea and cough and sputum at 3 years regardless of presence or absence of these symptoms at baseline (Evidence Figures 15–18 inAppendix D *). These results along with the primary study findings from LH-1 indicate that in smokers with normal airflow to moderate airflow obstruction ipratropium was not effective in altering spirometric decline or the development of respiratory symptoms or respiratory hospitalization.

Table 4 Prevalence of baseline symptoms in LH-1 subjects enrolled in smoking intervention arms according to spirometric category

Spirometric Category | Sputum n (%) | Dyspnea n (%) | Any Symptom n (%) | No Symptoms n (%)
Normal
FEV_1_/FVC >70% | 220 (25.5)* | 357 (41.4) | 674 (78.3) | 187 (21.7)
Stage 1
FEV_1_/FVC <70% | 345 (27.9) | 462 (37.3) | 967 (78.2) | 269 (21.8)
FEV1 >80%
Stage 2
FEV_1_/FVC <70% | 631 (34.5) | 866 (47.4) | 1536 (84.2) | 288 (15.7)
FEV1 50–79%
Totals
3921 (100) | 1196 (30.5) | 1685 (42.9) | 3177 (81) | 744 (18.9)

Sputum is defined as any sputum occurring at least three months per year for at least two years.

Dyspnea is defined as shortness of breath ≥Grade 1.

Any Symptom is defined as cough, sputum, wheeze, or dyspnea. Category overlaps with sputum or dyspnea.

* Subjects with normal spirometry (FEV_1_/FVC >70%) and sputum are GOLD 0 (n=220).

Percent of subjects within each spirometric category in a given symptom category is in parentheses.

Table 5 Outcomes at 3 years in LH-1 subjects according to baseline symptom status (no symptoms vs. any symptom) and treatment assignment

| Outcomes
Symptoms by Spirometry Value at Baseline | Smoking Intervention/Ipratropium n / N (%) | Smoking Intervention/Placebo n / N (%) | Totals n / N (%)
No Symptoms | Cough and Sputum | Cough and Sputum | Cough and Sputum
FEV_1_/FVC >70% | 2/96 (2.0) | 3/78 (3.8) | 5/174 (2.8)
Stage 1
FEV_1_/FVC <70%, FEV_1_ >80% | 8/119 (6.7) | 6/126 (4.7) | 14/245 (5.7)
Stage 2
FEV_1_/FVC <70%, FEV_1_ 50–79% | 12/144 (8.3) | 11/129 (8.5) | 23/273 (8.4)
Totals | 22/359 (6.1) | 20/333 (6.0) | 42/692 (6.1)
Any Symptom | Cough and Sputum | Cough and Sputum | Cough and Sputum
FEV_1_/FVC >70% | 42/302 (13.9) | 47/321 (14.6) | 89/623 (14.2)
Stage 1
FEV_1_/FVC <70%, FEV_1_ >80% | 89/454 (19.6) | 64/466 (13.7) | 153/920 (16.6)
Stage 2
FEV_1_/FVC <70%, FEV_1_ 50–79% | 120/715 (16.7) | 142/697 (20.3) | 262/1412 (18.5)
Totals | 251/1471 (17.0) | 253/1484 (17.0) | 504/1955 (25.7)
No Symptoms | Dyspnea | Dyspnea | Dyspnea
FEV_1_/FVC >70% | 12/95 (12.6) | 6/77 (7.7) | 18/172 (10.4)
Stage 1
FEV_1_/FVC <70%, FEV_1_ >80% | 17/118 (14.4) | 15/124 (12.1) | 32/242 (13.2)
Stage 2
FEV_1_/FVC <70%, FEV_1_ 50–79% | 27/142 (19.0) | 17/128 (13.2) | 44/270 (16.2)
Totals | 56/355 (15.7) | 38/329 (11.5) | 94/684 (13.7)
Any Symptom | Dyspnea | Dyspnea | Dyspnea
FEV_1_/FVC >70% | 110/297 (37.0) | 100/321 (31.1) | 210/618 (33.9)
Stage 1
FEV_1_/FVC <70%, FEV_1_ >80% | 130/451 (28.8) | 147/462 (31.8) | 277/913 (30.3)
Stage 2
FEV_1_/FVC <70%, FEV_1_ 50–79% | 266/706 (37.6) | 279/691 (40.4) | 545/1397 (39.0)
Totals | 506/1454 (34.8) | 526/1474 (35.6) | 1032/2928 (35.2)

Sputum is defined as any sputum occurring at least 3 months per year for at least 2 years

Dyspnea is defined as shortness of breath ≥Grade 1

Any Symptom is defined as cough, sputum, wheeze, and dyspnea. Category overlaps with sputum and dyspnea.

The Lung Health Study-2 recruited 1,116 participants who had previously participated in or had been screened for the LH-1 study and randomized them to the inhaled corticosteroid triamcinolone or placebo. Almost 90 percent of subjects were current smokers, but fewer than 20 percent of subjects had a previous physician diagnosis of emphysema or chronic bronchitis. Approximately one-third had daily cough and phlegm and 40 percent had some level of dyspnea. The mean FEV_1_ after bronchodilator was 2.3L (68 percent predicted: GOLD Stage 2). Thus, these individuals are representative of subjects who might be detected by case finding with spirometry. After a mean duration of followup of 40 months the rate of decline in the FEV_1_ after corticosteroid use was similar in the 559 participants in the triamcinolone group and the 557 participants in the placebo group (mean approximately = 44mL/year). Members of the triamcinolone group had fewer overall respiratory symptoms during the course of the study (21.1 per 100 person-years vs. 28.2 per 100 person-years, p = 0.005) and had fewer visits to a physician because of a respiratory illness (1.2 per 100 person-years vs. 2.1 per 100 person-years). There was no significant association between triamcinolone use and the development of specific respiratory symptoms of chronic cough, production of phlegm, or wheezing.

### Acute Response to Inhaled Bronchodilators to Assess and/or Modify Therapeutic Effectiveness

Several studies have assessed the short-term variability in FEV_1_ and bronchodilator responsiveness in patients with obstructive ventilatory defects. GOLD spirometric classification of COPD severity is based on postbronchodilator FEV_1_ and a finding that patients do not show a significant FEV_1_ response (<12 percent or 200mL) to a short-acting bronchodilator. Thus, spirometry has been suggested as being useful for determining whether patients with respiratory symptoms have reversible airflow obstruction (rather than COPD) based on postbronchodilator response. Two studies have assessed the ability of bronchodilator reversibility or acute response to bronchodilator therapy to predict response to treatment in patients with COPD.

One study tested the ability of acute change in FEV_1_ following inhaled short-acting β agonist to predict long-term symptomatic response to albuterol and theophylline. ^143^ The reproducibility of acute change over three repetitions was poor (intraclass correlation 0.17). Furthermore, the mean improvement in FEV_1_ following inhaled albuterol across the three repetitions did not relate closely to symptomatic response to either albuterol or theophylline. For example, if a bronchodilator response >15 percent was used, then the sensitivity and specificity for predicting symptomatic improvement as measured by a four-point improvement in physical function on the CRQ to albuterol was 0.86 and 0.30 respectively. If the percent response was 25 percent, then sensitivity and specificity were 0.43 and 0.80 respectively.

Calverley and colleagues assessed the bronchodilatory reversibility to determine “responders” and “non-responders” in Inhaled Steroids in Obstructive Lung Disease (ISOLDE) study. They found that mean post-bronchodilator response to salbutamol, ipratropium, and the combination was reproducible. The absolute change in FEV_1_ was independent of the pre-bronchodilator value, but the percentage change correlated with pre-bronchodilator FEV_1_. The rate of decline in FEV_1_, decline in health status, and exacerbation rate were unrelated to bronchodilator response. They concluded that bronchodilator response was a continuous variable, the criteria used for determining asthmatic status largely arbitrary and classifying adults as responders and non-responders can be misleading and does not predict disease progression. ^7^ None of the trials modified therapy based on acute response to inhaled bronchodilator.

Based on these results, acute spirometric response to inhaled bronchodilators does not appear to be useful for initiating or modifying treatment in subjects with COPD or predicting spirometric decline. The effectiveness on clinical outcomes due to modification or selection of treatment based on spirometric response has not been studied in randomized trials. However, it may help identify some subjects with asthma or a large asthmatic component to COPD.

### Change in Spirometric Slope Over Time as a Guide to Therapy

Long-term studies of inhaled long-acting anticholinergics and inhaled corticosteroids have demonstrated that these agents reduce exacerbations in selected individuals. However, this improvement is not related to acute response to therapy nor do pharmacologic interventions alter the course of airflow obstruction as measured by spirometric decline. In contrast to pharmacologic interventions used for treatment or prevention of symptomatic COPD which do not alter spirometry, medications used to prevent or treat heart disease, stroke, or diabetes have been shown to alter the disease specific surrogate measures (i.e., lower blood pressure, cholesterol, or glucose). Furthermore, clinically important outcomes of morbidity and mortality are directly related to both therapeutic response in these levels as well as achieving a given surrogate threshold. Trials evaluating long- and short-acting β agonists, short-acting anticholinergics, and sibanet all followed subjects for 1 year or less. None of the randomized trials adjusted interventions based on change in spirometric slope over time or whether patients' spirometry reached a certain threshold. Many studies used baseline spirometric values as entry criteria. However, inhaled bronchodilators and inhaled corticosteroids provide clinical benefits in symptomatic individuals with severe to very-severe airflow obstruction. Thus, spirometry at baseline or at an unknown interval in subjects with activity limiting respiratory symptoms is likely to be useful in identifying a threshold of airflow obstruction severity, whereby pharmacologic interventions may be effective. The available evidence suggests that this threshold appears to be approximately at an FEV_1_ of 50 percent predicted or lower.

Based on the average rate of decline in FEV_1_ of approximately 50mL/year, it may be reasonable to consider monitoring spirometry every 5 to 10 years in symptomatic patients with moderate airflow obstruction who are not yet receiving treatment in order to determine if they cross a threshold of spirometry where interventions may be effective. However, as shown in LH1 and cohort studies, there is considerable variability with these measurements. Thus making treatment decisions based on an individual's change in spirometry over time is problematic. Because pharmacologic interventions are not effective in individuals not reporting respiratory symptoms and likely of little benefit in those whose symptoms are mild or not bothersome, baseline or monitoring spirometry does not appear to be beneficial in these individuals. Additionally, once pharmacologic agents are initiated, evidence suggests that periodic spirometric monitoring does not provide a beneficial measure of response to treatment or guide for treatment modification. Furthermore, limited evidence indicates that response to therapy varies little by class of long-acting inhaled medications, within class effectiveness does not vary according to dose, and combination therapy compared to monotherapy does not improve respiratory functional status measures, exacerbation rates, or mortality.

### Estimating Treatment Benefit, Number Needed to Screen and Treat

In an attempt to estimate the possible benefits and harms associated with case finding and treatment based on spirometry and symptom status, we used data related to the prevalence and severity of airflow obstruction and symptom status from NHANES III in combination with efficacy results from treatment intervention trials using inhaled bronchodilators and inhaled corticosteroids. Such an approach, conceptually outlined in Figure 16 on page 86, provides estimates of the number of adults required to receive testing with spirometry and treatment with interventions other than smoking cessation or vaccinations in order to reduce the percentage of adults having at least one exacerbation.

Figure 16. Spirometric and symptom evaluation and subsequent treatment according to smoking, symptom, and spirometric status among adults in primary care clinic

Our approach takes the following assumptions based on the available data: 1) one time spirometry without bronchodilator or bronchoconstrictor assessment would be conducted in all previous or current smokers regardless of symptoms and in “never smokers” if they had any persistent respiratory symptom (wheeze, cough, sputum, or dyspnea); 2) symptom status was the same for each spirometric stage regardless of smoking status (data were not available according to smoking status); 3) primary care based spirometry detects airflow obstruction similar to that found in large population based studies using diagnostic spirometers without bronchodilator testing; 4) all patients detected by spirometric case-finding would not have been detected in the absence of spirometric testing; 5) symptomatic subjects with a given spirometric value found in population-based studies not using bronchodilator testing have similar symptoms and outcomes as stage matched controls enrolled in intervention studies many that enrolled subjects based on postbronchodilator spirometry; 6) subjects not reporting respiratory symptoms do not benefit from any intervention other than smoking cessation regardless of severity of airflow obstruction; 7) spirometric testing does not improve smoking cessation rates beyond counseling and pharmacologic interventions; 8) effectiveness of interventions other than smoking cessation and influenza vaccination are limited to subjects with bothersome respiratory symptoms who have severe to very severe airflow obstruction (GOLD Stage 3,4) (though we provide sensitivity analyses for subjects with GOLD Stage 2 airflow obstruction); 9) prior to establishing a diagnosis COPD or beginning COPD specific therapy, spirometry is conducted to demonstrate severe to very severe airflow obstruction; 10) long-acting inhaled therapies have similar effectiveness with different adverse effects); and 11) combination therapy does not provide clinically important benefits compared to monotherapy.

Figure 17 on page 87 demonstrates the results of spirometric and symptom assessment and subsequent treatment according to smoking status as might be seen in a primary care clinic of 10,000 adults that resembled the adult population from NHANES. It represents the potential number of adults presenting that would need to be evaluated to identify candidates for treatment and then the number that are likely to benefit from assessment and treatment. Because data were not available to detect symptom status according to GOLD stage for the various smoking categories, we assumed that symptom status was the same for each spirometric stage regardless of smoking status. Smoking status is ascertained in all adults in a primary care setting regardless of symptoms. From NHANES III results we determined that the prevalence of current, former, and never smoking adults equals 29 percent, 24 percent, and 47 percent and the prevalence of any respiratory symptoms for never smokers equals 27 percent (activity limiting dyspnea = 17 percent). NHANES results indicate that GOLD Stage 3,4 is present in 3 percent of “never smokers” reporting respiratory symptoms (an additional 8.6 percent have GOLD Stage 2 airflow obstruction).

Figure 17. Number of adults evaluated, treated, and receiving benefit from spirometric in primary care clinics

Thus, 1,288 never smokers would report respiratory symptoms and undergo spirometric testing. This would yield approximately 39 never-smoking adults who had assessment of symptoms and subsequently underwent spirometry for evaluation of symptoms who would be candidates for COPD therapy. From data indicating that treatment benefit was limited to subjects reporting respiratory symptoms and GOLD Stage 3,4 airflow obstruction the number of “never smokers” needed to receive symptom status assessment and subsequent spirometric testing in order to identify one candidate for effective COPD treatment is 120 (number needed to evaluate = 120). Based on pooled results from RCT of tiotropium demonstrating a 6 percent absolute risk reduction in subjects having COPD exacerbations (number needed to treat = 16.7) we conclude that two out of 4,700 primary care patients would be never smokers who would benefit from evaluation and treatment (0.04 percent of never smokers). Alternatively, using this approach one subject among 2,043 never smokers presenting to a primary care provider would have ≥1 COPD exacerbations prevented after 6 to 36 months of treatment.

For “increased risk individuals” based on a history of smoking, spirometry is considered regardless of symptom status. In the hypothetical population spirometry would be conducted in all 2,900 adults who were current smokers and 2,400 who were previous smokers. The prevalence of severe to very severe airflow obstruction (approximately GOLD Stage 3,4) is 2.2 percent in previous smokers and 2.1 percent for current smokers (7.3 percent and 10.6 percent have GOLD Stage 2, respectively). From population data of subjects with GOLD Stage 3,4 disease regardless of smoking status we estimate that 79 percent will have any respiratory symptom (approximately 60 percent have dyspnea). There would be 42 previous smoker and 48 current smoker candidates for treatment. Therefore, the number of previous smokers and current smokers regardless of symptom status needed to screen to identify a candidate for potentially effective treatment is 57 and 60 respectively. Assuming similar treatment efficacy regardless of baseline smoking status, we estimate that three current smokers (0.11 percent) and two former smokers (0.1 percent) would benefit. Alternatively, 960 former smokers and 1,010 current smokers would need to be initially tested with spirometry and subsequent treatment provided for the GOLD Stage 3,4 patients to prevent one adult from having ≥1 COPD exacerbation over a 6 to 36 month time period. Therefore, in a primary care population of 10,000 adults similar to NHANES III respondents, 6,588 would undergo spirometric testing, 129 (1.3 percent) would be candidates for COPD therapy, and 8 (0.07 percent) would benefit. Benefits could be maintained by reserving testing and treatment for individuals reporting bothersome respiratory symptoms (especially dyspnea, exercise intolerance, and COPD exacerbations). If spirometry was targeted to individuals with dyspnea regardless of smoking status the number needed to screen and treat for severe to very severe airflow obstruction would be 475.

The average change in validated respiratory status scores compared to placebo did not achieve clinical significance. However, additional analyses in two studies indicated that the percentage of individuals who reported a clinically significant change in SGRQ scores (at least 4 point improvement) was greater with tiotropium than placebo (49 percent versus 35 percent; ARD = 14.4 percent). Using this information the number needed to treat for adults who are candidates for therapy to achieve a clinically significant change in SGRQ is 7. Therefore, among the 129 candidates for treatment, 18 (0.2 percent) would have a clinically noticeable improvement in their respiratory health status.

The evidence indicates that treatment other than smoking cessation and vaccinations in symptomatic subjects with airflow obstruction that is less severe than GOLD Stage 3,4 disease provides little to no benefit. Additionally, differences in health status are not evident until the development of GOLD Stage 3 and 4 disease. ^144^ Nonetheless, if GOLD Stage 2 subjects are considered to benefit from treatment to a similar degree as GOLD Stage 3 to 4, then the number initially needed to evaluate and subsequently treat would be 520, 273, and 208 respectively for “never smokers with respiratory symptoms,” “previous smokers regardless of symptom status,” and “current smokers regardless of symptom status.” In a population of 10,000 adults, approximately 529 adults (5.3 percent) would be candidates for treatment and 32 (0.3 percent) would be prevented from having at least one exacerbation compared to placebo (approximately 76, or 0.8 percent, would have a clinically noticeable improvement in respiratory health status).

Our assumptions are optimistic for the following reasons. Most subjects enrolled in treatment trials demonstrating benefit had severe respiratory symptoms (especially frequent exacerbations) that would likely require and benefit from pharmacologic intervention. We chose “any respiratory symptom” as a “clinically significant”/activity limiting or bothersome symptom that would benefit from therapy. However, treatment trials indicated that the average improvements in health status and dyspnea were not clinically significant. Other clinically relevant outcomes such as rates of hospitalization were rarely reported. However, differences in the studies that selectively published hospitalizations were between 4 and 7 percent. Additionally, except for oxyen therapy in the small percentage of patients with resting hypoxemia, interventions did not reduce mortality. Therefore the benefit of interventions appears to be primarily limited to reduction in exacerbations. Treatment of individuals whose only symptoms are wheeze and cough is unlikely to be beneficial because these symptoms have little if any impact on quality of life.

We did not conduct a formal cost effectiveness analysis. However, it is important to consider the potential costs of spirometric testing and treatment. This needs to be weighed against the costs associated with symptomatic COPD including lost productivity, hospitalizations, and other medications that might occur due to potentially preventable disease progression. Additionally, based on NHANES results only 17.4 percent of adults who reported a clinical diagnosis of COPD, had 1987-ATS defined low lung function, suggesting that many individuals have an inaccurate clinical diagnosis of COPD. Furthermore, less than half of these individuals reported shortness of breath and only 25 percent had chronic sputum production (GOLD 0). Many adults may be treated unnecessarily with COPD specific medications in the absence of spirometric testing and assessment of respiratory symptoms.

The cost of a single primary care based spirometric evaluation (excluding confirmatory evaluations via diagnostic spirometry, bronchodilator testing, and/or followup office-based tests) is estimated between $10 and $40. ^2^ At a cost per day ranging from $2.66 to $4.00 the annual inhaled drug cots using long-acting monotherapy would be between $971 and $1,460 per treated patient or $4.5 to $6.8 billion to treat the estimated 4 percent of adults with dyspnea and severe to very severe airflow obstruction (n = 4,630,000) (average wholesale price for a 100 unit container, or closest size in the 2004 Red Book). Effectiveness would be similar but drug costs and adverse events would be higher if combination therapy was routinely used instead of monotherapy. Compared to diagnosis and treatment based on clinical examination alone spirometry is likely to reduce the number of individuals reporting symptoms who are inaccurately diagnosed with, and treated for, COPD because they do not have airflow obstruction of severity where treatment is beneficial. Among subjects with bothersome respiratory symptoms spirometry may enhance identification of untreated patients with severe airflow obstruction. Additionally, prevalence estimates from NHANES included individuals as young as 17 years old. Because most patients attending adult primary care clinics are over age 40 the number of individuals needed to receive spirometry in order to successfully identify candidates for treatment would be lower than results we estimated. However, many current recommendations do not provide an age criteria for initiating spirometric testing and they also recommend that spirometric testing be conducted in adults without respiratory symptoms and who have no history of smoking but do have exposure to additional risk factors including passive smoke and environmental toxins. Adherence to these recommendations would increase the number needed to receive wide spread spirometric testing without adding to benefit.

## Question 4 Is prediction of prognosis based on spirometry, with or without clinical indicators, more accurate than prediction based on clinical indicators alone?

Spirometry has been shown to have prognostic effect in determining mortality and disease specific morbidity. The risk of death in patients with COPD is often graded with the use of a single physiological variable (FEV_1_). However, other risk factors such as hypoxemia, hypercapnia, exercise intolerance, or body mass index are also associated with mortality. Additionally, observational studies have found that the degree of dyspnea and health-status scores are more accurate predictors of the risk of death than is the FEV_1_. ^145^ Based on discussion with our TEP we focused on studies that would provide prognostic information related to future COPD outcomes, especially respiratory symptoms and spirometric stage.

Celli and colleagues developed and tested a multidimensional grading system that assessed the respiratory and systemic expressions of COPD in predicting outcomes. They evaluated 207 patients with known COPD and found that four factors predicted the risk of death: the body-mass index (B), the degree of airflow obstruction as measured by spirometry (O), and dyspnea (D) and exercise capacity (E) as measured by the 6-minute walk test. The factors were subsequently validated in a multinational cohort of 625 patients with an assessment of death from any cause and from respiratory causes. Points were added for each variable so that the BODE index ranged from 0–10 points, with higher scores indicating a greater risk of death. FEV_1_ categories used in developing the BODE index were based on American Thoracic Society 1995 categorization. Point values contributing to the BODE index for FEV_1_ percent predicted were FEV_1_≥ 65 = 0 points; 50–64 = 1 point; 36–49 = 2 points; ≤ 35 = 3points. At a median followup of 28 months, the probability of survival was approximately 90 percent, 90 percent, and 75 percent for subjects with Stage I, Stage II, and Stage III COPD respectively as defined by the American Thoracic Society in 1995. Patients with higher BODE scores were at higher risk for death. The probability of survival for subjects with a BODE index in the lowest Quartile was 92 percent vs. 60 percent in the highest quartile. For each one point increment in the BODE score, the hazard ratio for death from any cause was 1.34 (95 percent CI 1.26 – 1.42) and the hazard ratio for death from a respiratory cause was 1.62 (95 percent CI 1.48 – 1.77). The BODE index was better able to predict death than the FEV_1_ alone. ^145^ It is not known how the BODE index might perform on subjects detected by case finding with spirometry, especially individuals not reporting respiratory symptoms.

Fletcher and coworkers showed a relationship between the level of FEV_1_ at baseline and its slope (i.e., rate of decline over time). ^146^ This relationship was considered a model of the preclinical course of COPD and advocated as a method for early detection and assessment of subsequent prognosis. As such, it could be useful for early identification of subjects (especially smokers) in the preclinical state who might be at increased risk for rapid decline in lung function so that they could be especially targeted for smoking cessation programs.

As shown in the assessment of Question 1, the prevalence of respiratory symptoms is associated with severity of airflow obstruction as measured by spirometry. For example, in community-dwelling subjects ages 18 or older, the prevalence of respiratory symptoms was 23.3 percent in subjects with normal spirometry (excluding chronic sputum production, i.e., GOLD 0), 50.8 percent in GOLD 1, 60.1 percent in GOLD 2, and 79 percent in subjects with GOLD Stage 3,4. However, as we described earlier, data from LH-1 and other longitudinal cohort studies demonstrate that the presence of symptoms at baseline is a better measure of future symptoms than spirometric stage.

Several studies assessed the prognosis of baseline spirometry and/or GOLD classification on COPD and spirometric progression. Results from the LH-1 evaluated whether baseline FEV_1_/FEV_6_ predicted subsequent lung function decline in adult smokers. After controlling for age, gender, cigarettes per day, years of education, and bronchial hyper responsiveness, FEV_1_/FEV_6_ was an independent predictor of subsequent decline in lung function in both men and women. Those with the lowest decile of FEV_1_/FEV_6_ at baseline lost more than twice as much lung function over the next 5 years when compared to those with the least baseline airways obstruction (FEV_1_ fell 93.2mL/year vs. 44.5mL/year for men). A multivariate model that included FEV_1_/FEV_6_ predicted 11 percent of the variance in subsequent change in lung function indicating that unmeasured factors account for nearly 90 percent of the variation in lung function decline. ^147^ These findings are similar to those of Fletcher and Burrows. ^146^ , ^148^ They suggest that baseline degree of airways obstruction as measured by spirometry is a predictor of the subsequent worsening in airway obstruction in smokers. Positive associations in the study by Burrows and colleagues were observed only in male smokers. Change in FEV_1_ could not be predicted in women or exsmokers.

Table 6 on page 53 shows 5 and 15 year followup in subjects without COPD and with GOLD 0 at baseline in the Copenhagen Heart Study. ^149^ Subgroup results were also presented for subjects who were smoking at baseline. At 5 and 15 years GOLD 0 subjects are not more likely to progress to COPD Stages 1–3 when compared to subjects without COPD at baseline. This suggests that chronic cough and sputum production is not an independent predictor for progression to COPD in subjects with normal baseline spirometry. Thus, based on these results, GOLD 0 subjects should not be considered “at risk.”

Table 6 Prevalence of different stages of COPD after 5 and 15 years in subjects without COPD and with GOLD 0 at baseline

| No COPD at Baseline / All Subjects | No COPD at Baseline / Subjects Smoking at Baseline | Gold 0 at Baseline / All subjects | Gold 0 at Baseline / Subjects Smoking at Baseline
Copenhagen City Heart Study ^149^
[underlined: 5-year followup]
COPD Stage 1 | 4.30% | 4.90% | 5.70% | 5.80%
COPD Stage 2 | 5.30% | 6.70% | 6.70% | 7.40%
COPD Stage 3 | 0.10% | 0.10% | 0% | 0%
[underlined: 15-year followup]
COPD Stage 1 | 7.20% | 9.90% | 13.50% | 14.80%
COPD Stage 2 | 5.80% | 8.40% | 5.00% | 5.70%
COPD Stage 3 | 0.20% | 0.20% | 0% | 0%

Additional data provided by Dr. Vestbo (personal communication, November 2004) from the Copenhagen Heart Study evaluated the point prevalence of specific respiratory symptoms (dyspnea, cough, sputum) and the prognostic significance of GOLD classification over a 10-year period (year 5 to year 15 followup). Complete respiratory symptom data (especially dyspnea) were not available at year 0 (n=13,091) and thus we considered year 5 as baseline (n=11,734) for purposes of this reporting. It should be noted that the spirometric stages and prevalence of sputum production were similar at year 0 and year 5 thus providing some confidence in using the 5-year results as baseline data. The prevalence (and percent within each category reporting no respiratory symptoms) of GOLD stage at year 5 was: normal spirometry = 79.1 percent (58.1 percent); GOLD 0 = 6.5 percent (by definition all had sputum production); GOLD 1 = 5.4 percent (53.9 percent) and GOLD 2 = 8.6 percent (32.5 percent).

Among subjects who were GOLD 0 at year 5 and provided followup information (n=417) 10 years later, only 47.5 percent still had chronic mucous production. This suggests that over many years chronic mucous production is not a stable condition. However, these results do not include subjects who were lost to followup or died, and there is no information regarding smoking status. Over time, symptoms of breathlessness also tended to become less frequent in all spirometric stages. This may be due to selection (loss to followup of those most severely ill), variable response to the question, institution of therapy, alteration in activity due to other factors, or variability in the natural history of dyspnea. According to GOLD stage the presence of dyspnea when “hurrying on the street or while walking up hill” at year 15 among those individuals who reported similar levels of dyspnea at year 5 was GOLD Normal = 67.4 percent; GOLD 0 = 74.3 percent; GOLD 1 = 74.2 percent, and GOLD 2 = 76.7 percent. Thus, even among the small percentage of subjects who were GOLD 0 at baseline and progressed to Stage 1 or 2 after 15 years (13 percent and 5 percent respectively), many had no activity limiting respiratory symptoms. Therefore, the prognosis regarding activity limiting respiratory symptoms after 10 years among GOLD 0 subjects and those with mild to moderate airflow obstruction appears to be quite good. Additionally, compared to subjects without COPD, individuals with Stage 0 were not at higher risk for mortality over a 15-year followup period after controlling for age, sex, smoking, and inhalation. In contrast to the above findings in patients with normal lung function, the presence of chronic mucous hypersecretion does appear be an important risk factor for spirometric decline and risk of hospitalization in subjects with baseline abnormal lung function.

Similar findings were reported by Fletcher and Peto. ^146^ A cohort of 792 men ages 30–59 at baseline were followed every 6 months with assessment of airflow obstruction by measuring FEV_1_ and questionnaires to assess smoking status, mucus hypersecretion, and bronchial infections. Their results demonstrated that FEV_1_ falls gradually over a lifetime, but in most nonsmokers and many smokers clinically significant airflow obstruction never develops. In susceptible people, smoking causes irreversible obstructive changes. If a susceptible smoker stops smoking he will not recover his lung function, but the average further rates of loss of FEV_1_ will revert to normal. However, infective processes and chronic mucus hypersecretion did not cause airflow obstruction to progress more rapidly. After adjusting for FEV_1_ level, smoking, age, and height there was no independent correlation between FEV_1_ slope and indices of either mucus hypersecretion or bronchial infections. There also were no changes in FEV_1_ level to changes in sputum production or episodes of infection. These findings indicate that chronic mucus hypersecretion in subjects with normal lung function (GOLD 0) is not independently prognostic for development of COPD.