# Introduction

## Overview

Chronic Obstructive Pulmonary Disease (COPD) is manifested by chronic cough, sputum production, and, in later stages, dyspnea, poor exercise tolerance, and signs/symptoms of right-sided heart failure. In more than 80 percent of cases, cigarette smoking is causally linked to the development of COPD. Other potentially modifiable risk factors include exposure to noxious gases, pollution, passive smoke, and chronic respiratory infections. Symptomatic COPD affects more than 5 percent of the adult population, is the fourth leading cause of death, and is the twelfth leading cause of morbidity in the United States. ^1^ The total economic costs of COPD were estimated to be $24 billion in 1993 ^2^ and the total direct cost of medical care is approximately $15 billion per year. These figures likely vastly underestimate the burden of COPD because airflow obstruction is a contributor to other health conditions. ^3^ – ^5^

In symptomatic individuals, COPD is diagnosed through the use of spirometric testing that demonstrates airflow obstruction that is not fully reversible which is due largely to airway narrowing and emphysema. The spirometric definition of airflow obstruction has evolved over time and varies according to criteria used. Normal values of spirometry are derived largely based on population distributions according to race, gender, and age. Most recently airflow obstruction has been defined as a postbronchodilator Forced Expiratory Volume in 1 second (FEV_1_) value of less than 80 percent of predicted, in association with an FEV_1_ to Forced Vital Capacity ratio (FEV_1_/FVC) of less than 70 percent. Both the FEV_1_ and FVC values are usually reduced in patients defined as having airflow limitation. Because the FEV_1_ is affected more than the FVC, the ratio of the FEV_1_ to FVC (FEV_1_/FVC) also decreases.

The Global Initiative for Chronic Obstructive Lung Disease (GOLD) is comprised of an international committee of clinicians and scientists with the goal of increasing awareness of COPD and decreasing disease specific morbidity and mortality. The GOLD committee recently published a consensus report that defined COPD as “a disease state characterized by airflow limitation that is not fully reversible. The airflow limitation is usually both progressive and associated with an abnormal inflammatory response of the lungs to noxious particles or gases.” ^6^ Most guidelines also state that patients with COPD have an incomplete response to the inhaled bronchodilator albuterol (change in FEV_1_ <200mL and 12 percent of baseline) and typically do not have evidence of airway hyper responsiveness. Although these features may be helpful in differentiating COPD from chronic asthma, they are not clear-cut, are potentially misleading, and do not predict spirometric progression. ^7^

The 2003 GOLD guidelines have proposed five different stages of COPD based largely on postbronchodilator FEV_1_ measures. These range from Stage 0 (“At Risk” FEV_1_ normal [i.e., ≥80 percent in the presence of chronic cough and sputum production] to Stage 4 [“very severe” FEV_1_ <30 percent predicted in association with FEV_1_/FVC <70 percent or <50 percent plus chronic respiratory failure]). This classification, as well as recommendations for treatment does not require the presence of respiratory symptoms that include wheezing, chronic cough, sputum production, and dyspnea. GOLD guidelines recommend that a diagnosis of COPD should be considered and spirometry performed for any patient who has cough, sputum production, or dyspnea, and/or a history of exposure to risk factors for the disease. ^6^ , ^8^ This includes all current and former smokers, and any adult with a history of exposure to tobacco smoke, occupational dusts and chemicals, or smoke from home cooking and heating fuels. Undiagnosed airflow obstruction, and the severity of FEV_1_ impairment, is independently associated with poorer health and functional status. ^3^ Office-based case finding of at-risk individuals with spirometry by primary care providers is being encouraged. Symptomatic disease is often not present until advanced airflow obstruction occurs and many patients with symptomatic airflow obstruction remain undiagnosed.

Spirometric testing in primary care settings for COPD case-finding, diagnosis, and management may improve diagnostic accuracy, provide effective interventions for at risk individuals to slow progression of spirometric decline, prevent and relieve respiratory symptoms, improve exercise tolerance and health status, prevent and treat complications from end-stage lung disease, and reduce mortality. Spirometry may be resource intensive; it may identify and label as “diseased” a large group of individuals who may not have, nor develop, symptoms and in whom therapy is neither effective nor necessary. Spirometry may not improve health outcomes or smoking cessation rates. As a guide to management, it is not clear if therapy based on an individual's baseline or followup spirometry, spirometric response to treatment, or change in spirometry over time produces superior outcomes compared to therapy determined by clinical history and physical examination.

Concern has been raised about the costs associated with primary-care office based spirometry. Although a single spirometric test done without bronchodilators is relatively inexpensive, the aggregate economic and health effects of testing all adults with a history of exposure to risk factors (regardless of whether they report respiratory symptoms) and non-smoking adults with chronic respiratory symptoms are large. Followup visits, repeat office spirometry, full pulmonary function tests with bronchodilator testing, lung imaging, drug prescriptions, and smoking cessation interventions would follow initial primary-care office spirometry in many patients. ^4^

The purpose of this report is to provide objective evidence and recommendations to inform the work of the American Thoracic Society (ATS), in collaboration with the American Academy of Family Practitioners (AAFP), the American College of Physicians (ACP) and the American Academy of Pediatrics (AAP) Spirometry Task Force in clarifying usage of spirometry as part of the management of COPD. The Minnesota EPC (contract awardee) was requested to address the following preliminary questions using GOLD 2003 criteria as definitions of airflow obstruction:

What is the evidence that case-finding using spirometry, compared to clinical assessment, increases detection of patients with clinically significant disease?

What is the evidence that therapy based on spirometry (for initial therapy and/or followup) produces better outcomes than therapy based on clinical assessment?

What is the evidence that benefits of specific therapies to improve symptoms in COPD varies based on severity of COPD as assessed by spirometry?

What is the evidence that predictions or prognosis based on spirometry, with or without clinical indicators, are more accurate than prediction based on clinical indicators alone?

Initial discussion with representatives from ATS, AAFP, ACP, AAP, and technical expert panel members resulted in question refinement and the final Key Questions. These changes were based on development of an analytic framework that was developed to assess the key questions along the causal pathway of case finding, diagnosis, treatment, and outcomes. The framework describes the logical chain that should be supported by evidence to link spirometry to improved health outcomes. It takes the perspective of adults presenting to primary health care settings based on smoking and symptom status. It evaluates pathways related to spirometric and symptom status and potential benefits or harms of therapeutic interventions.

Key Question 1 What is the prevalence of chronic obstructive pulmonary disease (COPD) and airflow obstructions in various adult populations as defined by: 1) spirometry and 2) clinical examination?

Key Question 2 Can use of spirometry lead to increased smoking cessation rates?

Key Question 3 Does the effectiveness of specific therapies to improve clinically relevant outcomes in COPD vary based on baseline or followup spirometry, short-term spirometric response due to initial therapy, or spirometric progression over time?

Key Question 4 Is prediction of prognosis based on spirometry, with or without clinical indicators, more accurate than prediction based on clinical indicators alone?

## Background

Less than half of the estimated 24 million Americans with impaired lung function have physician-diagnosed COPD. ^5^ A clinical diagnosis of COPD is often not made until patients have fairly advanced diseases that result in considerable functional impairment. Additionally, in the absence of spirometric testing, some individuals with dyspnea, wheezing, cough, or poor exercise tolerance due to COPD may not receive effective treatment because their symptoms are attributed to other etiologies (e.g., congestive heart failure) or conversely are misdiagnosed and treated erroneously for COPD when symptoms are due to other conditions. Because cigarette smoking is the greatest risk factor for development and progression of COPD, spirometric assessment of lung function may serve as a motivational tool to enhance smoking cessation rates. Spirometry may also be useful as a guide to 1) initiating treatment, 2) monitoring treatment effectiveness, 3) adjusting COPD specific therapies, and 4) establishing patient prognosis.

Case finding using office-based spirometry to detect impaired lung function has been proposed in selected “at-risk” individuals in primary care settings. In particular, the 2003 Executive Summary of GOLD recommends that “a diagnosis of COPD should be considered in any patient who has cough, sputum production, or dyspnea, and/or a history of exposure to risk factors for the disease. The diagnosis is confirmed by an objective measure of airflow limitation, preferably spirometry.” These individuals include anyone with a current or past history of smoking as well as nonsmoking adults with persistent respiratory symptoms. ^8^ Therapy is outlined at each stage of COPD. This includes inhaled therapies and rehabilitation for individuals with postbronchodilator spirometry demonstrating at least moderate airflow obstruction (FEV_1_ <80 percent predicted) with or without respiratory symptoms.

Case finding with spirometry has the potential to provide early identification of airflow obstruction in asymptomatic individuals or those with nonspecific symptoms of cough and sputum production prior to the development of dyspnea that limits daily activities. If interventions are effective in these individuals, identification and treatment could prevent development of considerable morbidity and mortality. Routine spirometric testing may prompt health care providers to more aggressively and successfully implement appropriate early interventions, including smoking cessation, avoidance of environmental hazards exercise, enhanced compliance with influenza and pneumococcal vaccination programs, development of positive coping skills, and/or more appropriate utilization of pharmacologic therapies. Providing patients with knowledge of their lung function may improve healthy lifestyle and medication compliance. Assessing lung function among symptomatic individuals to determine if airflow obstruction is present (and quantifying its severity) could lead to improved diagnostic accuracy of COPD compared to clinical examination and more appropriate utilization of disease-specific interventions.

A recent systematic review and quantitative meta-analysis evaluated randomized clinical trials and assessed the impact of long-acting bronchodilators, inhaled corticosteroids, noninvasive mechanical ventilation, pulmonary rehabilitation, domiciliary oxygen therapy, lung volume reduction surgery, and disease management programs. ^9^ The authors concluded that “a significant body of evidence supports the use of long-acting bronchodilators and inhaled corticosteroids in reducing exacerbations in patients with moderate to severe COPD. Domiciliary oxygen therapy is the only intervention that has been demonstrated to prolong survival, but only in patients with resting hypoxia.” Inhaled long-acting anticholingergics, and corticosteroids alone or in combination with a long-acting β2 agonist resulted in an improvement in health related quality of life and functional status as assessed by two standardized and validated COPD instruments. However, the weighted mean units of change compared to placebo were less than previously demonstrated to be clinically significant. ^10^

The National Lung Health Education Program (NLHEP) has as its theme: “Test Your Lungs—Know Your Numbers.” Their mission is to create awareness about COPD as a major health problem. NLHEP promotes the use of spirometry for diagnosis and monitoring of disease, including responses to therapy. NLHEP advises spirometric testing in all current and former smokers 45 years of age or older and in anyone of any age with chronic cough or wheeze, dyspnea on exertion, or mucus hypersection (i.e., production cough and phlegm). ^11^ To enhance implementation of these recommendations, NLHEP has developed educational materials and seminars and enlisted a cadre of “physician champions for COPD and respiratory health.”