# Appendix D Evidence Tables and Figures

## Evidence Figures

Evidence Figure 1. Inhaled therapies for the management of COPD, Long-acting B2-Agonists vs Placebo

Evidence Figure 2. Interventions for COPD using Spirometry, Long-acting B2-Agonists vs Placebo

Evidence Figure 3 . Inhaled Therapies for the Management of COPD, Tiotropium vs. Placebo or Ipratropium

Evidence Figure 4. Interventions for COPD using Spirometry, Ipratrotium vs. Placebo or Tiotropium

Evidence Figure 5. Interventions for COPD using Spirometry, Inhaled Corticosteroids vs. Placebo

Evidence Figure 6. Interventions for COPD using Spirometry, Combination of Long-Acting B2-Agonists and Corticosteroids vs. Placebo: Excaberations

Evidence Figure 7. Interventions for COPD using Spirometry, Combination of Long-Acting B2-Agonists and Corticosteroids vs. Placebo: Mortality

Evidence Figure 8. Interventions for COPD using Spirometry, Combination of Long-Acting B2-Agonists and Corticosteroids vs.Long-Acting B2-Agonists: Excaberations

Evidence Figure 9. Interventions for COPD using Spirometry, Combination of Long-Acting B2-Agonists and Corticosteroids vs.Long-Acting B2-Agonists: Mortality

Evidence Figure 10. Interventions for COPD using Spirometry, Combination of Long-Acting B2-Agonists and Corticosteroids vs.Corticosteroids: Excaberations

Evidence Figure 11. Interventions for COPD using Spirometry, Combination of Long-Acting B2-Agonists and Corticosteroids vs.Corticosteroids: Mortality

Evidence Figure 12. Combination Long-Acting B2-Agonists and Corticosteroid Analyses

Evidence Figure 13. Interventions for COPD using Spirometry, Sibanet vs. Placebo: Exacerbations

Evidence Figure 14. Interventions for COPD using Spirometry, Sibanet vs. Placebo: Mortality

Evidence Figure 15. LH-1 Relative Risks, Ipratropium vs. Placebo: Cough and sputum at year 3: Subjects with no symptoms at baseline

Evidence Figure 16. LH-1 Relative Risks, Ipratropium vs. Placebo: Cough and sputum at year 3: Subjects with any symptom at baseline

Evidence Figure 17. LH-1 Relative Risks, Ipratropium vs. Placebo: Dyspnea at year 3: Subjects with no symptoms at baseline

Evidence Figure 18. LH-1 Relative Risks, Ipratropium vs. Placebo: Dyspnea at year 3: Subjects with any symptom at baseline

## Evidence Tables

Evidence Table 1. Prevalence of COPD based upon American Thoracic Society (ATS) or Global Initiative for Chronic Obstructive Lung Disease (GOLD) spirometric categories for gender

Variable / Country; Study | % Normal Spirometry and No Respiratory Symptoms (n / N) | % GOLD 0 or “At Risk” / Normal Spirometry + Symptoms of Cough, Sputum (n / N) | % GOLD 1 or Mild - FEV_1_/FVC <70 and FEV_1_ >80% Predicted) (n / N) | % ATS 1 or GOLD 2 or “Moderate” / FEV_1_/FVC <70 and FEV_1_ >50 to 80–85% Predicted) (n / N) | % ATS 2 or 3 or GOLD > 3 or “Severe” / FEV_1_/FVC <70 and FEV_1_ <50% predicted) (n / N) | Notes
National Health and Nutrition Examination Survey-NHANES III ^ 150 ^
Male | Not reported | Not reported | 9.1 | 7.4 | Not reported | Estimated prevalence
Female | Not reported | Not reported | 4.9 | 5.8 | Not reported
National Health and Nutrition Examination Survey-NHANES I ^ 156 ^
Male | 61.9 (1,552 / 2,508) | 16.1 (see notes) | 9.8 (246 / 2,508) | 10 (251 / 2,508) | 2.2 (55 / 2,508) | Subjects had “any respiratory symptom,” defined as cough, sputum, or wheeze)
Female | 71.9 (2,182 / 3034) | 16.1 (see notes) | 6.2 (188 / 3,034) | 4.6 (140 / 3,034) | 1.2 (36 / 3,034) | Subjects had “any respiratory symptom,” defined as cough, sputum, or wheeze)
European Community Respiratory Health Survey ^ 157 ^
Male | 82.6 (6,145 / 7,441) | 12.6 (940 / 7,441) | 4.8 (356 / 7,441) | see note | see note | Stages GOLD1-IV were combined.
Female | 86.6 (6,422 / 7,414) | 10.9 (811 / 7,414) | 2.4 (181 / 7,414) | see note | see note | Stages GOLD1-IV were combined.
Copenhagen City Heart Study ^ 149 ^
Male | 74.7 (4,490 / 6,012) | 7.1 (429 / 6,012) | 6.7 (404 / 6,012) | 11 (663 / 6,012) | <1 (26 / 6,012)
Female | 83.9 (5,951 / 7,096) | 4.7 (337 / 7,096) | 3.6 (259 / 7,096) | 7.6 (542 / 7,096) | <1 (7 / 7,096)
Mini-Finland Health Survey ^ 151 ^
Male | 54 (1,740 / 3,255)* | Not reported | 36 (1,163 / 3,255) | 10 (314 / 3,255) | 1 (38 / 3,255)
Female | 61 (2,275 / 3,753)* | Not reported | 34 (1,286 / 3,753) | 5 (184 / 3,753) | 0.2 (8 / 3,753)
Prevalence of COPD in Elderly Finns ^ 152 ^
Male | 82.6 (252 / 305)* | Not reported | 3.6 (11 / 305) (FEV_1_ % predicted >80) | 11.8 (36 / 305) (FEV_1_ % predicted 40–79) | 2 (6 / 305) (FEV_1_ % predicted <40)
Female | 95.6 (435 / 455)* | Not reported | <1 (3 / 455) (FEV_1_ % predicted >80) | 2.9 (13 / 455) (FEV_1_ % predicted 40–79) | <1 (4 / 455) (FEV_1_ % predicted <40)
Prevalence of COPD in Norwegians ^ 154 ^
Male: age 18–44 | 96.4* | Not reported | 1.3 | 2.3 | 0
Male: age 45–73 | 88.3* | Not reported | 2.4 | 8.6 | 0.6
Female: age 18–44 | 97.9* | Not reported | 1.2 | 0.7 | 0.1
Female: age 45–73 | 90.8* | Not reported | 0.9 | 8.1 | 0.2

* Subjects may or may not be symptomatic and include “at risk”

Evidence Table 2. Prevalence of COPD based upon American Thoracic Society (ATS) or Global Initiative for Chronic Obstructive Lung Disease (GOLD) spirometric categories for ethnicity

Variable / Country; Study | % Normal Spirometry and No Respiratory Symptoms (n / N) | % GOLD 0 or “At Risk” / Normal Spirometry + Symptoms of Cough, Sputum (n / N) | % GOLD 1 or Mild - FEV_1_/FVC <70 and FEV_1_ >80% Predicted) (n / N) | % ATS 1 or GOLD 2 or “Moderate” / FEV_1_/FVC <70 and FEV_1_ >50 to 80–85% Predicted) (n / N) | % ATS 2 or 3 or GOLD >3 or “Severe” / FEV_1_/FVC <70 and FEV_1_ <50% Predicted) (n / N) | Notes
National Health and Nutrition Examination Survey-NHANES III ^ 150 ^
White | Not reported | Not reported | 7.1 | 6.7 | NR | Estimated prevalence
Black | Not reported | Not reported | 5 | 5.6 | NR
Other | Not reported | Not reported | 8 | 5.3 | NR
National Health and Nutrition Examination Survey-NHANES I ^ 156 ^
White | 67.6 (3310 / 4896) | 16.4 (803 / 4896) (see notes) | 7.5 (367 / 4,896) | 6.9 (338 / 4,896) | 1.6 (78 / 4,896) | Subjects had “any respiratory symptom,” defined as cough, sputum, or wheeze)
Non-white | 65.3 (422 / 646) | 14 (90 / 646) (see notes) | 10.5 (68 / 646) | 8.4 (54 / 646) | 1.8 (12 / 646)

Evidence Table 3. Prevalence of COPD based upon American Thoracic Society (ATS) or Global Initiative for Chronic Obstructive Lung Disease (GOLD) spirometric categories for age, gender, and ethnicity

Variable / Country; Study | % Normal Spirometry and No Respiratory Symptoms (n / N) | % GOLD 0 or “At Risk” / Normal Spirometry + Symptoms of Cough, Sputum (n / N) | % GOLD 1 or Mild - FEV_1_/FVC <70 and FEV_1_ >80% Predicted) (n / N) | % ATS 1 or GOLD 2 or “Moderate” / FEV_1_/FVC <70 and FEV_1_ >50 to 80–85% Predicted) (n / N) | % ATS 2 or 3 or GOLD >3 or “Severe” / FEV_1_/FVC <70 and FEV_1_ <50% Predicted) (n / N)
National Health and Nutrition Examination Survey-NHANES III ^ 150 ^
Black female, age 17–24 | Not reported | Not reported | Not reported | 1.1 | 0
Black female, age 25–44 | Not reported | Not reported | Not reported | 1.3 | 0.3
Black female, age 45–64 | Not reported | Not reported | Not reported | 6.5 | 1.6
Black female, age 65–74 | Not reported | Not reported | Not reported | 8.5 | 0
Black female, age 75–84 | Not reported | Not reported | Not reported | 6.7 | 3.6
Black female, age >85 | Not reported | Not reported | Not reported | 6.2 | 0
Black male, age 17–24 | Not reported | Not reported | Not reported | 2.7 | 0
Black male, age 25–44 | Not reported | Not reported | Not reported | 1.9 | 0
Black male, age 45–64 | Not reported | Not reported | Not reported | 10.8 | 2
Black male, age 65–74 | Not reported | Not reported | Not reported | 18.9 | 5.1
Black male, age 75–84 | Not reported | Not reported | Not reported | 30.1 | 5.1
Black male, age >85 | Not reported | Not reported | Not reported | 6.7 | 0
White female, age 17–24 | Not reported | Not reported | Not reported | 1 | 0
White female, age 25–44 | Not reported | Not reported | Not reported | 2.2 | 0.5
White female, age 45–64 | Not reported | Not reported | Not reported | 7.4 | 3.6
White female, age 65–74 | Not reported | Not reported | Not reported | 12.4 | 4
White female, age 75–84 | Not reported | Not reported | Not reported | 13.5 | 3.1
White female, age >85 | Not reported | Not reported | Not reported | 6.9 | 3.1
White male, age 17–24 | Not reported | Not reported | Not reported | 1.1 | 0
White male, age 25–44 | Not reported | Not reported | Not reported | 2.5 | 0.2
White male, age 45–64 | Not reported | Not reported | Not reported | 9.4 | 2.2
White male, age 65–74 | Not reported | Not reported | Not reported | 17.3 | 6.7
White male, age 75–84 | Not reported | Not reported | Not reported | 19.8 | 4.8
White male, age >85 | Not reported | Not reported | Not reported | 17.5 | 1

Evidence Table 4. Prevalence of spirometric categories: American Thoracic Society (ATS) or Global Initiative for Chronic Obstructive Lung Disease (GOLD) category criteria for smoking status

Variable / Country; Study | % Normal Spirometry and No Respiratory Symptoms (n / N) | % GOLD 0 or “At Risk” / Normal Spirometry + Symptoms of Cough, Sputum (n / N) | % GOLD 1 or Mild - FEV_1_/FVC <70 and FEV_1_ >80% Predicted) (n / N) | % ATS 1 or GOLD 2 or “Moderate” / FEV_1_/FVC <70 and FEV_1_ >50 to 80–85% Predicted) (n / N) | % ATS 2 or 3 or GOLD >3 or “Severe” / FEV_1_/FVC <70 and FEV_1_ <50% Predicted) (n / N) | Study, Population and Notes
National Health and Nutrition Examination Survey-NHANES I ^ 150 ^
Current smoker | 56.9 (1,321 / 2,323) | 21.3 (494 / 2,323) (see notes) | 9.2 (213 / 2,323) | 10.6 (247 / 2,323) | 2.1 (48 / 2,323) | Subjects had “any respiratory symptom,” defined as cough, sputum, or wheeze)
Previous smoker | 66.1 (734 / 1,110) | 15.8 (175 / 1,110) (see notes) | 8.6 (96 / 1,110) | 7.3 (81 / 1,110) | 2.2 (24 / 1,110)
Never smoker | 79.3 (1,672 / 2,109) | 10.6 (223 / 2,109) (see notes) | 6.2 (130 / 2,109) | 3 (64 / 2,109) | <1 (20 / 2,109)
European Community Respiratory Health Survey ^ 157 ^
Current smoker | 75.8 (4,135 / 5,455) | 19.1 (1,044 / 5,455) | 5.1 (276 / 5,455) | see note | see note | Stages GOLD1-IV were combined
Previous smoker | 89 (2,727 / 3,065) | 7.6 (233 / 3,065) | 3.4 (105 / 3,065) | see note | see note
Never smoker | 92 (5,705 / 6,203) | 7.6 (469 / 6,203) | <1 (29 / 6,203) | see note | see note
Copenhagen City Heart Study ^ 149 ^
Current smoker | 75.6 (6,265 / 8,255) | 7.2 (597 / 8,255) | 5.5 (457 / 8,255) | 11.1 (916 / 8,255) | <1 (20 / 8,255)
Previous smoker | 83.4 (1,879 / 2,253) | 4.4 (100/ 2,253) | 4.7 (107 / 2,253) | 6.9 (156 / 2,253) | <1 (11 / 2,253)
Never smoker | 88.3 (2,297 / 2,600) | 2.7 (69 / 2,600) | 3.8 (99 / 2,600) | 5.1 (133 / 2,600) | <1 (2 / 2,600)

Evidence Table 5. Losses to followup

Study | Group | Length of Followup (months) | N (# randomized) | Loss to Followup (n) | Loss to Followup (%)
Segnan et al., 1991 ^79^ | All participants | 12 | 923 | 120 | 13%
Risser et al., 1990 ^80^ | Control | 12 | 45 | 3 | 7%
| Intervention | 12 | 45 | 9 | 20%
Sippel et al., 1999 ^81^ | Control | 9 | 102 | 19 | 18.6%
| Intervention | 9 | 103 | 13 | 12.6%
Richmond et al., 1985 ^82^ | Control | 36 | 100 | 23 | 23%
| Intervention | 36 | 100 | 15 | 15%
Rose et al., 1978 ^84^ | Control | 36 | 731 | 220 | 30%
| Intervention | 36 | 714 | 258 | 36%
Humerfelt et al., 1998 ^83^ | Control | 12 | 1,310 | 109 | 8%
| Intervention | 12 | 1,300 | 219 | 17%
Li et al., 1984* ^85^ | All participants | 11 | 579 | 129 | 22%
| Total | | 6,052 | 1,137 | 19%

* In study by Li et al, the results of three participants were not included in the final results as it was uncertain which treatment had been received.

Evidence Table 6. Characteristics of studies of long-acting β2 agonists for COPD using spirometry

Study (Reference) | Study Duration | Intervention(s), Dose Per Day; Control(s) | Baseline FEV_1_ (L); % Predicted of Normal | Description of Subjects/Inclusion Criteria
Calverly et al, 2003 ^88^ | 1 year | 1) Formoterol 4.5 ug b.i.d. (n=171) | 1) 1.00, 36% | Worldwide 15 countries, 75% men and 25% women); mean age 64 (range 41–86); pack years = 39; Medication at enrollment: oral/inhaled steriods = 48%, short acting β agonists = 50%, long acting β agonists = 29%, xanthines 36%.
| | 2) Budesonide 200 ug, b.i.d. (n=257) | 2) 0.99, 36% | 1) both genders at least 40 years old, with diagnosis of COPD (GOLD stage 3 and 4 with symptoms for more than 2 years)
| | 3) Formoterol 4.5ug + Budesonide 160 ug, b.i.d. (n=254) | 3) .98, 36% | 2) current or ex-smokers with smoking history of ≥10 pack-years
| | 4) Placebo (n-256) | 4) 0.98, 36% | 3) FEV_1_/FVC ratio ≤70%
| | | | 4) FEV_1_ 50% of the predicted normal
| | | | 5) ≥1 COPD exacerbation requiring a course of oral corticosteriods and/or antibiotics 2–12 months before first clinic visit.
Brusasco et al., 2003 ^89^ | 6 months | 1) Tiotropium 18 ug q.d. (n=402) | 1) 1.12 (0.39), 39% | European, Canadian (18 countries) men and women (24%); mean age 64; pack years = 44.
| | 2) Salmeterol 50 ug, b.i.d. (n=405) | 2) 1.07 (0.38), 38% | 1) relatively stable airway obstruction with FEV_1_ ≤65% of predicted normal and ≤70% of FVC
| | 3) placebo (n=400) | 3) 1.09 (0.40), 39% | 2) over 40 years of age
| | | | 3) with smoking history of >10 pack years.
Calverley et al., 2003 ^87^ | 1 year | 1) Salmeterol 50 ug, b.i.d. (n=372) | 1) 1.25 (0.45), 44% | European et al. (25 countries) men and women (28%); mean age 63; Current smokers = 51%, pack years = 43.
| | 2) Fluticasone 50ug, b.i.d.(n=374) | 2) 1.26 (0.45), 45% | 1) baseline FEV_1_ before bronchodilation that was 25–70% of that predicted, an increase of less than 10% of predicted FEV_1_ 30 minutes after inhaling 400 ug salbutamol, and a prebronchodilator FEV_1_/FVC ratio of 70% or less
| | 3) Salmeterol 50 ug + Fluticasone 500 ug, b.i.d. (n=358) | 3) 1.31 (0.53), 45% | 2) at least 10 pack-years of smoking
| | 4) placebo (n=361) | 4) 1.27 (0.47), 44% | 3) of chronic bronchitis, at least one episode of acute COPD symptom exacerbation per year in the previous 3 years
| | | | 4) at least one exacerbation in the year immediately before trial entry that required treatment with oral corticosteroids, antibiotics, or both.
Celli et al., 2003 ^90^ | 3 months | 1) Sibenadet 500 ug, t.i.d. (n=543) | 1) 1.32 (0.48), 42% | Worldwide 15 countries (75% men and 25% women); Caucasian (96%), Black (1%), Oriental (2%), Others (1%); mean age 64 (range 35–80); pack years = 46; Medication at enrollment: oral/inhaled steroids = 54%, short acting β agonists = 55%, long acting β-agonists = 25%, xanthines 22%.
| | 2) Salmeterol 50 ug, b.i.d. (n=554) | 2) 1.30 (0.46), 42% | 1) both genders ranging in age from 40 to 80 years, with diagnosis of COPD (with symptoms for more than 2 years)
| | 3) placebo (n=271) | 3) 1.35 (0.50), 44% | 2) current or ex-smokers with smoking history of ≥15 pack-years
| | | | 3) FEV_1_/FVC ratio ≤65%
| | | | 4) FEV_1_ 20–70% of the predicted normal
| | | | 5) FEV_1_ reversibility to 400 ug salbutamol of ≤15% or <200 ml / Mean daily BCSS (Breathlessness, cough, and sputum scale) (1) 5.28, (2) 5.30.
Hanania et al., 2003 ^91^ | 6 months | 1) Salmeterol 50 ug, b.i.d. (n=177) | 1) 1.25 (0.43), 42% | American men and women (37%), White (93%), Black (4%), Asian/other (3%); mean age 64 (range 40–87); Current smokers = 47%, (median) pack years = 57; Concurrent theophylline use = 11%; Emphysema 67%.
| | 2) Fluticasone 250 ug, b.i.d. (n=183) | 2) 1.31 (0.44), 42% | 1) ≥40 years of age
| | 3) Salmeterol 50 ug + Fluticasone 250 ug b.i.d. (n=178) | 3) 1.25 (0.40), 41% | 2) current or former smokers with ≥20 pack-year history
| | 4) placebo (n=185) | 4) 1.29 (0.43), 42% | 3) diagnosis of COPD by ATS
| | | | 4) baseline FEV_1_/FVC ratio of ≤70% and baseline FEV_1_ of <65% of predicted normal, but >0.70 L (or if ≤0.70 L, then >40% of predicted normal)
| | | | 5) symptoms of chronic bronchitis and moderate dyspnea
Szafranski et al., 2003 ^92^ | 1 year | 1) Formoterol 4.5 ug b.i.d.(n=201) | 1) 1.00; 36% | Multinational (11 countries) men and women (21%); mean age 64 (range 40–92); Current smokers = 34%, pack years = 45; Previous use inhaled corticosteroids = 13%, short acting β agonists = 34%, long acting β agonists = 9%, xanthines 13%, combined inhaled β agonists/anticholinergic 11%.
| | 2) Budesonide 200 ug, b.i.d. (n=198) | 2) 1.01; 37% | 1) adults with moderate-to-severe COPD (in line with GOLD guidelines for diagnosis, management and prevention of COPD)
| | 3) Formoterol 4.5 ug + Budesonide 160 ug, b.i.d. (n=208) | 3) 0.96; 36% | 2) outpatients aged ≥40 yrs
| | 4) placebo (n=205) | 4) 0.98; 36% | 3) COPD symptoms for ≥2 years
| | | | 4) ≥10 pack-years smoking history
| | | | 5) FEV_1_/FVC ≤70%
| | | | 6) FEV_1_ ≤50% predicted normal (stages IIB and III according to the GOLD classification)
| | | | 7) total symptom score (including shortness of breath, cough, chest tightness, and night-time awakenings; each symptom scored 0–4) ≥2 per day during at least 7 days of the run-in period
| | | | 8) documented use of short-acting inhaled bronchodilators for reliever medication; 9) ≥1 severe COPD exacerbation within 2–12 months before the first clinic visit.
Aalbers et al., 2002 ^93^ | 3 months | 1) Formoterol 4.5 ug, b.i.d. (n=171) | 1) 1.44, 53% | European (9 countries) men and women (32%); mean age 62 (range 49–79); Current smoker = 47%.
| | 2) Formoterol 9 ug, b.i.d. (n=166) | 2) 1.49, 54% | 1) male and female aged 50–80 years, with clinical diagnosis of COPD
| | 3) Formoterol 18 ug, b.i.d. (n=177) | 3) 1.51, 55% | 2) current or former smokers with smoking history of at least 10 pack-years
| | 4) placebo (n=173) | 4) 1.47, 54% | 3) prebronchodilator FEV_1_ > 0.7 L and 40–70% of predicted
| | | | 4) FEV_1_/FVC ratio <89% pred normal for females and <88% for males
| | | | 5) total symptom score (night-time sleep disturbance, breathlessness, cough, and chest tightness; each symptom scored 0–4) had to be ≥2 on at least 7 days of run-in period / total symptom score 5.63 (sleep disturbance 1.74; breathlessness 2.56; cough 2.27; chest tightness 1.91).
Chapman et al., 2002 ^94^ | 6 months | 1) Salmeterol 50 ug, b.i.d. (n=201) | 1) 1.19, 44% | European and Canadian (6 countries) men and women (36%); Current smokers = 43%; Previous use corticosteroids = 61%, theophylline = 21%.
| | 2) placebo (n=207) | 2) 1.28, 46% | 1) men and women with COPD aged 40 years or older who were willing to give written, informed consent
| | | | 2) taking anticholinergic agents (alone or as a combination product) for at least 4 weeks
| | | | 3) history of smoking equivalent to at least 10 pack-years
| | | | 4) sputum production on most days during at least three consecutive months for two consecutive years
| | | | 5) baseline (visits 1, 2, or 3) FEV_1_ 85% or less of predicted
| | | | 6) baseline FEV_1_/FVC 70% or less of predicted
| | | | 7) FEV_1_ reversibility 5% to 15% of predicted, either by measurement 15 minutes after inhalation of salbutamol at baseline or documented evidence of such reversibility after inhalation of a β2 agonist within previous 12 months
| | | | 8) symptoms (daytime symptom scores 0–5; night-time symptom scores 0–4) on at least seven out of previous 14 day and night periods of run-in phase.
Donohue et al., 2002 ^95^ | 6 months | 1) Salmeterol 50 ug, b.i.d. (n=213) | 1) 1.07 (0.37) | European, American, and South African (12 countries) men and women (25%); mean age 65; pack years = 47; Previous use β agonists = 66%, theophylline = 21%, anticholinergics = 53%, steroids = 72%.
| | 2) Tiotropium 18 ug q.d. (n=209) | 2) 1.11 (0.39) | 1) relatively stable airway obstruction with FEV_1_ ≤60% of predicted normal and FEV_1_ ≤70% of FVC
| | 3) placebo (n=201) | 3) 1.06 (0.36) | 2) at least 40 years of age
| | | | 3) with smoking history of >10 pack-years.
Mahler et al., 2002 ^96^ | 6 months | 1) Salmeterol 50 ug, b.i.d. (n=160) | 1) 1.24, 40% | American men and women (34%), White (93%), Black (5%), Asian/other (2%); mean age 63 (range 40–90); Current smokers = 48%, (median) pack years = 56; Inhaled steroids use = 25%; Emphysema 76%.
| | 2) Fluticasone 500 ug, b.i.d. (n=168) | 2) 1.23, 41% | 1) 40 years of age or older
| | 3) Salmeterol 50 ug + Fluticasone 500 ug b.i.d. (n=165) | 3) 1.27, 41% | 2) current or former smokers with 20 pack-year or more history
| | 4) placebo (n=181) | 4) 1.32, 41% | 3) diagnosis of COPD
| | | | 4) baseline FEV_1_/FVC of 70% or less and baseline FEV_1_ of less than 65% of predicted but more than 0.70 L
| | | | 5) daily cough productive of sputum for 3 months of the year for 2 consecutive years and dyspnea.
Rossi et al., 2002 ^97^ | 1 year | 1) Formoterol 12 ug, b.i.d.(n=211) | 1) 1.36, 47% | European (13 countries) men and women (17%); mean age 63 (range 34–88).
| | 2) Formoterol 24 ug, b.i.d. (n=214) | 2) 1.39, 47% | 1) male or female outpatients aged ≥40 years, with diagnosis of COPD, who were either current or ex-smokers of >10 pack-years according to ATS guidelines
| | 3) Oral slow-release theophylline 200/300 mg, b.i.d. (n=209) | 3) 1.33, 46% | 2) FEV_1_ <70% of the predicted value and ≥0.75 L, with an FEV_1_/vital capacity ratio of <88% of that predicted in men and <89% of that predicted in women
| | 4) placebo (n=220) | 4) 1.40, 49% | 3) daytime and/or night-time symptoms (ability to perform usual daily activities, breathlessness over the previous 24 hours, waking at night due to respiratory symptoms, breathlessness on rising, cough, and sputum production; each symptom scored 0–3) were to be present on at least 4 of last 7 days of run-in period.
Wadbo et al., 2002 ^98^ | 3 months | 1) Formoterol 18 ug b.i.d. (n=61) | 1) 33% | Swedish men and women (47%); mean age 64 (range 47–74); Current smokers = 28%.
| | 2) Ipratropium bromide 80 ug, t.i.d. (n=62) | 2) 34% | 1) male and female outpatients, aged 40–75 years, current or former smokers with history of >10 pack-years and with a diagnosis of COPD by the European Respiratory Society
| | 3) placebo (n=60) | 3) 33% | 2) history of reduced exercise capacity due to dyspnea on exertion
| | | | 3) FEV_1_ <60% of predicted normal value and a quotient FEV_1_/FVC <70%
| | | | 4) the reversibility had to be <12% of predicted normal value, 45 minutes after inhalation of 120 ug ipratropium bromide via pressurized metered dose inhaler or 27 ug formoterol via Turbuhaler given on two separate occasions 1–3 days apart;
| | | | 5) oxygen tension in arterial blood (Pa, O2) at rest the second enrolment needed to be >7.3 kPa.
Dahl et al., 2001 ^99^ | 3 months | 1) Formoterol 12 ug b.i.d. (n=194) | 1) 1.33 (0.45), 46% | European and North American (11 countries) men and women (25%); mean age 64; Current smokers = 47%, (mean) pack years = 43.
| | 2) Formoterol 24 ug b.i.d. (n=192) | 2) 1.31 (0.43), 45% | 1) male or female outpatients aged ≥40 years, with diagnosis of COPD according to ATS guidelines, who were either current or ex-smokers of >10 pack-years and gave written informed consent
| | 3) Ipratropium bromide 40 ug, t.i.d. (n=194) | 3) 1.29 (0.46), 45% | 2) FEV_1_ <70% of predicted and >0.75 L, with the ratio FEV_1_/vital capacity of <88% of that predicted in men and <89% of that predicted in women
| | 4) placebo (n=200) | 4) 1.29 (0.41), 44% | 3) daytime and/or nighttime symptoms (ability to perform usual daily activities, breathlessness over the previous 24 hours, waking at night due to respiratory symptoms, breathlessness on rising, cough, and sputum production; each symptom scored 0–3) were to be present on at least 4 of last 7 days of run-in period.
Rennard et al., 2001 ^100^ | 3 months | 1) Salmeterol 42 ug, b.i.d. (n=132) | 1) 1.22 | American men and women (37%), White (94%), Black (5%), Hispanic (1%); mean age 63.
| | 2) Ipratropium 36 ug, t.i.d. (n=138) | 2) 1.28 | 1) at least 35 years of age
| | 3) placebo (n=135) | 3) 1.30 | 2) FEV_1_ ≤65% of predicted and >0.70 L, with an FEV_1_/FVC ratio of ≤70% at initial screening (or FEV_1_ ≥40% of predicted and <0.70 L)
| | | | 3) responsiveness to both inhaled albuterol and ipratropium assessed at entry
| | | | 4) score at least 1 on the Modified Medical Research Council five-point dyspnea scale (0–4).
van Noord et al., 2000 ^101^ | 3 months | 1) Salmeterol 50 ug, b.i.d. (n=47) | 1) 1.20 (0.40), 42% | Dutch men and women (13%); mean age 64; Current smokers = 55%; Previous use β agonists = 100%, methylxanthines = 13%, anticholinergics = 43%, corticosteroids = 85%, mucolytics = 32%.
| | 2) Salmeterol 50 ug (b.i.d.) + Ipratropium bromide 40 ug (q.i.d.) (n=47) | 2) 1.20 (0.40) | 1) current or exsmokers with a smoking history equivalent to 10 pack-years with COPD according to ATS criteria
| | 3) placebo (n=50) | 3) 1.20 (0.40), 41% | 2) aged 40–75 years
| | | | 3) no change in medication for COPD in the preceding 6 weeks and no major changes in smoking habits during the last 6 months
| | | | 4) FEV_1_ 75% of predicted value after inhalation of 200 ug salbutamol via metered dose inhaler (MDI).
Mahler et al., 1999 ^102^ | 3 months | 1) Salmeterol 42 ug, b.i.d. (n=135) | 1) 42% | American men and women (26%), White (91%), Black (7%), Hispanic (1%), Asian/Other (1%); mean age 63; Smoking (63 pack-years); Chronic bronchitis 24%, emphysema 47%, both 29%.
| | 2) Ipratropium 36 ug, q.i.d. (n=133) | 2) 37% | 1) ≥35 years of age
| | 3) placebo (n=143) | 3) 41% | 2) ≥10 pack-year history of smoking
| | | | 3) a diagnosis of COPD as defined by ATS
| | | | 4) a baseline FEV_1_ ≤65% of the predicted normal value and >0.70 L (or, if <0.70 L, ≥40% of predicted normal value)
| | | | 5) an FEV_1_/FVC ratio of ≤70%; 6) a baseline severity of breathlessness of grade 1 or higher on the modified Medical Research Council dyspnea scale.
Jones and Bosh, 1997 ^46^ | 4 months | 1) Salmeterol 50 ug, b.i.d. (n=94) | 1) 1.40 (0.50), 47% | Worldwide (17 countries) men and women (14%); mean age 63; Previous use inhaled/oral steroids = 86%, methylxanthines 45%.
| | 2) Salmeterol 100 ug, b.i.d. (n=94) | 2) 1.40 (0.50), 45% | 1) ranging in age from 40 to 70 years
| | 3) placebo (n=95) | 3) 1.30 (0.50), 45% | 2) a baseline FEV_1_ of less than 70% predicted normal (values greater than 0.6L) after withholding bronchodilator therapy for at least the previous 4 hours
| | | | 3) FEV_1_/FVC ratio less than 60%
| | | | 4) less than 15% reversibility of FEV_1_ following salbutamol 400 ug by metered-dose inhaler or salbutamol 800 ug by breath-actuated device
| | | | 5) daytime symptom scores of 2 or more, for at least 4 days of the last week of run-in period using symptom scoring scheme (0–5).
Boyd et al., 1997 ^103^ | 4 months | 1) Salmeterol 50 ug, b.i.d. (n=229) | 1) 1.31 (0.51) | European (18 countries) men and women (21%); mean age 62 (range 39–75); Current smokers = 43%; Previous use inhaled/oral corticosteroids = 64%, methylxanthines = 41%, anticholinergics = 19%, β agonists = 4%.
| | 2) Salmeterol 100 ug, b.i.d. (n=218) | 2) 1.23 (0.47) | 1) current or previous smokers aged 40–75 years, who had coughed up sputum on most days during at least three consecutive months in two consecutive years
| | 3) placebo (n=227) | 3) 1.31 (0.53) | 2) at or between Visits 1, 2, and 3, a measurement of FEV_1_ of ≤70% of predicted normal and a FEV_1_/FVC ratio of ≤60%
| | | | 3) at Visits 1, 2, and 3 (or documented in the previous 12 months), an increase in FEV1 of 5–15%, 15 minutes after inhalation of 400 or 800 ug of salbutamol from a metered-dose inhaler or Diskhaler™ inhaler, or 5 mg salbutamol nebulized for 3 minutes at 8 L min-1 from a nebulizer
| | | | 4) daytime symptom score (scored 0–5; modified Medical Research Council dyspnea scale) of ≥2 on at least 4 of the 7 days prior to randomization.
Pooled summary | Range | Total No. = 13,013 | Range
| 3 months – 1 year | | 0.96 – 1.51; 33% – 55%

Evidence Table 7. Characteristics of studies of tiotropium for COPD using spirometry

Study | Study Duration | Intervention(s), Dose Per Day; Control(s) | Baseline FEV_1_ (L); % Predicted of Normal | Description of Subjects / Inclusion criteria
Brusasco et al., 2003 ^89^ | 6 months | 1) Tiotropium 18 ug q.d. (n=402) | 1) 1.12 (0.39), 39% | European, Canadian (18 countries) men and women (24%); mean age 64; pack years = 44.
| | 2) Salmeterol 50 ug b.i.d. (n=405) | 2) 1.07 (0.38) | 1) relatively stable airway obstruction with FEV_1_ ≤ 65% of predicted normal and ≤ 70% of FVC
| | 3) placebo (n=400) | 3) 1.09 (0.40), 39% | 2) over 40 years of age
| | | | 3) with smoking history of >10 pack years.
Casaburi et al., 2002 ^104^ | 1 year | 1) Tiotropium 18 ug q.d. (n=550) | 1) 1.04 (0.41), 39% | American and English men and women (35%); mean age 65; pack years = 61; Previous use β agonists = 99%, theophylline = 24%, anticholinergics = 56%, steroids = 49%.
| | 2) placebo (n=371) | 2) 1.00 (0.44), 38% | 1) outpatients of either sex who were ≥40-years-old with clinical diagnosis of COPD by ATS
| | | | 2) at least 10 pack-year smoking history
| | | | 3) clinically stable airway obstruction
| | | | 4) FEV_1_ of ≤65% of predicted normal value and ≤70% of FVC.
| | | | COPD symptom scores (wheezing, shortness of breath, coughing, and chest tightness).
Donohue et al., 2002 ^95^ | 6 months | 1) Tiotropium 18 ug q.d. (n=209) | 1) 1.11 (0.39) | European, American, and South African (12 countries) men and women (25%); mean age 65; pack years = 47; Previous use β agonists = 66%, theophylline = 21%, anticholinergics = 53%, steroids = 72%.
| | 2) Salmeterol 50 ug b.i.d. (n=213) | 2) 1.07 (0.37) | 1) relatively stable airway obstruction with FEV_1_ ≤ 60% of predicted normal and FEV_1_ ≤ 70% of FVC
| | 3) placebo (n=201) | 3) 1.06 (0.36) | 2) at least 40 years of age
| | | | 3) with smoking history of >10 pack-years.
Vincken et al., 2002 ^105^ | 1 year | 1) Tiotropium 18 ug q.d. (n=356) | 1) 1.25 (0.43), 42% | Dutch/Belgian men and women (15%); mean age 64 (range 47–74); pack years = 34; Previous use inhaled/oral β agonists = 81%, theophylline = 16%, anticholinergics = 61%, inhaled/oral steroids = 90%.
| | 2) Ipratropium bromide 40 ug q.i.d. (n=179) | 2) 1.18 (0.37), 39% | 1) clinical diagnosis of COPD
| | | | 2) FEV_1_ of ≤ 65% of the predicted normal value and ≤ 70% of FVC
| | | | 3) ≥ 40 years of age
| | | | 4) smoking history of ≥10 pack-years.
| | | | respiratory symptom (cough, sputum, dyspnea, or wheeze).
van Noord et al., 2000 ^106^ | 3.3 months | 1) Tiotropium 18 ug q.d. (n=191) | 1) 1.24 (0.41), 42% | Dutch men and women (16%); mean age 64; pack years = 34; Previous use inhaled β agonists = 69%, theophylline = 14%, anticholinergics = 55%, inhaled/oral steroids = 86%.
| | 2) Ipratropium 40 ug q.i.d. (n=97) | 2) 1.19 (0.35), 40% | 1) clinical diagnosis of COPD according to the ATS criteria
| | | | 2) stable airways obstruction with FEV_1_ of < 65% predicted and a ratio of FEV_1_ to FVC of < 70%
| | | | 3) age at least 40 years
| | | | 4) current or previous smokers (≥ 10 pack-years)
Pooled summary | Range | Total No. = 3,574 | Range
| 3.3 months – 1 year | | 1.04 – 1.25; 38% – 42%

Evidence Table 8. Characteristics of studies of ipratropium for COPD using spirometry

Study | Study Duration | Intervention(s), Dose Per Day; Control(s) | Baseline FEV1 (L); % Predicted of Normal | Description of Subjects / Inclusion Criteria
Vincken et al., 2002 ^105^ | 1 year | 1) Ipratropium bromide 40 ug q.i.d. (n=179) | 1) 1.18 (0.37), 39% | Dutch/Belgian men and women (15%); mean age 64 (range 47–74); pack years = 34; Previous use inhaled/oral β agonists = 81%, theophylline = 16%, anticholinergics = 61%, inhaled/oral steroids = 90%.
| | 2) Tiotropium 18 ug q.d. (n=356) | 2) 1.25 (0.43), 42% | 1) clinical diagnosis of COPD
| | | | 2) FEV_1_ of ≤65% of the predicted normal value and ≤70% of FVC
| | | | 3) ≥40 years of age
| | | | 4) smoking history of ≥10 pack-years.
| | | | respiratory symptom (cough, sputum, dyspnea, or wheeze).
Wadbo et al., 2002 ^98^ | 3 months | 1) Ipratropium bromide 80 ug t.i.d. (n=62) | 1) 34% | Swedish men and women (47%); mean age 64 (range 47–74); Current smokers = 28%.
| | 2) Formoterol 18 ug b.i.d. (n=61) | 2) 33% | 1) male and female outpatients, aged 40–75 years, current or former smokers with history of >10 pack-years and with a diagnosis of COPD by the European Respiratory Society
| | 3) placebo (n=60) | 3) 33% | 2) history of reduced exercise capacity due to dyspnea on exertion
| | | | 3) FEV_1_ <60% of predicted normal value and a quotient FEV_1_/FVC < 70%
| | | | 4) the reversibility had to be <12% of predicted normal value, 45 minutes after inhalation of 120 ug ipratropium bromide via pressurized metered dose inhaler or 27 ug formoterol via Turbuhaler given on two separate occasions 1–3 days apart
| | | | 5) oxygen tension in arterial blood (Pa, O2) at rest the second enrolment needed to be > 7.3 kPa.
Dahl et al., 2001 ^99^ | 3 months | 1) Ipratropium bromide 40 ug t.i.d. (n=194) | 1) 1.29 (0.46), 45% | European and North American (11 countries) men and women (25%); mean age 64; Current smokers = 47%, (mean) pack years = 43.
| | 2) Formoterol 12 ug b.i.d. (n=194) | 2) 1.33 (0.45), 46% | 1) male or female outpatients aged ≥40 years, with diagnosis of COPD according to ATS guidelines, who were either current or ex-smokers of >10 pack-years and gave written informed consent
| | 3) Formoterol 24 ug b.i.d. (n=192) | 3) 1.31 (0.43), 45% | 2) FEV_1_ <70% of predicted and >0.75 L, with the ratio FEV_1_/vital capacity of < 88% of that predicted in men and <89% of that predicted in women
| | 4) placebo (n=200) | 4) 1.29 (0.41), 44% | 3) daytime and/or nighttime symptoms (ability to perform usual daily activities, breathlessness over the previous 24 hours, waking at night due to respiratory symptoms, breathlessness on rising, cough, and sputum production; each symptom scored 0–3) were to be present on at least 4 of last 7 days of run-in period.
Rennard et al., 2001 ^100^ | 3 months | 1) Ipratropium 36 ug t.i.d. (n=138) | 1) 1.28 | American men and women (37%), White (94%), Black (5%), Hispanic (1%); mean age 63.
| | 2) Salmeterol 42 ug b.i.d. (n=132) | 2) 1.22 | 1) at least 35 years of age
| | 3) placebo (n=135) | 3) 1.30 | 2) FEV_1_ ≤ 65% of predicted and >0.70 L, with an FEV_1_/FVC ratio of ≤70% at initial screening (or FEV_1_ ≥ 40% of predicted and < 0.70 L)
| | | | 3) responsiveness to both inhaled albuterol and ipratropium assessed at entry
| | | | 4) score at least 1 on the Modified Medical Research Council five-point dyspnea scale (0–4).
van Noord et al., 2000 ^106^ | 3.3 months | 1) Ipratropium 40 ug q.i.d. (n=97) | 1) 1.19 (0.35); 40% | Dutch men and women (16%); mean age 64; pack years = 34; Previous use inhaled β agonists = 69%, theophylline = 14%, anticholinergics = 55%, inhaled/oral steroids = 86%.
| | 2) Tiotropium 18 ug q.d. (n=191) | 2) 1.24 (0.41); 42% | 1) clinical diagnosis of COPD according to the ATS criteria
| | | | 2) stable airways obstruction with FEV_1_ of <65% predicted and a ratio of FEV_1_ to FVC of <70%
| | | | 3) age at least 40 years
| | | | 4) current or previous smokers (≥10 pack-years).
van Noord et al., 2000 ^101^ | 3 months | 1) Ipratropium bromide 40 ug (q.i.d.) + Salmeterol 50 ug (b.i.d.) (n=47) | 1) 1.20 (0.40); 41% | Dutch men and women (13%); mean age 64; Current smokers = 55%; Previous use β agonists = 100%, methylxanthines = 13%, anticholinergics = 43%, corticosteroids = 85%, mucolytics = 32%.
| | 2) Salmeterol 50 ug b.i.d. (n=47) | 2) 1.20 (0.40); 42% | 1) current or exsmokers with a smoking history equivalent to 10 pack-years with COPD according to ATS criteria
| | 3) placebo (n=50) | 3) 1.20 (0.40, 41% | 2) ages 40–75 years
| | | | 3) no change in medication for COPD in the preceding 6 weeks and no major changes in smoking habits during the last 6 months
| | | | 4) FEV_1_ ≤75% of predicted value after inhalation of 200 ug salbutamol via metered dose inhaler (MDI).
Mahler et al., 1999 ^102^ | 3 months | 1) Ipratropium 36 ug q.i.d. (n=133) | 1) 37% | American men and women (26%); White (91%), Black (7%), Hispanic (1%), Asian/Other (1%); mean age 63; Smoking (63 pack-years); Chronic bronchitis 24%, emphysema 47%, both 29%.
| | 2) Salmeterol 42 ug b.i.d. (n=135) | 2) 42% | 1) ≥35 years of age
| | 3) placebo (n=143) | 3) 41% | 2) ≥10 pack-year history of smoking
| | | | 3) a diagnosis of COPD as defined by ATS
| | | | 4) a baseline FEV_1_ ≤ 65% of the predicted normal value and >0.70 L (or, if <0.70 L, ≥40% of predicted normal value)
| | | | 5) an FEV_1_/FVC ratio of ≤70%
| | | | 6) a baseline severity of breathlessness of grade 1 or higher on the modified Medical Research Council dyspnea scale
COMBIVENT Inhalation Study Group, 1997 ^109^ | 3 months (85 days) | 1) Ipratropium bromide 0.5 mg q.i.d. (n=214) | 1) 0.91 | American men and women (35%); White (93%), Black (6%), Other (1%); mean age 65 (41–86).
| | 2) Albuterol sulfate 3.0 mg q.i.d. (n=216) | 2) 0.91, 34% | 1) diagnosis of COPD who were at least 40 years old
| | 3) Combination (IB 0.5 mg + Albuterol 3.0mg), q.i.d. (n=222) | 3) 0.92, 35% | 2) smoking history of at least 10 pack-years
| | | | 3) stable airway obstruction with FEV_1_ ≤65% predicted normal and ≤70% of FVC
| | | | 4) taking at least two prescribed therapeutic agents _f_or control of their COPD symptoms for at least 3 months before participation in the trial.
LUNG HEALTH STUDY Anthonisen et al., 1994 ^19^ | 5 years | 1) Ipratropium bromide t.i.d. plus smoking intervention (n=1961) | | American men and women smokers, aged 35 to 60 years (mean 48), with were thought to be at high risk for COPD (spirometric signs of early COPD, defined as FEV1/FVC ≤70% with an FEV1 between 55 to 90%.
| | 2) smoking intervention and placebo (n=1962) | | 1) Smoking defined as ≥10 cigarettes on at least 1 day during last 30 days preceding 1st screening visit
| | 3) Usual Care (no intervention) (n=1964)
COMBIVENT Inhalation Aerosol Study Group, 1994 ^108^ | 3 months (85 days) | 1) Ipratropium 21 ug t.i.d. (n=179) | 1) 1.00, 37% | American men and women (35%); White (94%), Black (5%), Other (1%); mean age 63 (40–88); Previous use inhaled β agonists = 93%, oral β agonists = 11%, theophylline = 81%, anticholinergics = 43%, inhaled/oral steroids = 41%.
| | 2) Albuterol 100 ug t.i.d. (n=173) | 2) 0.99, 37% | 1) diagnosis of COPD who were at least 40 years of age
| | 3) Combination (IB 21 ug + Albuterol 120 ug), t.i.d. (n=182) | 3) 1.00, 37% | 2) relatively stable, moderately severe airway obstruction with FEV_1_ ≤65% of predicted normal and FEV1 ≤70% of FVC
| | | | 3) smoking history of more than 10 pack-years
| | | | 4) regularly using at least two prescribed therapeutic agents for control of their COPD symptoms during the 3-month period immediately preceding consideration for entry into this trial.
Pooled summary | Range | Total No. = 9,819 | Range
| 3 months (85 days) – 1 year | | 0.91 – 1.33
| | | 33% – 46%

Evidence Table 9. Characteristics of studies of inhaled corticosteroids for COPD using spirometry

Study | Study Duration | Intervention(s), Dose Per Day; Control(s) | Baseline FEV_1_ (L); % Predicted of Normal | Description of Subjects / Inclusion criteria
Calverly et al, 2003 ^88^ | | | | See Long-Acting β2 Agonists for details
Calverley et al, 2003 ^87^ | | | | See Long-Acting β2 Agonists for details
Hanania et al, 2003 ^91^ | | | | See Long-Acting β2 Agonists for details
Szafranski et al, 2003 ^92^ | | | | See Long-Acting β2 Agonists for details
Mahler et al, 2002 ^96^ | | | | See Long-Acting β2 Agonists for details
van der Valk et al, 2002 ^86^ | 6 months | 1) Fluticasone 500 ug b.i.d. (n=123) | 1) Post 1.78 (0.53) | Dutch men and women (16%), mean age 64 years. Current smokers = 28%, pack years = 38; Mean number of exacerbations previous year = 1.3; Previous use corticosteroids = 83%, β agonists = 56%.
| | 2) placebo (n=121) | 2) Post 1.69 (0.53), 56% | 1) clinical diagnosis of stable COPD by ATS criteria
| | | | 2) no history of asthma
| | | | 3) no exacerbation in the month before enrollment
| | | | 4) current or former smoker
| | | | 5) age between 40 and 75 years
| | | | 6) baseline prebronchodilator FEV_1_ value of 25 to 80% of predicted
| | | | 7) prebronchodilator ratio FEV_1_ inspirator vital capacity (IVC) value of 60% or less
| | | | 8) reversibility of FEV_1_ postinhalation of 80 ug if ipratropium bromide via a metered dose inhalator with Aerochamber 12% of predicted value or less
| | | | 9) thin layer chromatography greater than the thin layer chromatography predicted minus 1.64 SD
| | | | 10) no maintenance treatment of oral steroids or antibiotics
| | | | 11) no medical condition with low survival or serious psychiatric morbidity (e.g., cardiac insufficiency, alcoholism)
| | | | 12) absence of any other active lung disease (e.g., sarcodosis)
| | | | 13) use of medication such as nasal corticosteroids, theophyllines, chronic use of acetylcysteine, and all other bronchodilators was allowed.
Burge et al., 2000 ^111^ | 3 years | 1) Fluticasone 500 ug b.i.d. (n=376) | 1) 1.25 (0.44), 50% | English men and women (25%); mean age 64 years; Current smokers = 38%, pack years = 44; Previous use inhaled corticosteroids = 54%.
| | 2) placebo (n=375) | 2) 1.23 (0.47), 50% | 1) current or former smokers aged 40–75 years with non-asthmatic COPD
| | | | 2) baseline FEV_1_ after bronchodilator was at least 0.8 litres but less than 85% of predicted normal, and the ratio of FEV_1_ to forced vital capacity was less than 70%
| | | | 3) previous use of inhaled and oral corticosteroids was permitted.
LHS Research Group, 2000 ^114^ | 4.5 years | 1) Triamcinolone 600 ug b.i.d. (n=559) | 1) 2.16 (0.62), 65% | North American men and women (37%), White (95%), Nonwhite (5%); mean age 56; Current smokers = 90%; Chronic bronchitis 11%, Asthma 9%, Emphysema 8%.
| | 2) placebo (n=557) | 2) 2.10 (0.64), 63% | 1) previously Lung Health Study participants
| | | | 2) 40 to 69 years of age with airflow obstruction
| | | | 3) a ratio of FEV_1_ to FVC of less than 0.70 and a value for FEV_1_ of 30 to 90% of the predicted value
| | | | 4) current smokers or quit within the previous two years.
| | | | Daily cough and phlegm ≥3 months/year 35%, Daily cough or phlegm ≥3 months/ year 58%, Dyspnea while walking up a slight hill or hurrying 28%, wheezing apart from a cold 31%.
Pauwels et al., 1999 ^115^ | 3 years | 1) Budesonide 400 ug b.i.d. (n=634) | 1) 2.53 (0.64), 77% | European (9 countries) men and women (27%); mean age 52 years; pack-years = 39; Previous use β agonists = 38%.
| | 2) placebo (n=643) | 2) 2.54 (0.64), 77% | 1) 30 to 65 years of age if currently smoking at least 5 cigarettes per day and smoked cigarettes for at least 10 years or a smoking history of at least 5 pack-years
| | | | 2) FEV_1_ after the use of bronchodilator - between 50% and 100% of the predicted normal value, and ratio of prebronchodilator FEV_1_ to slow vital capacity less than 70%
| | | | 3) increase in FEV_1_ after inhalation of 1 mg of terbutaline from a dry-power inhaler - less than 10% of the predicted normal value
| | | | 4) change in FEV_1_ between the end of the first 3-month period of the run-in phase and the end of the second - less than 15%.
Vestbo et al., 1999 ^112^ | 3 years | 1) Budesonide (800 ug, 400 ug b.i.d.) for 6 mo and (400 ug, b.i.d.) for 30 mo (n=145) | 1) Post 2.36 (0.79), 86% | Denmark men and women (40%); mean age 59 years; Current smokers = 77%.
| | 2) placebo (n=145) | 2) Post 2.39 (0.86), 87% | 1) CCHS participants
| | | | 2) age 30–70 years
| | | | 3) FEV_1_/FVC ratio 0.7 or less
| | | | 4) FEV_1_ reversibility after inhalation of 1.0 mg terbutaline from Turbuhaler of less than 15% of prebronchdilator FEV_1_
| | | | 5) FEV_1_ reversibility after 10 days of treatment with oral prednisolone 37.5 mg daily of less than 15% of prebronchdilator FEV_1_
| | | | 6) informed consent.
| | | | Chronic mucus hypersecretion 35%, wheeze with dyspnea 22%.
Weir et al., 1999 ^117^ | 2 years | 1) Beclomethasone dipropionate (750 ug for less than 50 kg) and (1000 ug for greater than 50 kg), b.i.d., (n=49) | 1) 1.07, 40% | English men and women (26%); mean age 67 years; Current smokers = 39%, pack years = 55
| | 2) placebo (n=49) | 2) 1.13, 41% | 1) clinical diagnosis with COPD
| | | | 2) adult onset airflow obstruction with FEV_1_ < 70% predicted and FEV_1_/FVC <65%.
Bourbeau et al., 1998 ^116^ | 6 months | 1) Budesonide 800 ug b.i.d, (n=39) | 1) 0.91 (0.33), 36% | Canadian men and women (22%); mean age 66 years; Current smokers = 39%, pack years = 51
| | 2) placebo (n=40) | 2) 0.95 (0.30), 37% | 1) age 40 years old or older
| | | | 2) smokers or ex-smokers
| | | | 3) no history of allergic asthma during childhood or as an adult
| | | | 4) absence of exacerbation in respiratory symptoms during the two months prior study
| | | | 5) pre-bronchodilator FEV_1_ less than 65% of predicted and FEV_1_/FVC less than 0.65
| | | | 6) post-bronchodilator FEV_1_ less than 80%
| | | | 7) regular treatment with at least one bronchodilator
| | | | 8) no inhaled corticosteroids in the previous month or oral corticosteroids in the previous two months
| | | | 9) absence of any other active lung disease
| | | | 10) absence of diabetes, active peptic ulcer disease, uncontrolled high blood pressure, or congestive heart failure
| | | | 11) absence of disease other than COPD that might interfere with quality of life (dyspnea, fatigue, emotion, and mastery).
Paggiaro et al., 1998 ^113^ | 6 months | 1) Fluticasone propionate 500 mg b.i.d. (n=142) | 1) 1.60 (0.58), 59% | European (13 countries), New Zealand, and South African men and women (23%); mean age 63 years (range 49–75); Current smokers = 49%; Previous use β agonists = 38%, methylxanthines = 34%, anticholinergics = 16%.
| | 2) placebo (n=139) | 2) 1.52 (0.62), 55% | 1) ages between 50 and 75 years with COPD by European Respiratory Society Consensus Statement
| | | | 2) if current or ex-smokers, with a history of smoking equivalent to at least 10 pack-years and chronic bronchitis
| | | | 3) history of at least one exacerbation each year for the previous 3 years that required a visit to their doctor or hospital, a high expectation, according to the investigator, of experiencing an exacerbation during the 6-month treatment period, a regular productive cough, a predicted FEV_1_ of 35–90%, a ratio of FEV_1_ to forced vital capacity of 70% or less, and reversibility in FEV_1_ of less than 15% after inhalation of 400 ug or 800 ug salbutamol via a metered-dose inhaler or Diskhaler, respectively
| | | | 4) a reversibility in FEV_1_ of more than 15% but a volume change of less than 200 mL
Pooled summary | Range | Total No. = 4,136 | Range
| 6 months – 4.5 years | | 0.91 – 2.53; 36% – 77% or 86% (post)

Evidence Table 10. Characteristics of studies of sibanet (D2-receptor/β agonist) for COPD using spirometry

Study | Study Duration | Intervention(s), Dose Per Day; Control(s) | Baseline FEV_1_ (L); % Predicted of Normal | Description of Subjects / Inclusion criteria
Celli et al., 2003 ^90^ | 3 months | 1) Sibenadet 500 ug t.i.d. (n=543) | 1) 1.32 (0.48), 42% | Worldwide 15 countries, 75% men and 25% women; Caucasian (96%), Black (1%), Oriental (2%), Others (1%); mean age 64 (range 35–80); pack years = 46; Medication at enrollment: oral/inhaled steroids = 54%, short acting β agonists = 55%, long acting β agonists = 25%, xanthines 22%.
| | 2) Salmeterol 50 ug b.i.d. (n=554) | 2) 1.30 (0.46), 42% | 1) both genders ranging in age from 40 to 80 years, with diagnosis of COPD (with symptoms for more than 2 years)
| | 3) placebo (n=271) | 3) 1.35 (0.50), 44% | 2) current or ex-smokers with smoking history of ≥15 pack-years
| | | | 3) FEV_1_/FVC ratio ≤65%
| | | | 4) FEV_1_ 20–70% of the predicted normal
| | | | 5) FEV_1_ reversibility to 400 ug salbutamol of ≤15% or <200 ml.
| | | | Mean daily BCSS (Breathlessness, cough, and sputum scale) (1) 5.28, (2) 5.30.
Hiller et al., 2003 ^118^ | 13 months | 1) Sibenadet 500 ug t.i.d. (n=290) | 1) 1.25 (0.53), 41% | American men and women (43%), mean age 64 (range 41–80). Current smoker = 41%, pack years = 60; Medication at enrollment: corticosteroids = 38%; β agonists = 26%; Combined β agonist/anticholinergic 22%.
| | 2) placebo (n=145) | 2) 1.25 (0.49), 41% | 1) male and female patients with stable, uncomplicated COPD (with symptoms for at least 2 years)
| | | | 2) ages 40–80 years with a smoking history of at least 15 pack-years
| | | | 3) FEV_1_/FVC ratio of ≤70%
| | | | 4) FEV_1_ 20–70% of the predicted normal range.
Laursen et al, 2003 ^119^ | 3 months | 1) Sibenadet 500 ug t.i.d.(n=524) | 1) 1.20 (0.36), 39% | European (3 countries) men and women (27%), mean age 65 (range 40–80); Current smoker = 46%, pack years = 51.
| | 2) placebo (n=526) | 2) 1.1 (0.46), 40% | 1) male and female patients, ages 40–80 years, with stable COPD, symptoms for ≥2 years)
| | | | 2) smoking history of at least 15 pack-years
| | | | 3) pre- and post-bronchodilator FEV_1_/FVC ≤ 65%
| | | | 4) pre- and post-bronchodilator FEV_1_ 20–70% of the predicted normal range.
| | | | Mean daily BCSS (Breathlessness, cough and sputum scale) 5.11.
Laursen et al, 2003 ^119^ | 6.5 months | 1) Sibenadet 500 ug t.i.d. (n=591) | 1) 1.40 (0.49), 41% | European (3 countries) men and women (26%), mean age 63 (range 40–79); Current smoker = 53%, pack years = 39.
| | 2) placebo (n=578) | 2) 1.20 (0.46), 40% | 1) male and female patients, ages 40–80 years, with stable COPD, symptoms for ≥2 years)
| | | | 2) smoking history of at least 15 pack-years
| | | | 3) pre- and post-bronchodilator FEV_1_/FVC ≤ 65%
| | | | 4) pre- and post-bronchodilator FEV_1_ 20–70% of the predicted normal range.
| | | | Mean daily BCSS (Breathlessness, cough and sputum scale) 5.21.
Pooled summary | Range: | Total No. = 4,022 | Range
| 3 months – 13 months | | 1.20 – 1.40; 39% – 42%

Evidence Table 11. Characteristics of studies of pulmonary rehabilitation (program) for COPD using spirometry

Study | Study Duration | Intervention(s), Dose Per Day; Control(s) | Baseline FEV_1_ (L); % Predicted of Normal | Description of Subjects / Inclusion Criteria
Ries et al., 2003 ^121^ | 2 years | Experimental maintenance intervention (n=87); control (standard care) (n=85) | 1.07 (0.43); 45% / | American men and women (46%); mean age 67 years.
| | | | More details document wasn't supplied (referred to online supplement)
Brooks et al., 2002 ^122^ | 1 year | Enhanced followup (n=50); control (conventional followup) (n=59) | 0.71 (0.04); 32% | Canadian men and women (41%); mean age 68 years.
| | | | 1) severe stable COPD (FEV_1_ <40% predicted, FEV_1_/FVC < 0.70)
| | | | 2) completion of inpatient or outpatient rehabilitation
| | | | 3) nonsmoker for a minimum of 6 months
| | | | 4) aged 49–85 years
Finnerty et al., 2001 ^123^ | 6 months | Rehabilitation (6-week outpatient-based program) (n=50); control (n=50) | 0.99 (0.36); 41% | English men and women (32%); mean age 70 years; Current smokers = 12%.
| | | | 1) long-standing airways disease, classified as COPD (known to the respiratory team at the hospital)
| | | | 2) had their therapy optimized, the role of oral or inhaled steroids and nebulized bronchodilator therapy
| | | | 3) assessed as to their ability to comply with requirements of program, specifically time and travel commitments involved
Griffiths et al., 2000 ^124^ | 1 year | Rehabilitation (6-week multidisciplinary program) (n=99); control (n=101) | 0.91 (0.38); 40% | English men and women (40%); mean age 68 years; pack years = 45.
| | | | 1) clinical diagnosis with chronic obstructive bronchitis, emphysema, or chronic poorly reversible asthma or bronchiectasis
| | | | 2) FEV_1_ measured at a time of clinical stability, less than 60% of predicted with less than 20% reversibility in response to inhaled β agonists
| | | | 3) no change in symptoms or medication for 2 months before entry
| | | | 4) additional, non-obstructive but disabling pulmonary disease, who matched the spirometric criteria
Ringbaek et al., 2000 ^125^ | 8 weeks | Rehabilitation (8 week program) (n=24); control (n=21) | 50% | Denmark men and women (84%); mean age 63 years; Current smokers = 51%; Previous use oral/inhaled steroid 89%.
| | | | 1) stable COPD with FEV_1_/FVC ratio <70%, FEV_1_ >0.6
| | | | 2) age <75 years
| | | | 3) oxygen saturation without oxygen supply >90%
Engstrom et al., 1999 ^126^ | 1 year | Rehabilitation (physiotherapy program) (n=26); control (n=24) | 31% | Swedish men and women (48%); mean age 66 years; Current smokers = 20%, pack-years = 38.
| | | | 1) diagnosis of COPD (chronic obstructive disease; developing after at least 10 pack years of smoking; debut of symptoms after 40 years of age; dyspnea mainly elicited by exercise or infections; no history of clinically significant allergy)
| | | | 2) age 45–75 years
| | | | 3) FEV_1_ of <50% pred. after bonchdilation
| | | | 4) PaO2 of >8 kPa
| | | | 5) stable clinical condition
Wedzicha et al., 1998 ^127^ | 8 weeks | Rehabilitation (exercise training and education for 8 weeks) (n=33); control (education) (n=33) | 0.95 (0.32); 37% | English men and women (49%); mean age 67 years (44–81).
(Moderate) | | | | 1) history of COPD
| | | | 2) FEV_1_ <70% predicted, with <15% reversibility to inhaled salbutamol 400 ug
| | | | 3) exercise capacity that was limited by dyspnea
| | | | 4) clinical stability for at least 3 weeks prior to recruitment, with no exacerbation over this period
| | | | 5) medical treatment was optimized prior to entry and was not changed during the rehabilitation programs
Wedzicha et al., 1998 ^127^ | 8 weeks | Rehabilitation (exercise training and education for 8 weeks) (n=30); control (education) (n=30) | 0.87 (0.41); 38% | English men and women (49%); mean age 67 years (44–81).
(Severe) | | | | 1) history of COPD
| | | | 2) FEV_1_ <70% predicted, with <15% reversibility to inhaled salbutamol 400 ug
| | | | 3) exercise capacity that was limited by dyspnea
| | | | 4) clinical stability for at least 3 weeks prior to recruitment, with no exacerbation over this period
| | | | 5) medical treatment was optimized prior to entry and was not changed during the rehabilitation programs
Pooled summary | Range 8 weeks - 2 years | Total No. = 693 | Range 0.71 – 1.07; 31% – 50%

Evidence Table 12. Characteristics of studies of disease management, education, and followup studies for COPD with/without spirometry

Study (Reference) | Study Duration | Intervention(s), Dose Per Day; Control(s) | Baseline FEV_1_ (L); % Predicted of Normal | Description of Subjects / Inclusion Criteria
Bourbean et al., 2003 ^159^ | 1 year | Self-management (n=96) | Post 1.00 (0.33) | Canadian men and women (45%); mean age 69 years; Current smokers = 26%; Previous use β agonists = 96%, methylxanthines = 29%, anticholinergics = 63%, steroids = 85%.
| | Placebo (n=95) | | 1) stable COPD (respiratory symptoms and medication unchanged for at least 4 weeks before enrollment)
| | | | 2) at least 50 years of age
| | | | 3) current or previous smoker (at least 10 pack-years)
| | | | 4) FEV_1_ after the use of bronchodilator between 25% and 70% of the predicted normal value and FEV_1_/FVC ratio less than 70%
| | | | 5) no previous diagnosis of asthma, left congestive heart failure, terminal disease, dementia, or uncontrolled psychiatric illness
| | | | 6) no participation in respiratory rehabilitation program in the past year
| | | | 7) no long-term care facility stays
| | | | Dyspnea 48%
Monninkhof et al., 2003 ^160^ | 1 year | Self-management education + fitness program (n=127) | Post 1.71 (0.56); 56% | Dutch men and women (32%); mean age 65 years; Current smokers = 22%; Previous use long acting β agonists = 37%, inhaled corticosteroids = 52%.
| | Control (n=121) | | 1) clinical diagnosis of stable COPD by STS criteria
| | | | 2) no history of asthma
| | | | 3) no exacerbation in the month prior to enrollment
| | | | 4) current or former smoker
| | | | 5) ages 40–75 years
| | | | 6) baseline prebronchodilator FEV_1_ 25–80% predicted
| | | | 7) prebronchodilator ratio FEV_1_/inspiratory vital capacity ≤60%
| | | | 8) reversibility of FEV_1_ postinhalation of 80 ug of ipratropium bromide via metered dose inhalator with aerochamber ≤12% predicted
| | | | 9) TLC greater than TLC predicted - (1.64xSD)
| | | | 10) no maintenance treatment of oral steroids or antibiotics
| | | | 11) no medical condition with low survival or serious psychiatric morbidity
| | | | 12) absence of any other active lung disease (e.g. sarcoidosis)
Hermiz et al., 2002 ^39^ | 3 months | Education/enhanced followup (home visits by nurse) (n=84) | No spirometry | Australian men and women (53%); mean age 67 years.
| | Control (standard care) (n=93) | | 1) ages 30–80 years who attended or admitted hospitals (emergency departments) with COPD (identified from their records and invited to participate in the study)
| | | | 2) provided with written consent about the study
Weinberger et al., 2002 ^161^ | 1 year | Pharmaceutical care program group (n=185) | No spirometry | American men and women (66%); mean age 62 years; White 87%; Current smokers 38%; Previous use sympathomimetics = 60%, methylxanthines = 16%, inhaled/systemic corticosteroids = 58%.
| | Peak flows meter monitoring control group (n=130) | | 1) filled a prescription for methylxanthines, inhaled corticosteroids, inhaled or oral sympathomimetics, et al. during the preceding 4 months
| | Usual care control (n=138) | | 2) reported having COPD as active problems
| | | | 3) 18 years or older
| | | | 4) received 70% or more of their medications from a single study drugstore
| | | | 5) reported no significant impairment in vision, hearing, or speech that precluded participation
| | | | 6) did not reside in an institution (e.g., nursing home)
| | | | 7) provided written informed consent
Gallefoss and Bakke, 2000 ^162^ | 1 year | Education (n=31) | 59% | Norway men and women (50%); mean age 58 years; Current smokers = 55%.
| | Control (n=31) | | 1) COPD between 18 and 70 years of age, not suffering from any other serious disease
| | | | 2) FEV_1_ ≥40% and ≥80% of predicted
| | | | 3) 32% patients were reversible to ipratropium bromide 80 ug and/or salbutamol
Watson et al., 1997 ^163^ | 6 months | Self-management (use of Action Plan & booklet) (n=29) | 37% | New Zealand men and women (46%); mean age 68 years; Current smokers = 29%.
| | Control (usual care) (n=27) | | 1) COPD as major functionally limiting disease (defined according to ATS criteria)
| | | | 2) smoking history of greater than 10 pack-years
| | | | 3) FEV_1_ less than 65% of predicted
| | | | 4) ratio of FEV_1_/FVC less than 70%
| | | | 5) current use of bronchodilator therapy
Weinberger et al., 1996 ^164^ | 6 months | Primary care intervention (n=295) | No spirometry | American men and women (2%); mean age 63 years; White (non-Hispanic) 65%, Black (non-Hispanic) 27%, Other 8%.
| | Control (n=288) | | 1) patients hospitalized in the General Medicine Service
| | | | 2) diagnosis of COPD that documented in medical record at or before time of index admission (because they are prevalent among veterans, because patients with this disease are commonly readmitted, and because hospital readmissions to treat this disease might be reduced if primary care physicians provided intervention to outpatients
Littlejohns et al., 1991 ^165^ | 1 year | Education/enhanced followup (n=73) | 45% | English men and women (35%); mean age 63 years; Current smokers = 25%.
| | Control (n=79) | | 1) ages 30–75 years
| | | | 2) no other major disease
| | | | 3) prebronchodilator FEV_1_ less than 60% predicted
| | | | 4) stable state as judged by the patient and physician with no change or perceived need for change in medication for at least six weeks before recruitment
| | | | 5) informed written consent
| | | | (Most days) cough 48%, produce sputum 38%, short of breath 67%, wheeze 25%
Cockcroft et al., 1987 ^166^ | 8 months | Enhanced followup (group visited by respiratory health worker) (n=42) | 0.78 (0.31) | English men and women (32%); mean age 70 years (46–84); Current smokers = 27%.
| | Control (n=33) | | 1) patients suffered from chronic respiratory disability caused mainly by COPD
| | | | 2) patients who had been admitted to hospital at least twice during the previous 3 years and new patients who had been seen within the past year
Pooled summary | Range 3 months – 1 year | Total No. = 1,997 | Range 0.78 - post 1.71; 37% – 59%

Evidence Table 13. Characteristics of studies of non invasive mechanical ventilation for COPD using spirometry

Study | Study Duration | Intervention(s), Dose Per Day; Control(s) | Baseline FEV_1_ (L); % Predicted of Normal | Description of Subjects / Inclusion Criteria
Jolliet et al., 2003 ^167^ | 2 years | Noninvasive pressure support ventilation (He/O_2_) (n=59) | 0.73 (0.36) | Switzerland / Belgian men and women (42%); mean age 70 years.
| | Control (Air/O_2_) (n=64) | | At least two of these criteria
| | | | 1) worsening dyspnea during the last 10 days
| | | | 2) respiratory rate of >25 breaths/minute
| | | | 3) arterial pH <7.35
| | | | 4) PaCO2 of >50 torr
| | | | 5) PaO2 of <50 torr
| | | | Dyspnea (Borg scale) points 4.7
Ambrosino et al., 2002 ^168^ | 6 months | Noninvasive positive pressure ventilation (n=63) | 30% | Italian men and women (29%); mean age 68 years.
| | Control (n=34) | | Patients known to be affected with COPD, according to ATS criteria, or with high probability of the disease based on their clinical history, physical examination, chest radiography, and, when available, previous pulmonary function test
Pooled summary | Range 6 months - 2 years | Total No. = 220 | Range 0.73; 30%

Evidence Table 14. Outcomes of studies of long-acting β2 agonists for COPD using spirometry

Study | Intervention | Exacerbations: Total Subjects with >1 Episode n/N (%) | Exacerbations - Other/ Hospitalizations Due to COPD/ or Other | Mortality: n/N (%) | St George's Respiratory Questionnaire
Brusasco et al., 2003 ^89^ | | | Use of oral steroid bursts in management of COPD; n/N % | | Change per group
| 1) Salmeterol 50 ug (n=405) | 142/405 (35) | 56/405 (13.8) | 6/405 (1.5) | 2.8 (0.7)
| 2) placebo (n=400) | 156/400 (39) | 58/400 (400) | 5/400 (1.3) | 1.5 (0.7)
Calverley et al., 2003 ^87^ | | | Mean rate per patient/year | | Treatment difference vs. combination therapy
| 1) Salmeterol 50 ug b.i.d. (n=372) | 8/372 (2.2) | 1.04 | Not reported | -1.1 (-2.2 to 0.1) (p=0.071)
| placebo (n=361) | 19/361 (5.3) | 1.3 | Not reported | -2.2 (-3.3 to -1.0) (p=0.0003)
Celli et al., 2003 ^90^ | | | “Deterioration of COPD”; n/N % | | Change per group
| 1) Salmeterol 50 ug b.i.d. (n=554) | 95/554 (17.1) | 74/553 (13.4) | 1/554 (<1) | -5.3 (0.8)
| 2) placebo (n=271) | 59/271 (21.9) | 51/268 (19) | 2/271 (<1) | -3.2 (1.1)
Hanania et al., 2003 ^91^ | 1) Salmeterol 50 ug b.i.d. (n=177) | Not reported | Not reported | 0/177 | Chronic Respiratory Disease Questionnaire; Treatment difference vs. pbo
| | | | | 2.0 (ns vs. pbo)
| 2) placebo (n=185) | Not reported | Not reported | 0/185
Szafranski et al, 2003 ^92^ | | | Mean exacerbation rates/year | | Change per group
| 1) Formoterol 4.5 ug b.i.d.(n=201) | Not reported | 1.84 | 6/201 (3) | -3.6
| 2) placebo (n=205) | Not reported | 1.87 | 9/205 (4.4) | -0.03
Aalbers et al., 2002 ^93^ | | | “Deterioration of COPD”; n/N %
| 1) Formoterol 4.5 ug b.i.d. (n=171) | Not reported | 7/171 (4.1) | Not reported | Not reported
| 2) Formoterol 9 ug b.i.d. (n=169) | Not reported | 12/169 (7.1) | Not reported | Not reported
| 3) Formoterol 18 ug b.i.d. (n=178) | Not reported | 18/178 (10.1) | Not reported | Not reported
| 4) placebo (n=173) | Not reported | 16/173 (9.2) | Not reported | Not reported
Chapman et al., 2002 ^94^ | | | | | Change per group
| 1) Salmeterol 50 ug b.i.d. (n=201) | 52/201 (26) | Not reported | Not reported | -2.4 (12.7) (p=0.3 vs. pbo)
| 2) placebo (n=207) | 68/207 (33) | Not reported | Not reported | -0.9 (12.2)
Donohue et al, 2002 ^95^ | | | | | Change per group
| 1) Salmeterol 50 ug b.i.d. (n=213) | 82/213 (38.5) | Not reported | 3/213 (1.4) | -3.54 (p=0.39 vs. pbo)
| 2) placebo (n=201) | 92/201 (45.8) | Not reported | 4/201 (2) | -2.43
Mahler et al., 2002 ^96^ | 1) Salmeterol 50 ug b.i.d. (n=160) | Not reported | Discontinuations due to exacerbations; n/N % | 0/160 | Chronic Respiratory Disease Questionnaire; Treatment difference vs. pbo
| | | 9/160 (5.6) | | 3.8 (ns vs. pbo)
| 2) placebo (n=181) | Not reported | 16/181 (8.8) | 3/181 (1.7)
Rossi et al., 2002 ^97^ | | | COPD hospitalizations (severe exacerbations) | | Change per group
| 1) Formoterol 12 ug b.i.d.(n=211) | 34/211 (16.1) | 10/211 (4.7) | 3/211 (1.4) | -5.3 (p=0.030 vs. pbo)
| 2) Formoterol 24 ug b.i.d.(n=214) | 31/214 (14.5) | 5/214 (2.3) | 1/214 (<1) | -6.1 (p=0.009 vs. pbo)
| 3) placebo (n=220) | 39/220 17.7) | 20/220 (9.1) | 0/220 | -1.9
Wadbo et al., 2002 ^98^ | | “Adverse Events related to COPD” | “Deterioration of COPD leading to withdrawal”; n/N % | | Change per group (in %)
| 1) Formoterol 18 ug b.i.d. (n=61) | 23/61 (37.7) | 3/61 (4.9) | Not reported | 0.0% (95%CI -2.2 to 2.2)
| 2) placebo (n=60) | 23/60 (38.3) | 6/60 (10.0) | Not reported | 1.5% (95%CI -0.8 to 3.7)
Dahl et al., 2001 ^99^ | | “COPD Adverse Events” - includes exacerbations | COPD hospitalizations; n/N % | | Treatment difference vs. pbo
| 1) Formoterol 12 ug b.i.d. (n=194) | 25/194 (12.9) | 2/194 (1) | 0/194 | -5.06 (p<0.001)
| 2) Formoterol 24 ug b.i.d. (n=192) | 37/192 (19.3) | 2/192 (1) | 0/192 | -3.3 (-5.8 to -0.8) (est.) (p=0.009)
| 3) placebo (n=200) | 37/200 (18.5) | 4/200 (2) | 0/200
Rennard et al., 2001 ^100^ | | | First exacerbation during week 1; n/N % | | Chronic Respiratory Disease Questionnaire; Change per group
| 1) Salmeterol 42 ug, b.i.d. (n=132) | 38/132 (28.8) | 6/132 (4.6) | 0/132 | 10.3 (p=0.078 vs. pbo)
| 2) placebo (n=135) | 41/135 (30.4) | 20/135 (14.8) | 1/135 | 6.8
van Noord et al., 2000 ^101^ | | | Discontinuations due to exacerbations; n/N %
| 1) Salmeterol 50 ug, b.i.d. (n=47) | 11/47 (23) | 3/47 (6.4) | Not reported | Not reported
| 2) placebo (n=50) | 18/50 (36) | 4/50 (8.0) | Not reported | Not reported
Mahler et al., 1999 ^102^ | | | First exacerbation during week 1; n/N % | | Chronic Respiratory Disease Questionnaire
| 1) Salmeterol 42 ug b.i.d. (n=135) | 28/135 (20.7) | 7/135 (5.2) | 0/135 | 7.1 (1.4) (p=0.007 vs. pbo)
| 2) placebo (n=143) | 47/143 (32.9) | 21/143 (14.7) | 0/143 | 2.1 (1.3)
Jones and Bosh 1997 ^46^ | | | | | Change per group
| 1) Salmeterol 50 ug b.i.d. (n=94) | Not reported | Not reported | Not reported | -6.8 (13.2) (p<0.001 vs. pbo)
| 2) Salmeterol 100 ug b.i.d. (n=94) | Not reported | Not reported | Not reported R | -2.3 (11.6)
| 3) placebo (n=95) | Not reported | Not reported | Not reported | -1.4 (11.7)
Boyd et al., 1997 ^103^ | 1) Salmeterol 50 ug b.i.d. (n=229) | 47/229 (21) | Not reported | 1/229 (<1) | Not reported
| 2) Salmeterol 100 ug (n=218) | 54/218 (25) | Not reported | 0/218 | Not reported
| 3) placebo (n=227) | 59/227 (26) | Not reported | 1/227 (<1) | Not reported

Evidence Table 15. Summary of outcomes for interventions for COPD using spirometry - long-acting β2 agonists

Studies | N | Duration | Long-Acting β2 Agonists Events, % | Placebo Events, % | ARR % [95%CI] | Relative Risk [95%CI] | Baseline Spirometry Range (FEV_1_; %) Predicted
[underlined: Exacerbations: Salmeterol]
Brusasco, 2003 ^89^ | 805 | 6 months | 35.1 | 39 | -4 [-11 to 3] | 0.90 [0.75 to 1.08] | 1.1; 38%
Calverley, 2003 ^87^ | 733 | 1 year | 2.2 | 5.3 | -3 [-6 to 0] | 0.41 [0.18 to 0.92] | 1.3; 45%
Celli, 2003 ^90^ | 825 | 3 months | 17.1 | 21.8 | -5 [-10 to 1] | 0.79 [0.59 to 1.05] | 1.3; 42%
Chapman, 2002 ^94^ | 408 | 6 months | 25.9 | 32.9 | -7 [-16 to 2] | 0.79 [0.58 to 1.07] | 1.2; 45%
Rennard, 2001 ^100^ | 267 | 3 months | 28.8 | 30.4 | -2 [-13 to 9] | 0.95 [0.65 to 1.37] | 1.3
Mahler, 2002 ^96^ | 341 | 6 months | 5.6 | 8.8 | -3 [-9 to 2] | 0.64 [0.29 to 1.40] | 1.3; 41%
van Noord, 2000 ^101^ | 97 | 3 months | 23.4 | 36 | -13 [-31 to 5] | 0.65 [0.34 to 1.23] | 1.1; 40%
Mahler, 1999 ^102^ | 278 | 3 months | 20.7 | 32.9 | -12 [-22 to -2] | 0.63 [0.42 to 0.95] | 41%
Boyd, 1997 ^103^ | 674 | 4 months | 22.6 | 26 | -3 [-10 to 4] | 0.87 [0.66 to 1.15] | 1.3
Overall | 4428 | 3 months – 1 year | 19.7 | 24.5 | -5 [-7 to -2] | 0.81 [0.73 to 0.90] | 1.1–1.3; 38–45%
[underlined: Exacerbations: Formeterol]
Calverley, 2003 ^88^ | 511 | 1 year | 28.6 | 30.9 | -2 [-10 to 6] | 0.93 [0.71 to 1.21] | 1.0; 36%
Aalbers, 2002 ^93^ | 691 | 3 months | 7.1 | 9.2 | -2 [-7 to 3] | 0.77 [0.44 to 1.35] | 1.5; 54%
Rossi, 2002 ^97^ | 645 | 1 year | 27.5 | 34.1 | -7 [-14 to 1] | 0.81 [0.64 to 1.03] | 1.4; 47%
Wadbo, 2002 ^98^ | 121 | 3 months | 37.7 | 38.3 | -1 [-18 to 17] | 0.49 [0.13 to 1.88] | 33%
Dahl, 2001 ^99^ | 586 | 3 months | 16.1 | 18.5 | -2 [-9 to 4] | 0.87 [0.60 to 1.26] | 1.3; 45%
Szafranski, 2003 ^92^ | 406 | 1 year | 18.9 | 25.9 | -7 [-15 to 1] | 0.73 [0.51 to 1.06] | 1.0; 36%
Overall | 2960 | 3 months – 1 year | 19.0 | 25.4 | -4 [-7 to -1] | 0.79 [0.67 to 0.94] | 1.0–1.5; 33–54%
OVERALL | 7388 | 3 months – 1 year | 19.4 | 24.8 | -4 [-6 to -2] | 0.82 [0.76 to 0.90] | 1.1–1.5; 33–54%
Studies | N | Duration | Long-Acting β2 Agonists Events, % | Tiotropium Events, % | ARR | Relative Risk (95%CI) | Baseline Spirometry Range FEV_1_; %) predicted
[underlined: Exacerbations: Salmeterol vs. Tiotropium]
Brusasco, 2003 ^89^ | 807 | 6 months | 35.1 | 32.1 | 3 [-4 to 9] | 1.09 (0.90 to 1.33) | 1.1; 39%
[underlined: Mortality: Salmeterol]
Brusasco, 2003 ^89^ | 805 | 6 months | 1.5 | 1.3 | 0 [-1 to 2] | 1.19 [0.36 to 3.85] | 1.1; 38%
Celli, 2003 ^90^ | 825 | 3 months | 0.18 | 0.73 | -1 [-2 to 1] | 0.24 [0.02 to 2.69] | 1.3; 42%
Hanania, 2003 ^91^ | 362 | 6 months | 0 | 0 | 0 [-1 to 1] | Not estimable | 1.3; 42%
Mahler, 2002 ^96^ | 341 | 6 months | 0 | 1.7 | -2 [-4 to 1] | 0.16 [0.01 to 3.10] | 1.3; 41%
Rennard, 2001 ^100^ | 267 | 3 months | 0 | 0.74 | -1 [-3 to 1] | 0.34 [0.01 to 8.29] | 1.3
Mahler, 1999 ^102^ | 278 | 3 months | 0 | 0 | 0 [-1 to 1] | Not estimable | 41%
Boyd, 1997 ^103^ | 674 | 4 months | 0.22 | 0.44 | 0 [-1 to 1] | 0.51 [0.03 to 8.08] | 1.3
Overall | 3552 | 3 months – 6 months | 0.39 | 0.77 | 0 [-1 to 1] | 0.57 [0.27 to 1.22] | 1.1–1.4; 38–42%
[underlined: Mortality: Formoterol]
Calverley 2003 ^88^ | 511 | 1 year | 5.1 | 2 | 3. [0 to 6] | 2.61 [0.94 to 7.21] | 1.0: 36%
Szafranski, 2003 ^92^ | 406 | 1 year | 3 | 4.4 | -1 [-5 to 2] | 0.68 [0.25 to 1.88] | 1.0; 36%
Rossi, 2002 ^97^ | 645 | 1 year | 0.94 | 0 | 1 [0 to 2] | 4.67 [0.25 to 86.33] | 1.4; 48%
Dahl, 2001 ^99^ | 586 | 3 months | 0 | 0 | 0 [-1 to 1] | Not estimable | 1.3; 45%
Overall | 2148 | 3 months – 1 year | 1.8 | 0.6 | 1 [0 to 2] | 1.52 [0.79 to 2.94] | 1.0–1.4; 36–48%
OVERALL | 5700 | 3 months – 1 year | 0.96 | 1.1 | 0 [0 to 1] | 1.00 [0.62 to 1.62] | 1.0–1.4; 36–48%
[underlined: Mortality: Salmeterol vs. Tiotropium]
Brusasco, 2003 ^89^ | 807 | 6 months | 1.5 | 0.0025 | 1.5 | 5.96 (0.72 to 49.25) | 1.1; 39%
Studies | N | Duration | Long-Acting β2 Agonists: Mean Change | Placebo: Change | | Weighted Mean Difference (95%CI) | Baseline Spirometry Range (FEV1; %) Predicted
[underlined: St George's Respiratory Questionnaire - Mean units of change: Salmeterol]
Brusasco, 2003 ^89^ | 805 | 6 months | -2.8 | -1.5 | Not applicable | -1.30 [-3.24 to 0.64] | 1.1; 38%
Celli, 2003 ^90^ | 825 | 3 months | -5.3 | -3.2 | Not applicable | -2.10 [-4.61 to 0.41] | 1.3; 42%
Chapman, 2002 ^94^ | 408 | 6 months | -2.4 | -0.9 | Not applicable | -1.50 [-4.32 to 1.32] | 1.2; 45%
Jones, 1997 ^46^ | 283 | 4 months | -6.8 | -1.4 | Not applicable | -5.40 [-8.96 to -1.84] | 1.40; 46%
Overall | 2321 | 3 months – 6 months | | | | -2.06 [-3.32 to -0.80] | 1.1–1.40; 38–46%
[underlined: St George's Respiratory Questionnaire - Mean units of change: Formoterol]
Calverley 2003 ^88^ | 511 | 1 year | Not reported | Not reported | Not applicable | -4.1 | 1.0: 36%
Dahl, 2001 ^99^ 12ug | 388 | 3 months | Not reported | Not reported | Not applicable | -5.1 [-7.6 to -2.6] | 1.3; 45%
Dahl, 2001 ^99^ 24ug | 392 | 3 months | Not reported | Not reported | Not applicable | -3.4 [-5.9 to -0.9] | 1.3; 45%
Wadbo, 2002 ^98^ | 121 | 3 months | 0 | 1.5 | Not applicable | -1.5 [-4.61 to 1.61] | 33%
Overall | 1412 | 3 months
OVERALL | 3733 | 3 months – 6 months | | | | -1.98 [-3.15 to -0.81] | 1.1–1.40; 33–46%

Evidence Table 16. Outcomes of studies of sibanet for COPD using spirometry

Study | Intervention | Exacerbations: Total Subjects With >1 Episode n/N (%) | Exacerbations - Other/Hospitalizations Due to COPD / or Other | Mortality: n/N (%) | St George's Respiratory Questionnaire
Celli et al., 2003 ^90^ | | | Deterioration of COPD; n/N % | | Treatment difference vs. pbo; Change per group
| 1) Sibenadet 500 ug t.i.d. (n=543) | 116/543 (21.4) | 89/543 (16.4) | 3/543 (<1) | -4.2 (0.8 SE)
| 2) placebo (n=271) | 59/271 (21.9) | 51/268 (19) | 2/271 (<1) | -3.2 (1.1 SE)
Hiller et al., 2003 ^118^ | | | Deterioration of COPD; n/N %
| 1) Sibenadet 500 ug t.i.d. (n=290) | 125/290 (43.1) | 73/290 (25.2); 12 discontinued the study | 3/290 (1.0) | “No notable differences between the treatment groups”
| 2) placebo (n=145) | 66/145 (45.5) | 39/145 (26.9); 3 discontinued the study | 2/145 (1.4)
Laursen et al., 2003 ^119^ | | | Deterioration of COPD; n/N %
| 1) Sibenadet (n=535) | 77/524 (14.7) (ITT population) | 56/535 (10.5) | 4/535 (<1) | “No statistically significant differences were seen” between the treatment groups
| 2) placebo (n=537) | 94/526 (17.9) (ITT population) | 64/537 (11.9) | 3/537 (<1)
Laursen et al., 2003 ^119^ | | | Deterioration of COPD; n/N % | | Change per group
| 1) Sibenadet (n=609) | 139/591 (23.5)) (ITT population) | 128/609 (21) | 12/609 (2.0) | -3.25 (p ns vs. pbo)
| 2) placebo (n=594) | 149/578 (25.8) (ITT population) | 115/594 (19.4) | 9/594 (1.5) | -2.33

Evidence Table 17. Summary of outcomes for interventions for COPD using spirometry - sibanet

Studies | N | Duration | Sibanet Events, % | Placebo Events, % | ARR % [95% CI] | Relative Risk [95% CI] | Baseline Spirometry Range (FEV_1_; %) Predicted
Exacerbations
Celli, 2003 ^90^ | 814 | 3 months | 21.4 | 21.8 | 0 [-6 to 6] | 0.98 [0.74 to 1.30] | 1.3; 43%
Hiller, 2003 ^118^ | 435 | 1 year | 43.1 | 45.5 | -2 [-12 to 7] | 0.95 [0.76 to 1.18] | 1.3; 41%
Laursen, 2003 ^119^ Study 1 | 1061 | 3 months | 14.7 | 17.9 | -3 [-8 to 1] | 0.82 [0.62 to 1.08] | 1.1*; 39%
Laursen, 2003 ^119^ Study 2 | 1169 | 6.5 months | 23.5 | 25.8 | -2 [-7 to 3] | 0.91 [0.75 to 1.12] | 1.3**; 40%
OVERALL | 3479 | 3 months - 1 year | 23.5 | 24.2 | -2 [-5 to 1] | 0.91 [0.81 to 1.03] | 1.1–1.4; 39–43%
Mortality
Celli, 2003 ^90^ | 814 | 3 months | 0.55 | 0.74 | 0 [-1 to 1] | 0.75 [0.13 to 4.45] | 1.3; 43%
Hiller, 2003 ^118^ | 435 | 1 year | 1 | 1.4 | 0 [-3 to 2] | 0.75 [0.13 to 4.44] | 1.3; 41%
Laursen, 2003 ^119^ Study 1 | 1072 | 3 months | 0.75 | 0.56 | 0 [-1 to 1] | 1.34 [0.30 to 5.95] | 1.1*; 39%
Laursen, 2003 ^119^ Study 2 | 1203 | 6.5 months | 2 | 1.5 | 0 [-1 to 2] | 1.30 [0.55 to 3.06] | 1.3**; 40%
OVERALL | 3524 | 3 months – 1 year | 1.1 | 1 | 0 [-1 to 1] | 1.14 [0.60 to 2.15] | 1.1–1.4; 39–43%
Studies | N | Duration | Long-Acting β2 Agonists: Mean Change | Placebo: Change | | Weighted Mean Difference (95%CI) | Baseline Spirometry Range (FEV_1_; %) Predicted
[underlined: St George's Respiratory Questionnaire - Mean units of change]
Celli, 2003 ^90^ | 814 | 3 months | -4.2 | -3.2 | Not applicable | -1.00 [-3.51 to 1.51] | 1.3; 43%
Laursen, 2003 ^119^ Study 2 | 1203 | 6.5 months | -3.3 | -2.3 | Not applicable | -1 | 1.3**; 40%

* For 130 subjects assessed on day 1 only

** For 152 subjects assessed on day 1 only

Evidence Table 18. Outcomes of studies of pulmonary rehabilitation (program) for COPD using spirometry

Study | Intervention | Exacerbations -Other/ Hospitalizations Due to COPD / or Other | Mortality: n/N (%) | St. George's Respiratory Questionnaire
Ries et al., 2003 ^121^ | | | | Chronic Respiratory Disease Questionnaire; Score at 12 months
| Experimental maintenance intervention (n=87); | Not reported | 10/87 (11.5) | 96.0 (21.3) / n=74
| Control (standard care) (n=85) | Not reported | 10/85 (11.8) | 95.9 (21.1) / n=64
Brooks et al., 2002 ^122^ | Enhanced followup (n=50) | 35 episodes | Not reported | No significant changes between groups
| Control (conventional followup) (n=59) | 33 episodes | Not reported
Finnerty et al., 2001 ^123^ | | | | Treatment difference vs. control; 6-month score for each group
| Rehabilitation (6-week outpatient-based program) (n=50); | Not reported | Not reported | -8.1 (95% CI -14.9 to -1.4); 50.6 (2.5 SE), n=24, p<0.02 vs. control
| Control (n=50) | Not reported | Not reported | 57.1 (3.0 SE), n=25
Griffiths et al., 2000 ^124^ | | Number of patients admitted to hospital | | Treatment difference vs. control; 12-month score for each group
| Rehabilitation (6-week multidisciplinary program) (n=99) | 40 (p=0.98 vs. control) | 6/99 (6.1) | -4.8 (95 %CI -8.4 to -1.2), p=0.010; 61.5 (17.5), n=93
| Control (n=101) | 41 | 12/101 (11.9) | 69 (13.3), n=89
Ringbaek et al., 2000 ^125^ | | Discontinuations due to exacerbation of COPD; n/N % | | Treatment difference vs. control
| Rehabilitation (8 week program) (n=24) | 3/24 (12.5) | Not reported | 0.1 (95% CI -9.8 to 10)
| Control (n=21) | 0/21 | Not reported
Engstrom et al., 1999 ^126^ | | Deterioration of COPD; n/N % | | Change per group
| Rehabilitation (physiotherapy program) (n=26) | 4/26 (15.4) non-compliers to treatment | 0/26 | 0.3 (2.2) ITT pop. / -0.2 (1.9) on treatment (n=20)
| Control (n=24) | 3/24 (12.5) | 0/24 | 2.1 (2.9)
Wedzicha et al., 1998 ^127^ (Moderate) | | | | Treatment difference vs. control; change per group
| Rehabilitation (exercise training and education for 8 weeks) (n=33) | Not reported | 0/33 | -5.4 (95% CI -10.7 to 0.02); -2 (95% CI -6 to 3)
| Control (education) (n=33) | Not reported | 1/33 | 4 (95% CI 1 to 7)
Wedzicha et al., 1998 ^127^ (Severe) | Rehabilitation (exercise training and education for 8 weeks) (n=30) | Not reported | 0/30 | 0.93 (95% CI -3.9 to 5.8); 3 (95% CI -2 to 7)
| Control (education) (n=30) | Not reported | 1/30 | 2 (95% CI -1 to 5)

Evidence Table 19. Outcomes of studies of disease management, education, and followup studies for COPD with/without spirometry

Study | Intervention | Exacerbations: Total Subjects With >1 Episode n/N (%) | Exacerbations - Other / Hospitalizations due to COPD / or Other | Mortality: n/N (%) | St George’s Respiratory Questionnaire; Change in Points (p vs. Control)
Bourbean et al., 2003 ^159^ | | Acute exacerbations (episode) of COPD | COPD hospitalizations; n/N % | | Treatment difference vs. pbo; 12-month change
| Self-management (n=96) | 299 | 31/96 (32.3) | 5/96 (5.2) | -2.0 (-5.9 to 1.8)
| Usual care (placebo) (n=95) | 362 | 48/95 (50.5) | 9/95 (9.5)
Monninkhof et al., 2003 ^160^ | | | | | Treatment difference vs. pbo
| Self-management (n=127) | Not reported | Not reported | 3/127 (2.4) | -0.6 (-2.8 to 1.7)
| Control (n=121) | Not reported | Not reported | 3/121 (2.5)
Hermiz et al., 2002 ^39^ | | | | | Treatment difference vs. pbo
| Enhanced followup (n=84) | Not reported | Not reported | 9/84 (10.7) | 1.32 (-2.97 to 5.62)
| Control (n=93) | Not reported | Not reported | 10/93 (10.8)
Weinberger et al., 2002 ^161^ | | | Breathing-related hospital or ED visit (%)
| Pharmaceutical care program group (n=185) | Not reported | 22.9 | Not reported | Not reported
| Peak flows meter monitoring control group (n=130) | Not reported | 23.9 | Not reported | Not reported
| Usual care control (n=138) | Not reported | 23.2 | Not reported | Not reported
Gallefoss and Bakke, 2000 ^162^ | | | COPD hospitalizations; n/N % | | Means (SD) at followup
| Education (n=31) | Not reported | 0/31 | Not reported | 40.0 (16)
| Control (n=31) | Not reported | 2/31 (6.5) | Not reported | 43.1 (21)
| | | | | p-value = 0.54
| | | Visits to GP or PN; n/N (%) | | Means (SD) at followup
Watson et al., 1997 ^163^ | Self-management (use of Action Plan & booklet) (n=29) | Not reported | 3/29 (10.3) | 0/29 | 39 (17) significant improvement than base [43(15)]
| Control (usual care) (n=27) | Not reported | 2/27 (7.4) | 0/27 | 39 (16)
Weinberger et al., 1996 ^164^ | | | Number of readmissions per month; mean (SD) | According to total study group
| Primary care intervention (n=295) | Not reported | 0.19 (0.3) | 59/695 (8.5) | Not reported
| Control (n=288) | Not reported | 0.14 (0.2) | 47/701 (6.7) | Not reported
| | | p=0.005
Littlejohns et al., 1991 ^165^ | | | Number (%) of admissions to hospital | | Sickness Impact Profile; mean change (95% CI)
| Education/enhanced followup (n=73) | Not reported | 12 (18) | 3/73 (4.1) | 0.63 (-1.60 to 2.87)
| Control (n=79) | Not reported | 14 (21) | 9/79 (11.4) | -0.4 (-1.85 to 1.05)
| | | p=0.80 | | p=0.46
Cockcroft et al, 1987 ^166^ | | | Respiratory illness hospitalizations; n/N %
| Enhanced followup (group visited by respiratory health worker) (n=42) | Not reported | 22/42 (52.4) | 5/42 (11.9) | Not reported
| Control (n=33) | Not reported | 11/33 (33.3) | 7/33 (21.2) | Not reported

Evidence Table 20. Prevalence of symptoms in LH-1 subjects at 3 years by baseline spirometry according to treatment assignment

Baseline Spirometry | Dyspnea (%) | | | Cough and Sputum (%) | | | Respiratory Hospitalizations (mean)*
| Ipratropium | Placebo | Usual Care | Ipratropium | Placebo | Usual Care | Ipratropium | Placebo | Usual Care
Stage 0 and Normal | 31.1 | 26.6 | 34 | 11 | 12.5 | 22 | 0.32 | 0.27 | 0.40
Stage 1 | 25.8 | 27.6 | 32.5 | 16.9 | 11.8 | 26 | 0.29 | 0.37 | 0.67
Stage 2 | 34.5 | 36.1 | 38 | 15.3 | 18.5 | 27.8 | 0.71 | 0.58 | 0.73
Totals | 31 | 31.2 | 35.5 | 14.9 | 15 | 26 | 0.48 | 0.45 | 0.64

There are only 3 patients in Stage 3 and not represented here

* Per 100 patient years