# Appendix C: Abstraction Forms

Interventions for COPD / Spirometry

Article Abstraction Form:

Author (first):___________________________________

Journal:____________________________________________ Year Publication: _________

Country:_____________________________ (where study performed)

Reviewer:_________________________

VERIFICATION/SELECTION OF STUDY ELIGIBILITY

Randomized | Yes | No | Unclear
Placebo or Control (usual care, O2) | Yes | No | Unclear
Subjects with COPD (any GOLD Stage) | Yes | No | Unclear
(i.e irreversible airway obstruction, NOT asthma and NOT α-1 antitrypsin deficiency, or were the outcomes in the group with COPD reported separately?
Age of subjects > 19 years of age | Yes | No | Unclear
Minimum of 50 subjects per arm | Yes | No | Unclear
Study duration ≥ 3 months | Yes | No | Unclear
(exception pulmonary rehabilitation)
Were subjects stable for at least 1 month prior to initiation of therapy | Yes | No | Unclear
Clinical outcomes of interest | Yes | No | Unclear
(death, respiratory death, hospitalizations - any reason or COPD exacerbations, physician visits - any reason or due to COPD, FEV1, FEV1/FVC ratio, SGRQ, CRQ QoL measures)
* Using Spirometry for measurement of PFT | Yes | No | Unclear

Stop if any of the above is “NO”

METHODS

Study Design and Conduct
Subject blinded | Yes | No | Unclear
Provider blinded | Yes | No | Unclear
Intention-to-treat analysis | Yes | No | Unclear
Crossover trial | Yes | No | Unclear

RANDOMIZATION ALLOCATION CONCEALMENT METHOD (circle one)

Clearly adequate: Centralized randomization by telephone, randomization scheme controlled by pharmacy, numbered or coded identical containers administered sequentially, on site computer system which can only be accessed after entering the characteristics of an enrolled participant, sequentially numbered sealed opaque envelopes.

Clearly Inadequate: Alternation (odd-even, etc..), date of birth, date of week

Unclear: Sealed envelopes but not sequentially numbered or opaque, other, list of random numbers read by someone entering patient into trial (open list) or study noted to be random or “randomization” or “random allocation” but no details provided.

PARTICIPANTS

Multi-center or single site (circle one) Total number of subjects eligible______________

Total # subjects enrolled ______________ Subjects completed trial:______________

Setting (circle all that apply): Community Primary Clinic Specialty Clinic Nursing Home

Other ___________________________

| Intervention (or write in subgoups) | | | Placebo/control (write in)
| I | II | III
# Subjects:
Mean age
Men: n / N and %
Women: n / N and %
Age < 65* n / N and %
Age ≥ 65 n / N and %
Race: white n / N and %
Race: black n / N and %
Race: Asian n / N and %
Race: Hispanic n / N and %
Race: Other n/N and %
Asthma n/N and %
Bronchitis n/N and %
Emphysema n/N and %

[underlined: SMOKING HISTORY]

| Intervention (write in) | | | Placebo/control (write in)
| I | II | III
Current smoker
Ex-smoker
Never smoked

Notes:

INTERVENTION

| | Drug name | Dosing regimen (describe)
Intervention | I
| II
| III
[underlined: Placebo / Control]

Notes:

Study duration (months): Mean _________ Median _________

Range:______________ months

SUBJECTS RANDOMIZED / DROPOUTS / FOLLOWED

| | Total Randomized | Lost to attrition | Due to side effects | # available for follow-up
Intervention | I
| II
| III
| IV
| V
Placebo/Control

Notes:

QUALITY OF LIFE

(provide SDs, SEs, p-values and confidence intervals when appropriate)

| Intervention (write in in subgoups) | | | Placebo/control (write in)
| I | II | III
SGRQ*, baseline
SGRQ*, end
SGRQ*, mean change
CRQ **, baseline
CRQ**, end
CRQ**, mean change

* St George's Respiratory Questionnaire

** Chronic Respiratory Questionnaire

CLINICAL OUTCOMES

(provide SDs, SEs, p-values and confidence intervals when appropriate)

| Intervention (write in in subgoups) | | | Placebo/control (write in)
| [underlined: I] | II | III
Deaths, all causes
Death, respiratory
Total hospitalizations - any reason
At least one hospitalization - any reason,
Total hospitalizations - COPD exacerbations
At least one hospitalization - COPD exacerbations
Total physician visits - any reason
At least one physician visit - any reason
Total physician visits - due to COPD
At least one physician visit - due to COPD
Other (describe)

FORCED AIR EXPIRATORY VOLUME (FEV1)

| Intervention (write in subgoups) | | | Placebo/control (write in)
| I | II | III
FEV1, mean at baseline (+ SD/SE if provided)
FEV1, mean at follow-up (+ SD/SE if provided)
FEV1, mean change (if provided)
FEV1, value < 80% > 79% predicted Stage 1:Mild
FEV1 50%–79% Stage 2:Moderate
FEV1 30–49% predicted: Stage 3 Severe
FEV1 < 30% Stage 4 Very Severe
Forced vital capacity ratio (FEV1/FVC), < 70%
Other

CLINICAL SYMPTOMS

| Intervention (write in subgoups) | | | Placebo/control (write in)
| I | II | III
Dyspnea n/N and % | Baseline: | Baseline: | Baseline: | Baseline:
| Followup | Followup | Followup | Follow-up:
Cough | Baseline: | Baseline: | Baseline: | Baseline:
| Follow-up: | Followup: | Followup: | Followup:
Sputum | Baseline: | Baseline:: | Baseline: | Baseline:
| Followup: | Followup | Followup: | Followup:
Wheeze | Baseline: | Baseline: | Baseline: | Baseline:
| Followup: | Followup: | Followup: | Followup:
Combined Clinical Symptoms | Baseline: | Baseline: | Baseline: | Baseline:
| Followup: | Followup: | Followup: | Followup:
Other | Baseline: | Baseline: | Baseline: | Baseline:
| Followup: | Followup: | Followup: | Followup:

* If you need more of this form __________________________________________

[photocopy and attach additional sheets for more than 4 subgroups]

Interventions for Smoking Cessation with the Addition of Spirometry

Article Abstraction Form:

Author (first):________________________________________________

Journal:________________________________________ Year Publication: _________

Country:_____________________________ (where study performed)

Reviewer:_________________________

VERIFICATION/SELECTION OF STUDY ELIGIBILITY

Randomized | Yes | No | Unclear
Placebo or Control | Yes | No | Unclear
Spirometry used | Yes | No | Unclear
Minimum of 50 subjects per arm | Yes | No | Unclear
Study duration ≥ 3 months | Yes | No | Unclear

Stop if any of the above is “NO”

METHODS

Study Design and Conduct
Subject blinded | Yes | No | Unclear
Provider blinded | Yes | No | Unclear
Intention-to-treat analysis | Yes | No | Unclear
Crossover trial | Yes | No | Unclear

RANDOMIZATION ALLOCATION CONCEALMENT METHOD (circle one)

Clearly adequate: Centralized randomization by telephone, randomization scheme controlled by pharmacy, numbered or coded identical containers administered sequentially, on-site computer system which can only be accessed after entering the characteristics of an enrolled participant, sequentially numbered sealed opaque envelopes.

Clearly Inadequate: Alternation (odd-even, etc..), date of birth, date of week

Unclear: Sealed envelopes but not sequentially numbered or opaque, other, list of random numbers read by someone entering patient into trial (open list) or study noted to be random or “randomization” or “random allocation” but no details provided.

PARTICIPANTS

Multicenter or single site (circle one)

Total number of subjects eligible______________

Total # subjects enrolled ______________ Subjects completed trial:______________

Setting (circle all that apply): Community Primary Clinic Specialty Clinic Nursing Home

Other ___________________________

Intervention (write in) | | Placebo/control (write in)
# Subjects: | | # Subjects:
Mean age | | Mean age
Men: n / N and % | | Men: n / N and %
Women: n / N and % | | Women: n / N and %
Age < 65* n / N and % | | Age ≥ 65 n / N and %
Age ≥ 65 n / N and % | | Age ≥ 65 n / N and %
Race: white n / N and % | | Race: white n / N and %
Race: black n / N and % | | Race: black n / N and %
Race: Asian n / N and % | | Race: Asian n / N and %
Race: Other n / N and % | | Race: Other n / N and %
Living status: alone n / N and % | | Living status: alone n / N and %
Living status: with smoker | | Living status: with smoker
Living status: with non smoker | | Living status: with non smoker
COPD: n / N and % | | COPD: n / N and %
Emphysema: n / N and % | | Emphysema: n / N and %
Other | | Other
Other | | Other

SMOKING HISTORY

(provide SDs, SEs, ranges, p-values and confidence intervals when appropriate)

Intervention (write in) | | Placebo/control (write in)
Mean # cigarettes Smoked/day | | Mean # cigarettes Smoked/day
Pack years | | Pack years
Mean age when starting smoking | | Mean age when starting smoking
Nicotine content > 1 mg/cig | | Nicotine content > 1 mg/cig
Nicotine content < 1 mg/cig | | Nicotine content < 1 mg/cig
Any prior attempt to quit | | Any prior attempt to quit
Prior attempts: none | | Prior attempts: none
Prior attempts: 1–2 | | Prior attempts: 1–2
Prior attempts: ≥ 3 | | Prior attempts: ≥ 3
Previous nicotine patch use | | Previous nicotine patch use
Previous nicotine gum use | | Previous nicotine gum use
Mean Fagerström score | | Mean Fagerström score
Other | | Other
Other | | Other
Other | | Other

Notes:

BASELINE LUNG FUNCTION

(provide SDs, SEs, ranges, p-values and confidence intervals when appropriate)

Intervention (write in) | | Placebo / control (write in)
FEV1, mean | | FEV1, mean
FEV1, value, % predicted | | FEV1, value, % predicted
Forced vital capacity ratio (FEV1/FVC), | | Forced vital capacity ratio (FEV1/FVC),
CO, ppb | | CO, ppb

INTERVENTION

| Intervention name: description | Intervention frequency (describe)
Intervention
Placebo / Control

Notes:

Mean study duration _________ months

Median study duration ________ months

Range:______________ months

SUBJECTS RANDOMIZED / DROPOUTS / FOLLOWED

| Total Randomized | Lost to attrition | Due to side effects | # available for follow-up
Intervention
Placebo/Control

Notes:

CESSATION

(provide SDs, SEs, p-values and confidence intervals when appropriate)

Intervention (write in) | | Placebo/control (write in)
Quit rate, last followup | | Quit rate, last followup
Made ≥ 1 attempt to quit or “ever quit” | | Made ≥ 1 attempt to quit or “ever quit”
CO-validated cessation | | CO-validated cessation
Other (describe) | | Other (describe)
Other (describe) | | Other (describe)
Other (describe) | | Other (describe)

FORCED AIR EXPIRATORY VOLUME (FEV1)

Intervention (write in) | | Placebo / control (write in)
FEV1, mean at baseline (+ SD/SE if provided) | | FEV1, mean at baseline (+ SD/SE if provided)
FEV1, mean at followup (+ SD/SE if provided) | | FEV1, mean at followup (+ SD/SE if provided)
FEV1, mean change (if provided) | | FEV1, mean change (if provided)
FEV1, value < 80% predicted | | FEV1, value < 80% predicted
Forced vital capacity ratio (FEV1/FVC), < 70% | | Forced vital capacity ratio (FEV1/FVC), < 70%
CO, ppb | | CO, ppb

QUALITY OF LIFE

(provide SDs, SEs, p-values and confidence intervals when appropriate)

Intervention (write in) | | Placebo / control (write in)
SGRQ*, mean change | | SGRQ*, mean change
CRQ**, mean change | | CRQ**, mean change

* St George's Respiratory Questionnaire

** Chronic Respiratory Questionnaire

For SUBGROUPS - photocopy Outcomes pages and attach

Subgroup __________________________________________

Intervention (write in) | | Placebo/control (write in)
# Subjects: | | # Subjects:
Mean age | | Mean age
Men: n / N and % | | Men: n / N and %
Women: n / N and % | | Women: n / N and %
Age < 65* n / N and % | | Age ≥ 65 n / N and %
Age ≥ 65 n / N and % | | Age ≥ 65 n / N and %
Race: white n / N and % | | Race: white n / N and %
Race: black n / N and % | | Race: black n / N and %
Race: Asian n / N and % | | Race: Asian n / N and %
Race: Other n / N and % | | Race: Other n / N and %

SMOKING HISTORY

Intervention (write in) | | Placebo/control (write in)
Mean # cigarettes Smoked/day | | Mean # cigarettes Smoked/day
Pack years | | Pack years
Nicotine content > 1 mg/cig | | Nicotine content > 1 mg/cig
Nicotine content < 1 mg/cig | | Nicotine content < 1 mg/cig
Any prior attempt to quit | | Any prior attempt to quit
Prior attempts: none | | Prior attempts: none
Prior attempts: 1–2 | | Prior attempts: 1–2
Prior attempts: ≥ 3 | | Prior attempts: ≥ 3
Other | | Other
Other | | Other

Notes:

Subgroup 1________________________________________

[photocopy and attach additional sheets for more than 2 subgroups]

| Total Randomized | Total Dropouts | Due to side effects | # available for follow-up
Intervention
Placebo/Control

Notes:

Prevalence COPD / Spirometry

Article Abstraction Form:

Author (first):___________________________________

Journal:________________________________________ Year Publication: _________

Country:_____________________________ (where study performed)

Reviewer:_________________________

VERIFICATION/SELECTION OF STUDY ELIGIBILITY

Subjects with COPD | Yes | No | Unclear
(i.e., irreversible airway obstruction, NOT asthma and NOT α-1 antitrypsin deficiency, or were the outcomes in the group with COPD reported separately?
FEV1/FVC measured with spirometry | Yes | No | Unclear

TYPE OF STUDY

Source of data (circle): Epidemiologic survey Cohort study Case/Control

Other (describe)______________________________________

Prospective_____ Retrospective______ Unclear_____

Subjects selected at random? | Yes | No | Unclear
Control Group (i.e subjects with no COPD) | Yes | No | Unclear
Multivariate analyses used? | Yes | No | Unclear

SUBJECTS

Total number of subjects ______________

COPD subjects ______________ Control subjects __________________

Setting (circle all that apply): Community Primary Clinic Specialty Clinic Nursing Home

Other (describe)______________________________________

DEMOGRAPHICS

COPD subjects (write in) | | No COPD / Control (write in)
# Subjects: | | # Subjects:
Mean age | | Mean age
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Men: n / N and % | | Men: n / N and %
Women: n / N and % | | Women: n / N and %
Age < 65* n / N and % | | Age ≥ 65 n / N and %
Age ≥ 65 n / N and % | | Age ≥ 65 n / N and %
Race: white n / N and % | | Race: white n / N and %
Race: black n / N and % | | Race: black n / N and %
Race: Asian n / N and % | | Race: Asian n / N and %
Race: Other n / N and % | | Race: Other n / N and %

SMOKING HISTORY

COPD subjects (write in) | | No COPD / Control (write in)
Current smoker | | Current smoker
Ex-smoker | | Ex-smoker
Never smoked | | Never smoked
Duration, pack years | | Duration, pack years
Other (write in) | | Other (write in)

Notes:

FEV1/FVC

COPD subjects (write in) | | No COPD / Control (write in)
Mean FEV1, L | | Mean FEV1, L
Mean FEV1, % of predicted | | Mean FEV1, % of predicted
FEV1 < 50% predicted | | FEV1 < 50% predicted
FEV1 50–70% predicted | | FEV1 50–70% predicted
FEV1 70%–80% predicted | | FEV1 70%–80% predicted
FEV1/FVC <0.70 and FEV1<50% predicted (severe) | | FEV1/FVC <0.70 and FEV1<50% predicted (severe)
FEV1/FVC <0.70 and FEV1≥50–<80% predicted (moderate) | | FEV1/FVC <0.70 and FEV1≥50–<80% predicted (moderate)
FEV1/FVC <0.70 and FEV1≥ 80% predicted (mold) | | FEV1/FVC <0.70 and FEV1≥ 80% predicted (mold)
GOLD, stage 0 Cough, FEV1/FVC >0.70 | | GOLD, stage 0 Cough, FEV1/FVC >0.70
GOLD, stage 1 FEV1/FVC <0.70, FEV1 ≥ 80% pred | | GOLD, stage 1 FEV1/FVC <0.70, FEV1 ≥ 80% pred
GOLD, stage 2 FEV1/FVC <0.70, FEV1≥30% and < 80% pred | | GOLD, stage 2 FEV1/FVC <0.70, FEV1≥30% and < 80% pred
GOLD, stage 3 FEV1/FVC <0.70, FEV1< 30% pred | | GOLD, stage 3 FEV1/FVC <0.70, FEV1< 30% pred
Other (write in) | | Other (write in)

Notes:

COPD SUBGROUPS (Based on severity—mild, moderate, severe—or GOLD stage)

Subgroup 1 __________________________________________

[photocopy and attach additional sheets for more than 3 subgroups]

COPD subjects (write in) | | No COPD / Control (write in)
# Subjects: | | # Subjects:
Mean age | | Mean age
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Men: n / N and % | | Men: n / N and %
Women: n / N and % | | Women: n / N and %
Age < 65* n / N and % | | Age ≥ 65 n / N and %
Age ≥ 65 n / N and % | | Age ≥ 65 n / N and %
Race: white n / N and % | | Race: white n / N and %
Race: black n / N and % | | Race: black n / N and %
Race: Asian n / N and % | | Race: Asian n / N and %
Race: Other n / N and % | | Race: Other n / N and %

SMOKING HISTORY

COPD subjects (write in) | | No COPD / Control (write in)
Current smoker | | Current smoker
Ex-smoker | | Ex-smoker
Never smoked | | Never smoked
Duration, pack years | | Duration, pack years
Other (write in) | | Other (write in)

Notes:

FEV1/FVC

COPD subjects (write in) | | No COPD / Control (write in)
Mean FEV1, L | | Mean FEV1, L
Mean FEV1, % of predicted | | Mean FEV1, % of predicted
FEV1 < 50% predicted | | FEV1 < 50% predicted
FEV1 50–70% predicted | | FEV1 50–70% predicted
FEV1 70%–80% predicted | | FEV1 70%–80% predicted
FEV1/FVC <0.70 and FEV1<50% predicted (severe) | | FEV1/FVC <0.70 and FEV1<50% predicted (severe)
FEV1/FVC <0.70 and FEV1≥50–<80% predicted (moderate) | | FEV1/FVC <0.70 and FEV1≥50–<80% predicted (moderate)
FEV1/FVC <0.70 and FEV1≥ 80% predicted (mold) | | FEV1/FVC <0.70 and FEV1≥ 80% predicted (mold)
GOLD, stage 0 Cough, FEV1/FVC >0.70 | | GOLD, stage 0 Cough, FEV1/FVC >0.70
GOLD, stage 1 FEV1/FVC <0.70, FEV1 ≥ 80% pred | | GOLD, stage 1 FEV1/FVC <0.70, FEV1 ≥ 80% pred
GOLD, stage 2 FEV1/FVC <0.70, FEV1≥30% and < 80% pred | | GOLD, stage 2 FEV1/FVC <0.70, FEV1≥30% and < 80% pred
GOLD, stage 3 FEV1/FVC <0.70, FEV1<30% pred | | GOLD, stage 3 FEV1/FVC <0.70, FEV1<30% pred
Other (write in) | | Other (write in)

Notes:

Subgroup 2 __________________________________________

COPD (write in)________________________ | | COPD (write in)________________________
# Subjects: | | # Subjects:
Mean age | | Mean age
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Men: n / N and % | | Men: n / N and %
Women: n / N and % | | Women: n / N and %
Age < 65* n / N and % | | Age ≥ 65 n / N and %
Age ≥ 65 n / N and % | | Age ≥ 65 n / N and %
Race: white n / N and % | | Race: white n / N and %
Race: black n / N and % | | Race: black n / N and %
Race: Asian n / N and % | | Race: Asian n / N and %
Race: Other n / N and % | | Race: Other n / N and %

SMOKING HISTORY

COPD subjects (write in) | | No COPD / Control (write in)
Current smoker | | Current smoker
Ex-smoker | | Ex-smoker
Never smoked | | Never smoked
Duration, pack years | | Duration, pack years
Other (write in) | | Other (write in)

Notes:

FEV1/FVC

COPD subjects (write in) | | No COPD / Control (write in)
Mean FEV1, L | | Mean FEV1, L
Mean FEV1, % of predicted | | Mean FEV1, % of predicted
FEV1 < 50% predicted | | FEV1 < 50% predicted
FEV1 50–70% predicted | | FEV1 50–70% predicted
FEV1 70%–80% predicted | | FEV1 70%–80% predicted
FEV1/FVC <0.70 and FEV1<50% predicted (severe) | | FEV1/FVC <0.70 and FEV1<50% predicted (severe)
FEV1/FVC <0.70 and FEV1≥50–<80% predicted (moderate) | | FEV1/FVC <0.70 and FEV1≥50–<80% predicted (moderate)
FEV1/FVC <0.70 and FEV1≥ 80% predicted (mold) | | FEV1/FVC <0.70 and FEV1≥ 80% predicted (mold)
GOLD, stage 0* Cough, FEV1/FVC >0.70 | | GOLD, stage 0 Cough, FEV1/FVC >0.70
GOLD, stage 1 FEV1/FVC <0.70, FEV1 ≥ 80% pred | | GOLD, stage 1 FEV1/FVC <0.70, FEV1 ≥ 80% pred
GOLD, stage 2 FEV1/FVC <0.70, FEV1≥30% and < 80% pred | | GOLD, stage 2 FEV1/FVC <0.70, FEV1≥30% and < 80% pred
GOLD, stage 3 FEV1/FVC <0.70, FEV1< 30% pred | | GOLD, stage 3 FEV1/FVC <0.70, FEV1< 30% pred
GOLD, stage 4
Other (write in) | | Other (write in)

Notes:

* GOLD, Stage 0 = at risk

GOLD, Stage 1 = mild COPD

GOLD, Stage 2 = moderate COPD

GOLD, Stage 3 = severe COPD

GOLD, Stage 4 = very severe COPD

PREVALENCE (MILD COPD)

Write in definition______________________________________________________

Time of followup___________________________

COPD subjects (write in) | | No COPD / Control (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Men: n / N and % | | Men: n / N and %
Women: n / N and % | | Women: n / N and %
Race: white n / N and % | | Race: white n / N and %
Race: black n / N and % | | Race: black n / N and %
Race: Asian n / N and % | | Race: Asian n / N and %
Race: Other n / N and % | | Race: Other n / N and %
Current smoker | | Current smoker
Ex-smoker | | Ex-smoker
Never smoked | | Never smoked

PREVALENCE (MODERATE COPD)

Write in definition______________________________________________________

Time of follow-up___________________________

COPD subjects (write in) | | No COPD / Control (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Men: n / N and % | | Men: n / N and %
Women: n / N and % | | Women: n / N and %
Race: white n / N and % | | Race: white n / N and %
Race: black n / N and % | | Race: black n / N and %
Race: Asian n / N and % | | Race: Asian n / N and %
Race: Other n / N and % | | Race: Other n / N and %
Current smoker | | Current smoker
Ex-smoker | | Ex-smoker
Never smoked | | Never smoked
Other

PREVALENCE (SEVERE COPD)

Write in definition______________________________________________________

Time of followup___________________________

COPD subjects (write in) | | No COPD / Control (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Age, years (write in) | | Age, years (write in)
Men: n / N and % | | Men: n / N and %
Women: n / N and % | | Women: n / N and %
Race: white n / N and % | | Race: white n / N and %
Race: black n / N and % | | Race: black n / N and %
Race: Asian n / N and % | | Race: Asian n / N and %
Race: Other n / N and % | | Race: Other n / N and %
Current smoker | | Current smoker
Ex-smoker | | Ex-smoker
Never smoked | | Never smoked

POSTIVE PREDICTIVE VALUE

COPD subjects (write in) | | No COPD / Control (write in)

QUALITY OF LIFE

(provide SDs, SEs, p-values and confidence intervals when appropriate)

COPD subjects (write in) | | No COPD / Control (write in)
SGRQ*, baseline | | SGRQ*, baseline
SGRQ*, end | | SGRQ*, end
SGRQ*, mean change | | SGRQ*, mean change
CRQ **, baseline | | CRQ**, baseline
CRQ**, end | | CRQ**, end
CRQ**, mean change | | CRQ**, mean change
SF-36-Physical functioning
SF-36-
SF-36-

* St George's Respiratory Questionnaire

** Chronic Respiratory Questionnaire

For SUBGROUPS - photocopy Outcomes pages and attach