# Appendix B Exact Search Strings

Search Strings for Use of Spirometry for Case Finding, Diagnosis, and Management of Chronic Obstructive Pulmonary Disease (COPD)

[underlined: Question 1 (prevalence)]

The literature search was done on MEDLINE (via OVID) using the following combination of MeSH headings, keywords, and publication types:

((copd.mp. OR

Pulmonary Disease, Chronic Obstructive/ OR

chronic obstructive pulmonary disease.mp. OR

emphysema.mp. OR

emphysema/ OR

bronchitis.mp. OR

bronchitis/ OR

chronic bronchitis.mp. OR

bronchitis, chronic/ OR

airflow limitation.mp. OR

airway obstruction/)

AND

(diagnosis.mp. OR

diagnosis/ OR

epidemiology.mp. OR

epidemiology/ OR

community.mp. OR

residence characteristics/ OR

catchment.mp. OR

“catchment area (health)”/ OR

prevalence.mp. OR

prevalence/ OR

incidence.mp. OR

incidence/ OR

risk assessment.mp. OR

risk assessment/ OR

(high adj1 risk).ti,ab.)

AND

(spirometry.mp. or spirometry/ OR

bronchospirometry.mp. OR

bronchospirometry/ OR

respiratory function tests.mp. OR

respiratory function tests/)

AND

(cohort studies/ OR

case reports.pt. OR

case-control studies/))

OR

((exp pulmonary disease, chronic obstructive/ OR

copd.mp.)

AND

(exp spirometry/ OR

spiromet:.mp.)

AND

(exp pulmonary disease, chronic obstructive/ep OR

prevalen:.mp. OR

prevalence/))

[underlined: Question 2 (smoking cessation)]

The literature search was done on MEDLINE (via OVID) using the following combination of MeSH headings, keywords, and publication types:

((copd.mp. OR

Pulmonary Disease, Chronic Obstructive/ OR

chronic obstructive pulmonary disease.mp. OR

emphysema.mp. OR

emphysema/ OR

bronchitis.mp. OR

bronchitis/ OR

chronic bronchitis.mp. OR

bronchitis, chronic/ OR

airflow limitation.mp. OR

airway obstruction/)

AND

(spirometry.mp. OR

spirometry/ OR

bronchospirometry.mp. OR

bronchospirometry/ OR

respiratory function tests.mp. OR

respiratory function tests/)

AND

(smoking/ OR

smoking cessation/ OR

smoking cessation therapy.mp. OR

smoking psychology.mp.)

AND

(randomized controlled trial.pt. OR

controlled clinical trial.pt. OR

case-control studies/))

OR

((exp spirometry/ OR

spiromet:.mp.)

AND

(smoking cessation/ OR

(smoking adj cessation).mp. OR

exp smoking/dh, dt, th))

[underlined: Question 3 (Sin review update)]

The literature search was done on MEDLINE (via OVID) using the following combination of MeSH headings, keywords, and publication types (search results were limited to controlled clinical trials, meta analyses or randomized controlled trials, and limited to references published from the years 2002 to 2004):

[underlined: Combination of short-acting β-2 agonists and ipratropium bromide]

(obstructive.mp. OR

chronic obstructive.mp. OR

bronchitis.mp. OR

bronchitis/ OR

emphysema.mp. OR

mediastinal emphysema / OR

subcutaneous emphysema / OR

emphysema / OR

pulmonary emphysema / OR

airway obstruction.mp. OR

airway obstruction/ OR

copd.mp. OR

Pulmonary Disease, Chronic Obstructive/ or

lung diseases, obstructive/)

AND

(Ipratropium/ AND

adrenergic β-agonists/)

[underlined: Long-acting β-2 Agonists]

(obstructive.mp. OR

chronic obstructive.mp. OR

bronchitis.mp. OR

bronchitis/ OR

emphysema.mp. OR

mediastinal emphysema / OR

subcutaneous emphysema / OR

emphysema / OR

pulmonary emphysema / OR

airway obstruction.mp. OR

airway obstruction/ OR

copd.mp. OR

Pulmonary Disease, Chronic Obstructive/ or

lung diseases, obstructive/)

AND

(adrenergic β-agonists/ OR

receptors, adrenergic, β -2/ OR

(adrenergic adj1 beta).ti,ab. OR

salmeterol.mp. OR

formoterol.mp.)

[underlined: Long-acting Anticholinergics]

(obstructive.mp. OR

chronic obstructive.mp. OR

bronchitis.mp. OR

bronchitis/ OR

emphysema.mp. OR

mediastinal emphysema / OR

subcutaneous emphysema / OR

emphysema / OR

pulmonary emphysema / OR

airway obstruction.mp. OR

airway obstruction/ OR

copd.mp. OR

Pulmonary Disease, Chronic Obstructive/ or

lung diseases, obstructive/)

AND

(cholinergic antagonists/ OR

tiotropium.mp. OR

scopolamine derivatives/)

[underlined: Inhaled Corticosteroids]

(obstructive.mp. OR

chronic obstructive.mp. OR

bronchitis.mp. OR

bronchitis/ OR

emphysema.mp. OR

mediastinal emphysema / OR

subcutaneous emphysema / OR

emphysema / OR

pulmonary emphysema / OR

airway obstruction.mp. OR

airway obstruction/ OR

copd.mp. OR

Pulmonary Disease, Chronic Obstructive/ or

lung diseases, obstructive/)

AND

(glucocorticosteroids.mp. OR

corticosteroids/ OR

beclomethasone.mp. OR

budesonide.mp. OR

fluticasone.mp. OR

triamcinolone.mp.)

[underlined: Combination of Inhaled Corticosteroids and Long-Acting β-2 Agonists]

(obstructive.mp. OR

chronic obstructive.mp. OR

bronchitis.mp. OR

bronchitis/ OR

emphysema.mp. OR

mediastinal emphysema / OR

subcutaneous emphysema / OR

emphysema / OR

pulmonary emphysema / OR

airway obstruction.mp. OR

airway obstruction/ OR

copd.mp. OR

Pulmonary Disease, Chronic Obstructive/ or

lung diseases, obstructive/)

AND

(glucocorticosteroids.mp. OR

corticosteroids/ OR

beclomethasone.mp. OR

budesonide.mp. OR

fluticasone.mp. OR

triamcinolone.mp.)

AND

(salmeterol.mp. OR

formoterol.mp.)

[underlined: Non-invasive Mechanical Ventilation]

(obstructive.mp. OR

chronic obstructive.mp. OR

bronchitis.mp. OR

bronchitis/ OR

emphysema.mp. OR

mediastinal emphysema / OR

subcutaneous emphysema / OR

emphysema / OR

pulmonary emphysema / OR

airway obstruction.mp. OR

airway obstruction/ OR

copd.mp. OR

Pulmonary Disease, Chronic Obstructive/ or

lung diseases, obstructive/)

AND

(nippv.mp. OR

nimv.mp. OR

bi-level.mp. OR

respiration, artificial/ OR

positive-pressure respiration/)

[underlined: Pulmonary Rehabilitation]

(obstructive.mp. OR

chronic obstructive.mp. OR

bronchitis.mp. OR

bronchitis/ OR

emphysema.mp. OR

mediastinal emphysema / OR

subcutaneous emphysema / OR

emphysema / OR

pulmonary emphysema / OR

airway obstruction.mp. OR

airway obstruction/ OR

copd.mp. OR

Pulmonary Disease, Chronic Obstructive/ or

lung diseases, obstructive/)

AND

(exercise tolerance/ OR

dyspnea/rh [Rehabilitation] OR

exercise therapy/)

[underlined: Oxygen Therapy]

(obstructive.mp. OR

chronic obstructive.mp. OR

bronchitis.mp. OR

bronchitis/ OR

emphysema.mp. OR

mediastinal emphysema / OR

subcutaneous emphysema / OR

emphysema / OR

pulmonary emphysema / OR

airway obstruction.mp. OR

airway obstruction/ OR

copd.mp. OR

Pulmonary Disease, Chronic Obstructive/ or

lung diseases, obstructive/)

AND

oxygen inhalation therapy/

[underlined: Disease Management]

(obstructive.mp. OR

chronic obstructive.mp. OR

bronchitis.mp. OR

bronchitis/ OR

emphysema.mp. OR

mediastinal emphysema / OR

subcutaneous emphysema / OR

emphysema / OR

pulmonary emphysema / OR

airway obstruction.mp. OR

airway obstruction/ OR

copd.mp. OR

Pulmonary Disease, Chronic Obstructive/ or

lung diseases, obstructive/)

AND

(self care/ OR

patient education/ OR

primary health care/)

[underlined: Question 4 (prognosis)]

The literature search was done on MEDLINE (via OVID) using the following combination of MeSH headings, keywords, and publication types:

((copd.mp. OR

Pulmonary Disease, Chronic Obstructive/ OR

chronic obstructive pulmonary disease.mp. OR

emphysema.mp. OR

emphysema/ OR

bronchitis.mp. OR

bronchitis/ OR

chronic bronchitis.mp. OR

bronchitis, chronic/ OR

airflow limitation.mp. OR

airway obstruction/)

AND

(spirometry.mp. OR

spirometry/ OR

bronchospirometry.mp. OR

bronchospirometry/ OR

respiratory function tests.mp. OR

respiratory function tests/)

AND

(prognosis/ OR

prognosis.mp.)

AND

(cohort studies/ OR

case reports.pt. OR

case-control studies/))

OR

((exp pulmonary disease, chronic obstructive/ OR

copd.mp.)

AND

(exp spirometry/ OR

spiromet:.mp.)

AND

(exp prognosis/ OR

prognos:.mp.))