# Appendix A Technical Expert Panel Members

Technical Expert Panel Members and Areas of Expertise

TEP Member | Area of Expertise
John Connett, PhD | Biostatistics
University of Minnesota School of Public Health
Minneapolis, Minnesota
Anne Fuhlbrigge, MD | Epidemiology, COPD
Brigham and Women's Hospital
Harvard Medical School
Boston, Massachusetts
Anne Marie Joseph, MD | General medicine, smoking cessation
VA Medical Center
Minneapolis, Minnesota
Michael Light, MD | Pediatrics, airways disease
University of Miami School of Medicine
Miami, Florida
Katherine Sherif, MD | General medicine, disease prevention
Center for Women's Health
Drexel University College of Medicine
Philadelphia, Pennsylvania
Stuart W. Stoloff, MD | Primary care, airways disease
Stuart W. Stoloff, MD, Ltd.
Carson City, Nevada
Barbara Yawn | Pulmonary care, airways disease
Olmsted Medical Center
Rochester, Minnesota